# Appendix E Integrated Discrimination Improvement Evidence

Appendix E Table 1 Integrated Discrimination Improvement in Included ABI Risk Prediction Studies

Model Type: Base Model | Author, Year | Study Name | N | Outcome^*^ | Subgroup | IDI (95% CI) | IDI p-value
Published coefficient: FRS | Velescu, 2015^91^ | REGICOR | 5,182 | Soft CVD | All Participants | 1.11 (0.67 to 1.55) | <0.001
Published coefficient: FRS | Velescu, 2015^91^ | REGICOR | 5,182 | Soft CHD | All Participants | 0.63 (0.32 to 0.95) | <0.001
Model development: FRS variables | Murphy, 2012^79^ | ARIC | 11,594 | Hard CVD | All Participants | 0.075 (NR to NR) | 0.0002
Model development: FRS variables | Holewijn, 2014^95^ | Nijmegen Biomedical Study | 659 | Soft CVD | Women | 0.025 (NR to NR) | 0.087
Model development: FRS variables | Holewijn, 2014^95^ | Nijmegen Biomedical Study | 582 | Soft CVD | Men | 0.013 (NR to NR) | 0.263

* Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities study; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; FRS=Framingham Risk Score; IDI = integrated discrimination improvement; NR = not reported; NRI = net reclassification improvement; REGICOR = Registre Gironί del Cor (Girona Heart Registry)

Appendix E Table 2 Integrated Discrimination Improvement in Included hsCRP Risk Prediction Studies

Model Type: Base Model | Author, Year | Study Name | N | Outcome^*^ | Subgroup | IDI (95% CI) | IDI p-value
Published coefficient: FRS | Lyngbaek, 2013^96^ | MONICA - Copenhagen | 1,168 | Hard CVD | Women | 0.004 (-0.001 to 0.008) | 0.058
Published coefficient: FRS | Lyngbaek, 2013^96^ | MONICA - Copenhagen | 1,147 | Hard CVD | Men | 0.018 (0.008 to 0.028) | <0.001
Model development: FRS variables | Wannamethee, 2011^102^ | British Regional Heart Study | 2,854 | Hard CVD | All Participants | 0.32 (NR to NR) | 0.14
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | 72,574 | Hard CVD | All Participants | 0.0036 (0.0028 to 0.0043) | <0.0001
Model development: FRS variables | Mohlenkamp, 2011^103^ | HNR | 3,966 | Hard CHD | All Participants | 0.0015 (NR to NR) | 0.32
Model development: FRS variables | Seven, 2015^92^ | Inter99 | 6,138 | Soft CVD | All Participants | 0.003 (NR to NR) | <0.001

* Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; ERFC IPD MA= Emerging Risk Factors Collaboration individual participant data meta-analysis; IDI = integrated discrimination improvement; FRS = Framingham Risk Score; HNR = Heinz Nixdorf Recall study; hsCRP = high sensitivity C-reactive protein; MONICA = MONItoring of trends and determinants in CArdiovascular disease; NR = not reported; NRI = net reclassification improvement

Appendix E Table 3 Integrated Discrimination Improvement in Included CAC Risk Prediction Studies

Model Type: Base Model | Author, Year | Study Name | N | Outcomeǁ | Subgroup | IDI (95% CI) | IDI p-value
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 3,556 | Hard CVD | Women | 0.0069 (NR to NR) | 0.032
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 3,186 | Hard CVD | Men | 0.0117 (NR to NR) | <0.001
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 1,850 | Hard CVD | African American | 0.014 (NR to NR) | <0.001
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 2,599 | Hard CVD | Caucasian | 0.012 (NR to NR) | <0.001
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 801 | Hard CVD | Chinese American | 0.005 (NR to NR) | 0.27
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 1,492 | Hard CVD | Hispanic | 0.006 (NR to NR) | 0.23
Model development: PCE variables | Bos, 2015^89^ | Rotterdam | 2,408 | Fatal CVD | All Participants | 0.18 (0.07 to 0.3)^*^ | NR
Model development: FRS variables | Erbel, 2010^74^ | HNR | 4,129 | Hard CHD | All Participants | 0.0152 (NR to NR) | <0.0001
Model development: FRS variables | Mohlenkamp, 2011^103^ | HNR | 3,966 | Hard CHD | All Participants | 0.0148 (NR to NR) | <0.0001
Model development: FRS variables | Rana, 2012^99^ | EISNER | 1,279 | Soft CVD | All Participants | 0.076 (NR to NR) | 0.0001
Model development: FRS variables | Chang, 2015^93^ | Houston Methodist DeBakey Heart and Vascular Center | 946 | Soft CHD | All Participants | 0.035 (NR to NR)^†^ | <0.0001
Model development: FRS variables | Chang, 2015^93^ | Houston Methodist DeBakey Heart and Vascular Center | 655 | Soft CHD | Intermediate Risk | 0.029 (NR to NR)^‡^ | <0.0001
Model development: FRS variables | Polonsky, 2010^77^ | MESA | 5,878 | Soft CHD | All Participants | 0.026 (NR to NR)^§^ | <0.001

* Reported as relative IDI (ratio of the absolute difference in discrimination slopes of the 2 models over the discrimination slope of the reference model)

† Relative IDI=2.85

‡ Relative IDI=1.62

§ Relative IDI showed 81% improvement in discrimination slope

ǁ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; IDI = integrated discrimination improvement; FRS = Framingham Risk Score; HNR = Heinz Nixdorf Recall study; MESA = Multi-Ethnic Study of Atherosclerosis; NR = not reported