# Appendix D Excluded Studies

Reason for Exclusion
E1. | Aim
E2. | Setting
E3. | Population
E4. | Outcomes
*E4a. | Outcome of CVA only
*E4b. | Outcome of all-cause mortality only
†E4c. | Radiation dose only
E5. | Intervention
E6. | Study design
E7. | Quality
E8 | Language
*E9. | Base model
E10. | Comparator
E11. | Ancillary article meeting criteria but not outcomes not abstracted

* KQ2-specific exclusion code

† KQ3-specific exclusion code

1 Abbott RD, Petrovitch H, Rodriguez BL, . Ankle/brachial blood pressure in men >70 years of age and the risk of coronary heart disease. Am J Cardiol. 2000;86(3):280-4. PMID: 10922433. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.10922433
2 Abbott RD, Rodriguez BL, Petrovitch H, . Ankle-brachial blood pressure in elderly men and the risk of stroke: the Honolulu Heart Program. J Clin Epidemiol. 2001;54(10):973-8. PMID: 11576807. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.11576807
3 AbouEzzeddine OF, McKie PM, Scott CG, . Biomarker-based risk prediction in the community. Eur J Heart Fail. 2016;18(11):1342-50. PMID: 27813304. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.27813304
4 Aboyans V, McClelland RL, Allison MA, . Lower extremity peripheral artery disease in the absence of traditional risk factors. The Multi-Ethnic Study of Atherosclerosis. Atherosclerosis. 2011;214(1):169-73. PMID: 21067754. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21067754
5 Agarw al S, Cox AJ, Herrington DM, . Coronary calcium score predicts cardiovascular mortality in diabetes: diabetes heart study. Diabetes Care. 2013;36(4):972-7. PMID: 23230101. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.23230101
6 Agarw al S, Morgan T, Herrington DM, . Coronary calcium score and prediction of all-cause mortality in diabetes: the diabetes heart study. Diabetes Care. 2011;34(5):1219-24. PMID: 21398528. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.21398528
7 Agarwal SK, Chambless LE, Ballantyne CM, . Prediction of incident heart failure in general practice: the Atherosclerosis Risk in Communities (ARC) Study. Circ Heart Fail. 2012;5(4):422-9. PMID: 22589298. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22589298
8 Ahmadi N, Hajsadeghi F, Blumenthal RS, . Mortality in individuals without know n coronary artery disease but with discordance between the Framingham risk score and coronary artery calcium. Am J Cardiol. 2011;107(6):799-804. PMID: 21247539. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.21247539
9 Ahmadi-Abhari S, Luben RN, Wareham NJ, . Seventeen year risk of all-cause and cause-specific mortality associated with C-reactive protein, fibrinogen and leukocyte count in men and women: the EPIC-Norfolk study. Eur J Epidemiol. 2013;28(7):541-50, PMID: 23821244. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23821244
10 Al Rifai M, McEvoy JW, Nasir K, . Traditional cardiovascular disease risk factors associated with one-year all-cause mortality among those with coronary artery calcium scores >400. Atherosclerosis. 2015;241(2):495-7, PMID: 26091973. KQ1E1, KQ2E4, KQ3E1, KG4EI, KQ5E1.26091973
11 Alemao E, Cawston H, Bourhis F, . Corrparison of cardiovascular risk algorithms in patients withvs without rheumatoid arthritis and the role of C-reactive protein in predicting cardiovascular outcomes in rheumatoid arthritis. Rheumatology (Oxford). 2017;56(5):777-86. PMID: 28087832. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.28087832
12 Allan GM, Garrison S, McCormack J. Comparison of cardiovascular disease risk calculators. Curr Opin Lipidol. 2014;25(4):254-65. PMID: 24977979. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.24977979
13 Alzamora MT, Fores R, Pera G, . Ankle-brachial index and the incidence of cardiovascular events in the Mediterranean low cardiovascular risk population ARTPER cohort. BMC Cardiovasc Disord. 2013;13:119. PMID: 24341531. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24341531
14 Ambrose MS, Nagy CD, Blumenthal RS. Selective use of coronary calcification measurements in an expanded intermediate risk group. J Cardiovasc Comput Tomogr. 2008;2(4):209-13. PMID: 19083951. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.19083951
15 Ambrosius WT, Polonsky TS, Greenland P, . Design of the value of imaging in enhancing the wellness of your heart (VIEW) trial and the impact of uncertainty on power. Clinical Trials. 2012;9(2):232-46. PMID: 22333998. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22333998
16 Anand DV, Lim E, Hopkins D, . Risk stratification in uncomplicated type 2 diabetes: prospective evaluation of the combined use of coronary artery calcium imaging and selective myocardial perfusion scintigraphy. Eur Heart J. 2006;27(6):713-21. PMID: 16497686. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.16497686
17 Andersson C, Vasan RS. Is there a role for coronary artery calcium scoring for management of asymptomatic patients at risk for coronary artery disease?: Clinical risk scores are sufficient to define primary prevention treatment strategies among asymptomatic patients. Circ Cardiovasc Imaging. 2014;7(2):390-7; discussion 7. PMID: 24642921. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.24642921
18 Andersson J, Johansson L, Ladenvall P, . C-reactive protein is a determinant of first-ever stroke: prospective nested case-referent study. Cerebrovasc Dis. 2009;27(6):544-51. PMID: 19390179. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19390179
19 Ankle Brachial Index Collaboration, Fow kes FG, Murray GD, . Ankle brachial index combined with Framingham Risk Score to predict cardiovascular events and mortality: a meta-analysis. JAMA. 2008;300(2):197-208. PMID: 18612117. KQ1E1, KQ2E11, KQ3E1, KQ4E1, KQ5E1.18612117
20 Anonymous. Corrigendum to: Incremental prognostic utility of coronary CT angiography for asymptomatic patients based upon extent and severity of coronary artery calcium: results from the COronary CT Angiography EvaluatioN For Clinical Outcomes InteRnationalMulticenter (CONFIRM) Study. Eur Heart J. 2015;36(46):3287. PMID: 26063448. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.26063448
21 Arad Y, Goodman KJ, Roth M, . Coronary calcification, coronary disease risk factors, C-reactive protein, and atherosclerotic cardiovascular disease events: the St. Francis Heart Study. J Am Coll Cardiol. 2005;46(1):158-65. PMID: 15992651. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.15992651
22 Arad Y, Spadaro LA, Goodman K, . Predictive value of electron beam computed tomography of the coronary arteries. 19-month follow-up of 1173 asymptomatic subjects. Circulation. 1996;93(11):1951-3. PMID: 8640967. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.8640967
23 Arad Y, Spadaro LA, Goodman K, . Prediction of coronary events with electron beam computed tomography. J Am Coll Cardiol. 2000;36(4):1253-60. PMID: 11028480. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.11028480
24 Arad Y, Spadaro LA, Roth M, . Erratum: Treatment of asymptomatic adults with elevated coronary calcium scores with atorvastatin, vitamin C, and vitamin E: The St. Francis heart study randomized clinical trial (Journal of the American College of Cardiology (2005) 46 (166-172)). J Am Coll Cardiol. 2011;58(17):1832. PMID: None. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.
25 Arcadi T, Maffei E, Sverzellati N, . Coronary artery calcium score on low -dose computed tomography for lung cancer screening. World J Radiol. 2014;6(6):381-7. PMID: 24976939. KQ1E1, KQ2E1, KQ3E4c, KQ4E1, KQ5E124976939
26 Arima H, Kubo M, Yonemoto K, . High-sensitivity C-reactive protein and coronary heart disease in a general population of Japanese: the Hisayama study. Arterioscler Thromb Vasc Biol. 2008;28(7):1385-91. PMID: 18403728. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18403728
27 Baber U, Mehran R, Sartori S, . Prevalence, Impact, and Predictive Value of Detecting Subclinical Coronary and Carotid Atherosclerosis in Asymptomatic Adults: The BioImage Study. J Am Coll Cardiol. 2015;65(11):1065-74. PMID: 25790876. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.25790876
28 Ballantyne CM, Hoogeveen RC, Bang H, . Lipoprotein-associated phospholipase A2, high-sensitivity C-reactive protein, and risk for incident coronary heart disease in middle-aged men and women in the Atherosclerosis Risk in Communities (ARIC) study. Circulation. 2004;109(7):837-42. PMID: 14757686. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.14757686
29 Barac A, Wang H, Shara NM, . Markers of inflammation, metabolic risk factors, and incident heart failure in American Indians: the Strong Heart Study. J Clin Hypertens (Greenwich). 2012;14(1):13-9. PMID: 22235819. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22235819
30 Barac A, Wang H, Shara NM, . C-reactive protein, fibrinogen, and incident heart failure in the Strong Heart Study population. J Clin Hypertens (Greenwich). 2013;15(4):299. PMID: 23551734. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.23551734
31 Becker A, Leber A, Becker C, . Predictive value of coronary calcifications for future cardiac events in asymptomatic individuals. Am Heart J. 2008;155(1):154-60. PMID: 18082507. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.18082507
32 Becker A, Leber AW, Becker C, . Predictive value of coronary calcifications for future cardiac events in asymptomatic patients with diabetes mellitus: a prospective study in 716 patients over 8 years. BMC Cardiovasc Disord. 2008;8:27. PMID: 18847481. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.18847481
33 Beer C, Alfonso H, Flicker L, . Traditional risk factors for incident cardiovascular events have limited importance in later life compared with the health in men study cardiovascular risk score. Stroke. 2011;42(4):952-9. PMID: 21311063. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.21311063
34 Benchimol D, Pillois X, Oysel-Mestre M, . Ankle brachial index using an automatic blood pressure device in occupational medicine: relevance in routine examination and comparison with Framingham cardio-vascular risk score. Int J Clin Pract. 2012;66(9):862-6. PMID: 22897463. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22897463
35 Berry JD, Liu K, Folsom AR, . Prevalence and progression of subclinical atherosclerosis in younger adults with low short-term but high lifetime estimated risk for cardiovascular disease: the coronary artery risk development in young adults study and multi-ethnic study of atherosclerosis. Circulation. 2009;119(3):382-9. PMID: 19139385. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19139385
36 Bischoff B, Kantert C, Meyer T, . Cardiovascular risk assessment based on the quantification of coronary calcium in contrast-enhanced coronary computed tomography angiography. Eur Heart J Cardiovsc Imaging. 2012;13(6):468-75. PMID: 22166591. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22166591
37 Blaha M, Whelton S, Al RM, . Rationale and design of the coronary artery calcium consortium: a multicenter cohort study. J Cardiovasc Comput Tomoqr. 2017;11(1):54-61. PMID: 27884729. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.27884729
38 Blaha MJ, Budoff MJ, DeFilippis AP, . Associations between C-reactive protein, coronary artery calcium, and cardiovascular events: implications for the JUPITER population from MESA, a population-based cohort study. Lancet. 2011;378(9792):684-92. PMID: 21856482. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.21856482
39 Blaha MJ, Cainzos-Achirica M, Greenland P, . Role of Coronary Artery Calcium Score of Zero and Other Negative Risk Markers for Cardiovascular Disease: The Multi-Ethnic Study Of Atherosclerosis (MESA). Circulation. 2016. PMID: 26801055. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26801055
40 Blaha MJ, Nasir K, Budoff MJ, . The impact of baseline c-reactive protein and coronary artery calcium on the benefit observed with atorvastatin: A secondary analysis of the St. Francis heart study. Circulation. 2013;128(22 suppl. 1). PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E11, KQ5E4.
41 Blair KJ, Allison MA, Morgan C, . Comparison of ordinal versus Agatston coronary calcification scoring for cardiovascular disease mortality in community-living individuals. The Int J Cardiovasc Imaging. 2014;30(4):813-8. PMID: 24610090. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24610090
42 Blake GJ, Rifai N, Buring JE, . Blood pressure, C-reactive protein, and risk of future cardiovascular events. Circulation. 2003;108(24):2993-9. PMID: 14638538. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.14638538
43 Blankstein R, Budoff MJ, Shaw LJ, . Predictors of coronary heart disease events among asymptomatic persons with low low-density lipoprotein cholesterol MESA (Multi-Ethnic Study of Atherosclerosis). J Am Coll Cardiol. 2011;58(4):364-74. PMID: 21757113. KQ1E1, KQ2E11, KQ3E1, KQ4E1, KQ5E1.21757113
44 Boekholdt SM, Hack CE, Sandhu MS, . C-reactive protein levels and coronary artery disease incidence and mortality in apparently healthy men and women: the EPIC-Norfolk prospective population study 1993-2003. Atherosclerosis. 2005;187(2):415-22. PMID: 16257408. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.16257408
45 Bos MJ, Schipper CM, Koudstaal PJ, . High serum C-reactive protein level is not an independent predictor for stroke: the Rotterdam Study. Circulation. 2006;114(15):1591-8. PMID: 17015791. KQ1E1, KQ2E4a, KQ3E1, KQ4E1, KQ5E1.17015791
46 Bouchi R, Babazono T, Takagi M, . Non-linear association between ankle-brachial pressure index and prevalence of silent cerebral infarction in Japanese patients with type 2 diabetes. Atherosclerosis. 2012;222(2):490-4. PMID: 22460047. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22460047
47 Brown ER, Kronmal RA, Bluemke DA, . Coronary calcium coverage score: determination, correlates, and predictive accuracy in the Multi-Ethnic Study of Atherosclerosis. Radiology. 2008;247(3):669-75. PMID: 18413889. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.18413889
48 Bruchas RR, de Las Fuentes L, Carney RM, . The St. Louis African American health-heart study: methodology for the study of cardiovascular disease and depression in young-old African Americans. BMC Cardiovasc Disord. 2013;13:66. PMID: 24011389. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24011389
49 Bruno G, Fornengo P, Novelli G, . C-reactive protein and 5-year survival in type 2 diabetes: the Casale Monferrato Study. Diabetes. 2009;58(4):926-33. PMID: 19074985. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.19074985
50 Budoff MJ, Hokanson JE, Nasir K, . Progression of coronary artery calcium predicts all-cause mortality. JACC Cardiovasc Imaging. 2010;3(12):1229-136. PMID: 21163451. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.21163451
51 Budoff MJ, Nasir K, McClelland RL, . Coronary calcium predicts events better with absolute calcium scores than age-sex-race/ethnicity percentiles: MESA (Multi-Ethnic Study of Atherosclerosis).[Erratum appears in J Am Coll Cardiol. 2009 Apr 21;53(16):1474]. J Am Coll Cardiol. 2009;53(4):345-52. PMID: 19161884. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.19161884
52 Cai T, Tian L, Lloyd-Jones D, . Evaluating subject-level incremental values of new markers for risk classification rule. Lifetime Data Anal. 2013;19(4):547-67. PMID: 23807696. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23807696
53 Cainzos-Achirica M, Rampal S, Chang Y, . Brachial-ankle pulse wave velocity is associated with coronary calcium in young and middle-aged asymptomatic adults: The Kangbuk Samsung Health Study. Atherosclerosis. 2015;241(2):350-6. PMID: 26071657. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.26071657
54 Cao JJ, Arnold AM, Manolio TA, . Association of carotid artery intima-media thickness, plaques, and C-reactive protein with future cardiovascular disease and all-cause mortality: the Cardiovascular Health Study. Circulation. 2007;116(1):32-8. PMID: 17576871. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.17576871
55 Cao JJ, Thach C, Manolio TA, . C-reactive protein, carotid intima-media thickness, and incidence of ischemic stroke in the elderly: the Cardiovascular Health Study. Circulation. 2003;108(2):166-70. PMID: 12821545. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.12821545
56 Carr JJ, Jacobs DR, Jr., Terry JG, . Association of Coronary Artery Calcium in Adults Aged 32 to 46 Years With Incident Coronary Heart Disease and Death. JAMA Cardiol. 2017;2(4):391-9. PMID: 28196265. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.28196265
57 Casasnovas JA, Alcaide V, Civeira F, . Aragon workers’ health study--design and cohort description. BMC Cardiovasc Disord. 2012;12:45. PMID: 22712826. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22712826
58 Caslake MJ, Packard CJ, Robertson M, . Lipoprotein-associated phospholipase A(2), inflammatory biomarkers, and risk of cardiovascular disease in the Prospective Study of Pravastatin in the Elderly at Risk (PROSPER). Atherosclerosis. 2010;210(1):28-34. PMID: 20005516. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.20005516
59 Cesari M, Penninx BW, New man AB, . Inflammatory markers and onset of cardiovascular events: results from the Health ABC study. Circulation. 2003;108(19):2317-22. PMID: 14568895. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.14568895
60 Chambless LE, Folsom AR, Sharrett AR, . Coronary heart disease risk prediction in the Atherosclerosis Risk in Communities (ARIC) study. J Clin Epidemiol. 2003;56(9):880-90. PMID: 14505774. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.14505774
61 Chang P, Nead KT, Olin JW, . Effect of physical activity assessment on prognostication for peripheral artery disease and mortality. Mayo Clin Proc. 2015;90(3):339-45. PMID: 25649965. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.25649965
62 Chapman MJ, Giral P, Barter PJ. The conundrum of C-reactive protein as a risk marker for cardiovascular risk assessment: insight from EPIC-Norfolk and JUPITER. Eur Heart J. 2013;34(18):1318-20. PMID: 23482520. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.23482520
63 Chauffe RJ, Winchester DE. Q: Which patients may benefit from coronary artery calcification scoring? Cleve Clin J Med. 2013;80(6):370-3. PMID: 23733903. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.23733903
64 Chei CL, Yamagishi K, Kitamura A, . C-reactive protein levels and risk of stroke and its subtype in Japanese: The Circulatory Risk in Communities Study (CIRCS). Atherosclerosis. 2011;217(1):187-93. PMID: 21444086. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.21444086
65 Chironi G, Simon A, Megnien JL, . Impact of coronary artery calcium on cardiovascular risk categorization and lipid-lowering drug eligibility in asymptomatic hypercholesterolemic men. Int J Cardiol. 2011;151(2):200-4. PMID: 20580446. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20580446
66 Chiu YW, Adler SG, Budoff MJ, . Coronary artery calcification and mortality in diabetic patients with proteinuria. Kidney International. 2010;77(12):1107-14. PMID: 20237457. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20237457
67 Cho DY, Kim KN, Kim KM, . Combination of high-sensitivity C-reactive protein and homocysteine may predict an increased risk of coronary artery disease in Korean population. Chinese Medical Journal. 2012;125(4):569-73. PMID: 22490475. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22490475
68 Cho I, Chang HJ, Sung JM, . Coronary computed tomographic angiography and risk of all-cause mortality and nonfatal myocardial infarction in subjects without chest pain syndrome from the CONFIRM Registry (coronary CT angiography evaluation for clinical outcomes: an international multicenter registry). Circulation. 2012;126(3):304-13. PMID: 22685117. KQ1E1, KQ2E5, KQ3E1, KQ4E1, KQ5E1.22685117
69 Christian AH, Mochari H, Mosca LJ. Waist circumference, body mass index, and their association with cardiometabolic and global risk. Journal of the CardioMetabolic Syndrome. 2009;4(1):12-9. PMID: 19245511. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19245511
70 Chung SL, Yang CC, Chen CC, . Coronary Artery Calcium Score Compared with Cardio-Ankle Vascular Index in the Prediction of Cardiovascular Events in Asymptomatic Patients with Type 2 Diabetes. Journal of Atherosclerosis & Thrombosis. 2015;22(12):1255-65. PMID: 26269147. KQ1E1, KQ2E2, KQ3E1, KQ4E1, KQ5E1.26269147
71 Clarke R, Emberson JR, Breeze E, . Biomarkers of inflammation predict both vascular and non-vascular mortality in older men. European Heart Journal. 2008;29(6):800-9. PMID: 18303034. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18303034
72 Coffman E, Richmond-Bryant J. Multiple biomarker models for improved risk estimation of specific cardiovascular diseases related to metabolic syndrome: a cross-sectional study. Population Health Metrics. 2015;13:7. PMID: 25788869. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25788869
73 Corrado E, Rizzo M, Muratori I, . Older age and markers of inflammation are strong predictors of clinical events in women with asymptomatic carotid lesions. Menopause. 2008;15(2):240-7. PMID: 17917609. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.17917609
74 Cox AJ, Agarw al S, D MH, . C-reactive protein concentration predicts mortality in type 2 diabetes: the Diabetes Heart Study. Diabetic Medicine. 2012;29(6):767-70. PMID: 22211818. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22211818
75 Cox AJ, Hsu FC, Agarw al S, . Prediction of mortality using a multi-bed vascular calcification score in the Diabetes Heart Study. Cardiovascular Diabetology. 2014;13:160. PMID: 25496604. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.25496604
76 Cozlea DL, Farcas DM, Nagy A, . The impact of C reactive protein on global cardiovascular risk on patients with coronary artery disease. Current Health Sciences Journal. 2013;39(4):225-31. PMID: 24778862. KQ1E1, KQ2E2, KQ3E1, KQ4E1, KQ5E1.24778862
77 Criqui MH, Denenberg JO, Ix JH, . Calcium density of coronary artery plaque and risk of incident cardiovascular events. JAMA. 2014;311(3):271-8. PMID: 24247483 KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.24247483
78 Criqui MH, Denenberg JO, McClelland RL, . Abdominal aortic calcium, coronary artery calcium, and cardiovascular morbidity and mortality in the Multi-Ethnic Study of Atherosclerosis.[Erratum appears in Arterioscler Thromb Vasc Biol. 2015 Jan;35(1):e1]. Arteriosclerosis, Thrombosis & Vascular Biology. 2014;34(7):1574-9. PMID: 24812323. KQ1E1, KQ2E11, KQ3E1, KQ4E1, KQ5E1.24812323
79 Criqui MH, McClelland RL, McDermott MM, . The ankle-brachial index and incident cardiovascular events in the MESA (Multi-Ethnic Study of Atherosclerosis). Journal of the American College of Cardiology. 2010;56(18):1506-12. PMID: 20951328. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.20951328
80 Cui R, Yamagishi K, Imano H, . Relationship between the ankle-brachial index and the risk of coronary heart disease and stroke: the circulatory risk in communities study. Journal of Atherosclerosis & Thrombosis. 2014;21(12):1283-9. PMID: 25078068. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25078068
81 Currie CJ, Poole CD, Conw ay P. Evaluation of the association between the first observation and the longitudinal change in C-reactive protein, and all-cause mortality. Heart. 2008;94(4):457-62. PMID: 17761503. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.17761503
82 Cushman M, Arnold AM, Psaty BM, . C-reactive protein and the 10-year incidence of coronary heart disease in older men and women: the cardiovascular health study. Circulation. 2005;112(1):25-31. PMID: 15983251. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.15983251
83 Cushman M, McClure LA, How ard VJ, . Implications of increased C-reactive protein for cardiovascular risk stratification in black and white men and women in the US. Clinical Chemistry. 2009;55(9):1627-36. PMID: 19643839. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19643839
84 Daniels LB, Clopton P, Laughlin GA, . Grow th-differentiation factor-15 is a robust, independent predictor of 11-year mortality risk in community-dwelling older adults: the Rancho Bernardo Study. Circulation. 2011;123(19):2101-10. PMID: 21536998. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.21536998
85 Davies JH, Kenkre J, Williams EM. Current utility of the ankle-brachial index (ABI) in general practice: implications for its use in cardiovascular disease screening. BMC Family Practice. 2014;15:69. PMID: 24742018. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24742018
86 Dayan A, Narin B, Biteker M, . Coronary calcium score, albuminuria and inflammatory markers in type 2 diabetic patients: associations and prognostic implications. Diabetes Research & Clinical Practice. 2012;98(1):98-103. PMID: 22595190. KQ1E1, KQ2E2, KQ3E1, KQ4E1, KQ5E1.22595190
87 de Lemos JA, Ayers CR, Levine BD, . A Multimodality Strategy for Cardiovascular Risk Assessment: Performance in Two Population-Based Cohorts. Circulation. 2017. PMID: 28360032. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.28360032
88 de Ruijter W, Westendorp RG, Assendelft WJ, . Use of Framingham risk score and new biomarkers to predict cardiovascular mortality in older people: population based observational cohort study. BMJ. 2009;338:a3083. PMID: 19131384. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.19131384
89 Dedic A, Ten Kate GJ, Roos CJ, . Prognostic Value of Coronary Computed Tomography Imaging in Patients at High Risk Without Symptoms of Coronary Artery Disease. American Journal of Cardiology. 2016;117(5):768-74. PMID: 26754124. KQ1E1, KQ2E5, KQ3E1, KQ4E1, KQ5E1.26754124
90 DeFilippis AP, Blaha MJ, Ndumele CE, . The association of Framingham and Reynolds risk scores with incidence and progression of coronary artery calcification in MESA (Multi-Ethnic Study of Atherosclerosis). Journal of the American College of Cardiology. 2011;58(20):2076-83. PMID: 22051329. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.22051329
91 deGoma EM, Dunbar RL, Jacoby D, . Differences in absolute risk of cardiovascular events using risk-refinement tests: a systematic analysis of four cardiovascular risk equations. Atherosclerosis. 2013;227(1):172-7. PMID: 23347959. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23347959
92 Degrell P, Sorbets E, Feldman LJ, . Screening for coronary artery disease in asymptomatic individuals: Why and how? Archives of cardiovascular diseases. 2015;108(12):675-82. PMID: 26596251. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.26596251
93 Desai CS, Ning H, Soliman EZ, . Electrocardiographic abnormalities and coronary artery calcium for coronary heart disease prediction and reclassification: the Multi-Ethnic Study of Atherosclerosis (MESA). American Heart Journal. 2014;168(3):391-7. PMID: 25173552. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.25173552
94 Detrano R, Guerci AD, Carr JJ, . Coronary calcium as a predictor of coronary events in four racial or ethnic groups. New England Journal of Medicine. 2008;358(13):1336-45. PMID: 18367736. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.18367736
95 Detrano RC, Wong ND, Doherty TM, . Coronary calcium does not accurately predict near-term future coronary events in high-risk adults. Circulation. 1999;99(20):2633-8. PMID: 10338455. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.10338455
96 Diederichsen AC, Mahabadi AA, Gerke O, . Increased discordance between HeartScore and coronary artery calcification score after introduction of the new ESC prevention guidelines. Atherosclerosis. 2015;239(1):143-9. PMID: 25602856. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25602856
97 Diederichsen AC, Rasmussen LM, Sogaard R, . The Danish Cardiovascular Screening Trial (DANCAVAS): study protocol for a randomized controlled trial. Trials [Electronic Resource]. 2016;16:554. PMID: 26637993. KQ1E4, KQ2E1, KQ3E4, KQ4E1, KQ5E1.26637993
98 Diederichsen AC, Sand NP, Norgaard B, . Discrepancy between coronary artery calcium score and HeartScore in middle-aged Danes: the DanRisk study. European Journal of Preventive Cardiology. 2012;19(3):558-64. PMID: 21525124. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.21525124
99 Dikic M, Tesic M, Markovic Z, . Prognostic value of calcium score and coronary flow velocity reserve in asymptomatic diabetic patients. Cardiovascular Ultrasound. 2015;13:41. PMID: 26340922. KQ1E1, KQ2E2, KQ3E1, KQ4E1, KQ5E1.26340922
100 Dirrichs T, Penzkofer T, Reinartz SD, . Extracoronary Thoracic and Coronary Artery Calcifications on Chest CT for Lung Cancer Screening: Association with Established Cardiovascular Risk Factors - The “CT-Risk” Trial. Academic Radiology. 2015;22(7):880-9. PMID: 25957500. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25957500
101 Dorresteijn JA, Visseren FL, Ridker PM, . Estimating treatment effects for individual patients based on the results of randomised clinical trials. BMJ. 2011;343:d5888. PMID: 21968126. KQ1E1, KQ2E1, KQ3E1, KQ4E11, KQ5E1.21968126
102 Efstathopoulos EP, Pantos I, Thalassinou S, . Patient radiation doses in cardiac computed tomography: comparison of published results with prospective and retrospective acquisition. Radiation Protection Dosimetry. 2012;148(1):83-91. PMID: 21324959. KQ1E1, KQ2E1, KQ3E6, KQ4E1, KQ5E1.21324959
103 Elias-Smale SE, Wieberdink RG, Odink AE, . Burden of atherosclerosis improves the prediction of coronary heart disease but not cerebrovascular events: the Rotterdam Study. European Heart Journal. 2011;32(16):2050-8. PMID: 21606087. KQ1E1, KQ2E11, KQ3E1, KQ4E1, KQ5E1.21606087
104 Elkeles RS, Godsland IF, Feher MD, . Coronary calcium measurement improves prediction of cardiovascular events in asymptomatic patients with type 2 diabetes: the PREDICT study. European Heart Journal. 2008;29(18):2244-51. PMID: 18573867. KQ1E1, KQ2E9, KQ3E4c, KQ4E1, KQ5E1.18573867
105 Elkeles RS, Godsland IF, Rubens MB, . The progress of coronary heart disease in Type 2 diabetes as measured by coronary calcium score from electron beam computed tomography (EBCT): the PREDICT study. Atherosclerosis. 2008;197(2):777-83. PMID: 17920067. KQ1E1, KQ2E4, KQ3E4c, KQ4E1, KQ5E1.17920067
106 Elkind MS, Luna JM, Moon YP, . High-sensitivity C-reactive protein predicts mortality but not stroke: the Northern Manhattan Study. Neurology. 2009;73(16):1300-7. PMID: 19841382. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19841382
107 Ellis CJ, Legget ME, Edwards C, . High calcium scores in patients with a low Framingham risk of cardiovascular (CVS) disease: implications for more accurate CVS risk assessment in New Zealand. New Zealand Medical Journal. 2011;124(1335):13-26. PMID: 21946678. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.21946678
108 Emerging Risk Factors Collaboration, Kaptoge S, Di Angelantonio E, . C-reactive protein concentration and risk of coronary heart disease, stroke, and mortality: an individual participant meta-analysis. Lancet. 2010;375(9709):132-40. PMID: 20031199. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20031199
109 Empana JP, Jouven X, Canoui-Poitrine F, . C-reactive protein, interleukin 6, fibrinogen and risk of sudden death in European middle-aged men: the PRIME study. Arteriosclerosis, Thrombosis & Vascular Biology. 2010;30(10):2047-52. PMID: 20651278. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20651278
110 Erbel R, Mohlenkamp S, Kerkhoff G, . Non-invasive screening for coronary artery disease: calcium scoring. Heart. 2007;93(12):1620-9. PMID: 18003695. KQ1E1, KQ2E1, KQ3E6, KQ4E1, KQ5E1.18003695
111 Erbel R, Mohlenkamp S, Lehmann N, . Sex related cardiovascular risk stratification based on quantification of atherosclerosis and inflammation. Atherosclerosis. 2008;197(2):662-72. PMID: 17386928. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.17386928
112 Everett BM, Glynn RJ, MacFadyen JG, . Rosuvastatin in the prevention of stroke among men and women with elevated levels of C-reactive protein: justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER). Circulation. 2012;121(1):143-50. PMID: 20026779. KQ1E1, KQ2E1, KQ3E1, KQ4E11, KQ5E4.20026779
113 Everett BM, Kurth T, Buring JE, . The relative strength of C-reactive protein and lipid levels as determinants of ischemic stroke compared with coronary heart disease in women. J Am Coll Cardiol. 2003;48(11):2235-42. PMID: 17161253. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.17161253
114 Falk E, Sillesen H, Muntendam P, . The high-risk plaque initiative: primary prevention of atherothrombotic events in the asymptomatic population. Current Atherosclerosis Reports. 2011;13(5):359-66. PMID: 21800090. KQ1E4, KQ2E9, KQ3E1, KQ4E1, KQ5E1.21800090
115 Farkas K, Jarai Z, Kolossvary E, . High prevalence of peripheral arterial disease in hypertensive patients: the Evaluation of Ankle-Brachial Index in Hungarian Hypertensives screening program. Journal of Hypertension. 2012;30(8):1526-32. PMID: 22743684. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22743684
116 Farkouh ME, Bansilal S, Mathew V. CRP has little incremental value over traditional cardiovascular risk factors in risk stratification. Nature Clinical Practice Cardiovascular Medicine. 2007;4(6):290-1. PMID: 17522718. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.17522718
117 Faustino A, Providencia R, Mota P, . Can cardiac computed tomography predict cardiovascular events in asymptomatic type-2 diabetics?: results of a long term follow -up. BMC Cardiovascular Disorders. 2014;14:2. PMID: 24400648. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.24400648
118 Felix-Redondo FJ, Fernandez-Berges D, Grau M, . Prevalence and clinical characteristics of peripheral arterial disease in the study population Hermex. Revista Espanola de Cardiologia. 2012;65(8):726-33. PMID: 22727799. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22727799
119 Feringa H, Blaha M, Blankstein R, . Derivation and validation of a risk model to predict the presence and extent of coronary artery calcification in asymptomatic individuals. Journal of the American College of Cardiology. 2012;59(13 suppl. 1):E1447. PMID: None. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.
120 Ferket BS, van Kempen BJ, Hunink MG, . Predictive value of updating Framingham risk scores with novel risk markers in the U.S. general population. PLoS ONE [Electronic Resource]. 2014;9(2):e88312. PMID: 24558385. KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E1.24558385
121 Fernandez-Friera L, Penalvo JL, Fernandez-Ortiz A, . Prevalence, Vascular Distribution, and Multiterritorial Extent of Subclinical Atherosclerosis in a Middle-Aged Cohort: The PESA (Progression of Early Subclinical Atherosclerosis) Study. Circulation. 2015;131(24):2104-13. PMID: 25882487. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25882487
122 Fernandez-Ortiz A, Jimenez-Borreguero LJ, Penalvo JL, . The Progression and Early detection of Subclinical Atherosclerosis (PESA) study: rationale and design. American Heart Journal. 2013;166(6):990-8. PMID: 24268213. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24268213
123 Folsom AR, Kronmal RA, Detrano RC, . Coronary artery calcification compared with carotid intima-media thickness in the prediction of cardiovascular disease incidence: the Multi-Ethnic Study of Atherosclerosis (MESA).[Erratum appears in Arch Intern Med. 2008 Sep 8;168(16):1782]. Archives of Internal Medicine. 2008;168(12):1333-9. PMID: 18574091. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.18574091
124 Fox ER, Samdarshi TE, Musani SK, . Development and Validation of Risk Prediction Models for Cardiovascular Events in Black Adults: The Jackson Heart Study Cohort. JAMA Cardiol. 2016;1(1):15-25. PMID: 27437649. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.27437649
125 Gaibazzi N, Rigo F, Facchetti R, . Ultrasound carotid intima-media thickness, carotid plaque and cardiac calcium incrementally add to the Framingham Risk Score for the prediction of angiographic coronary artery disease: a multicenter prospective study. International Journal of Cardiology. 2014;177(2):708-10. PMID: 25449491. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.25449491
126 Galper BZ, Wang YC, Einstein AJ. Strategies for Primary Prevention of Coronary Heart Disease Based on Risk Stratification by the ACC/AHA Lipid Guidelines, ATP III Guidelines, Coronary Calcium Scoring, and C-Reactive Protein, and a Global Treat-All Strategy: A Comparative--Effectiveness Modeling Study. PLoS ONE [Electronic Resource]. 2015;10(9):e0138092. PMID: 26422204. KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E1.26422204
127 Gassett AJ, Sheppard L, McClelland RL, . Risk Factors for Long-Term Coronary Artery Calcium Progression in the Multi-Ethnic Study of Atherosclerosis. Journal of the American Heart Association. 2015;4(8):e001726. PMID: 26251281. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.26251281
128 George A, Movahed A. Recognition of noncardiac findings on cardiac computed tomography examination. Reviews in Cardiovascular Medicine. 2010;11(2):84-91. PMID: 20700090. KQ1E1, KQ2E1, KQ3E6, KQ4E1, KQ5E1.20700090
129 Gepner AD, Young R, Delaney JA, . Comparison of Carotid Plaque Score and Coronary Artery Calcium Score for Predicting Cardiovascular Disease Events: The Multi-Ethnic Study of Atherosclerosis. J Am Heart Assoc. 2017;6(2):14. PMID: 28196817. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.28196817
130 Gepner AD, Young R, Delaney JA, . Comparison of coronary artery calcium presence, carotid plaque presence, and carotid intima-media thickness for cardiovascular disease prediction in the Multi-Ethnic Study of Atherosclerosis. Circulation Cardiovascular imaging. 2015;8(1). PMID: 25596139. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.25596139
131 Gerber TC, Kantor B. Refining coronary heart disease event prediction in young and old individuals by coronary artery calcification imaging with computed tomography. Mayo Clinic Proceedings. 2014;89(10):1324-93. PMID: 21676014. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.25236431
195 Khalil Y, Mukete B, Durkin MJ, . A comparison of assessment of coronary calcium vs carotid intima media thickness for determination of vascular age and adjustment of the Framingham Risk Score. Preventive Cardiology. 2010;13(3):117-21. PMID: 20626666. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20626666
196 Khamis R, Hughes A, Caga-Anan M, . High Serum Immunoglobulin G and M Levels Predict Freedom From Adverse Cardiovascular Events in Hypertension: a Nested Case-Control Substudy of the Anglo-Scandinavian Cardiac Outcomes Trial. EBioMedicine. 2017;9:372-80. PMID: 27333022. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.27333022
197 Khoo CM, Tan M, Wu Y, . Central obesity and smoking are key modifiable risk factors for elevated C-reactive protein in Asian individuals who are not eligible for statin therapy. Nutrition & Diabetes. 2011;1:e8. PMID: 23154530. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23154530
198 Kim BJ, Choi SY, Lee SH, . Advanced coronary artery calcification is associated with ischemic stroke. Cerebrovascular Diseases. 2010;30(1):93-100. PMID: 20501993. KQ1E1, KQ2E4a, KQ3E1, KQ4E1, KQ5E1.20501993
199 Kim BJ, Kim BS, Kang JH. Conventional versus image-based cardiovascular risk assessment in Korean adults. Coronary Artery Disease. 2014;25(2):118-24. PMID: 24346493. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24346493
200 Kim J, McEvoy JW, Nasir K, . Critical review of high-sensitivity C-reactive protein and coronary artery calcium for the guidance of statin allocation: head-to-head comparison of the JUPITER and St. Francis Heart Trials. Circulation Cardiovascular Quality & Outcomes. 2014;7(2):315-22. PMID: 24619319. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.24619319
201 Kim KI, Oh SW, Ahn S, . CRP level and HDL cholesterol concentration jointly predict mortality in a Korean population. American Journal of Medicine. 2012;125(8):787-95.e4. PMID: 22840665. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22840665
202 Kim KP, Einstein AJ, Berrington de Gonzalez A. Coronary artery calcification screening: estimated radiation dose and cancer risk. Archives of Internal Medicine. 2009;169(13):1188-94. PMID: 19597067. KQ1E1, KQ2E1, KQ3E6, KQ4E1, KQ5E1.19597067
203 Kleber ME, Siekmeier R, Delgado G, . C-reactive protein and lipoprotein-associated phospholipase A2 in smokers and nonsmokers of the Ludwigshafen Risk and Cardiovascular Health study. Advances in Experimental Medicine & Biology. 2015;832:15-23. PMID: 25300684. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.25300684
204 Knapper JT, Khosa F, Blaha MJ, . Coronary calcium scoring for long-term mortality prediction in patients with and without a family history of coronary disease. Heart. 2016;102(3):204-8. PMID: 26701965. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.26701965
205 Koenig W, Khuseyinova N, Baumert J, . Increased concentrations of C-reactive protein and IL-6 but not IL-18 are independently associated with incident coronary events in middle-aged men and women: results from the MONICA/KORA Augsburg case-cohort study, 1984-2002. Arterioscler Thromb Vasc Biol. 2006;26(12):2745-51. PMID: 17008587. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.17008587
206 Koenig W, Ridker PM. Rosuvastatin for primary prevention in patients with European systematic coronary risk evaluation risk > 5% or Framingham risk >20%: post hoc analyses of the JUPITER trial requested by European health authorities. European Heart Journal. 2011;32(1):75-83. PMID: 20971747. KQ1E1, KQ2E1, KQ3E1, KQ4E11, KQ5E11.20971747
207 Kondos GT, Hoff JA, Sevrukov A, . Electron-beam tomography coronary artery calcium and cardiac events: a 37-month follow -up of 5635 initially asymptomatic low - to intermediate-risk adults. Circulation. 2003;107(20):2571-6. PMID: 12743005. KQ1E1, KQ2E7, KQ3E1, KQ4E1, KQ5E1.12743005
208 Korhonen P, Vesalainen R, Aarnio P, . Assessment of cardiovascular risk in primary health care. Scandinavian Journal of Primary Health Care. 2012;30(2):101-6. PMID: 22643155. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22643155
209 Korhonen PE, Vesalainen RK, Aarnio PT, . The assessment of total cardiovascular risk in hypertensive subjects in primary care. Annals of Medicine. 2010;42(3):187-95. PMID: 20350256. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20350256
210 Kostapanos MS, Elisaf MS. JUPITER and satellites: Clinical implications of the JUPITER study and its secondary analyses. World Journal of Cardiology. 2011;3(7):207-14. PMID: 21860701. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.21860701
211 Krause KJ, Williams DS, White N. Baseline distribution and correlation analysis of hsCRP in an insurance applicant population. Journal of Insurance Medicine (Seattle). 2008;40(2):124-9. PMID: 19119592. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19119592
212 Kunita E, Yamamoto H, Kitagaw a T, . Prognostic value of coronary artery calcium and epicardial adipose tissue assessed by noncontrast cardiac computed tomography. Atherosclerosis. 2014;233(2):447-53. PMID: 24530777. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.24530777
213 Kuoppamaki M, Salminen M, Vahlberg T, . High sensitive C-reactive protein (hsCRP), cardiovascular events and mortality in the aged: a prospective 9-year follow -up study. Archives of Gerontology & Geriatrics. 2015;60(1):112-7. PMID: 25456891. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25456891
214 Kusunose K, Sato M, Yamada H, . Prognostic Implications of Non-Invasive Vascular Function Tests in High-Risk Atherosclerosis Patients. Circ J. 2016;80(4):1034-40. PMID: 26936237. KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.26936237
215 Lakoski SG, Cushman M, Blumenthal RS, . Implications of C-reactive protein or coronary artery calcium score as an adjunct to global risk assessment for primary prevention of CHD. Atherosclerosis. 2007;193(2):401-7. PMID: 16914155. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.16914155
216 Lakoski SG, Cushman M, Siscovick DS, . The relationship between inflammation, obesity and risk for hypertension in the Multi-Ethnic Study of Atherosclerosis (MESA). Journal of Human Hypertension. 2011;25(2):73-9. PMID: 20944659. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20944659
217 LaMonte MJ, FitzGerald SJ, Church TS, . Coronary artery calcium score and coronary heart disease events in a large cohort of asymptomatic men and women. Am J Epidemiol. 2005;162(5):421-9. PMID: 16076829. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.16076829
218 Landman GW, Kleefstra N, Groenier KH, . Inflammation biomarkers and mortality prediction in patients with type 2 diabetes (ZODIAC-27). Atherosclerosis. 2016;250:46-51. PMID: 27179179. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.27179179
219 Lee AJ, Price JF, Russell MJ, . Improved prediction of fatal myocardial infarction using the ankle brachial index in addition to conventional risk factors: the Edinburgh Artery Study. Circulation. 2004;110(19):3075-80. PMID: 15477416. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.15477416
220 Lee CW, Baek SH, Hong TJ, . A multicenter, eight-week treatment, single-step titration, open-label study assessing the percentage of Korean dyslipidemic patients achieving LDL cholesterol target with atorvastatin starting doses of 10 mg, 20 mg and 40 mg. Cardiovascular Drugs & Therapy. 2010;24(2):181-8. PMID: 20383571. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20383571
221 Lee S, Choi EK, Chang HJ, . Subclinical coronary artery disease as detected by coronary computed tomography angiography in an asymptomatic population. Sunhw angi. 2010;40(9):434-41. PMID: 20967144. KQ1E1, KQ2E5, KQ3E1, KQ4E1, KQ5E1.20967144
222 Lee S, Kim IT, Park HB, . High-sensitivity C-reactive protein can predict major adverse cardiovascular events in Korean patients with type 2 diabetes. Journal of Korean Medical Science. 2011;26(10):1322-7. PMID: 22022185. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22022185
223 Leening MJ, Elias-Smale SE, Kavousi M, . Coronary calcification and the risk of heart failure in the elderly: the Rotterdam Study. Jacc: Cardiovascular Imaging. 2012;5(9):874-80. PMID: 22974798. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22974798
224 Leistner DM, Klotsche J, Pieper L, . Prognostic value of NT-pro-BNP and hs-CRP for risk stratification in primary care: results from the population-based DETECT study. Clinical Research in Cardiology. 2013;102(4):259-68. PMID: 23288467. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.23288467
225 Leng S, Hruska CB, McCollough CH. Use of ionizing radiation in screening examinations for coronary artery calcium and cancers of the lung, colon, and breast. Seminars in Roentgenology. 2015;50(2):148-60. PMID: 25770345. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.25770345
226 Leschka S, Kim CH, Baumueller S, . Scan length adjustment of CT coronary angiography using the calcium scoring scan: effect on radiation dose. AJR American Journal of Roentgenology. 2010;194(3):W272-7. PMID: 20173126. KQ1E1, KQ2E1, KQ3E3, KQ4E1, KQ5E1.20173126
227 Lin T, Liu JC, Chang LY, . Association between coronary artery calcification using lowdose MDCT coronary angiography and bone mineral density in middle-aged men and women. Osteoporosis International. 2011;22(2):627-34. PMID: 20552331. KQ1E1, KQ2E2, KQ3E1, KQ4E1, KQ5E1.20552331
228 Lin WH, Zhang H, Zhang YT. Investigation on cardiovascular risk prediction using physiological parameters. Computational & Mathematical Methods in Medicine. 2013;2013:272691. PMID: 24489599. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.24489599
229 Lin YH, Glei D, Weinstein M, . Additive value of interleukin-6 and C-reactive protein in risk prediction for all-cause and cardiovascular mortality among a representative adult cohort in Taiw an. J Formos Med Assoc. 2017. PMID: 28292623. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.28292623
230 Liu JS, Chuang TJ, Chen JH, . Cilostazol attenuates the severity of peripheral arterial occlusive disease in patients with type 2 diabetes: the role of plasma soluble receptor for advanced glycation end-products. Endocrine. 2015;49(3):703-10. PMID: 25666934. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.25666934
231 Lowe G, Woodw ard M, Hillis G, . Circulating inflammatory markers and the risk of vascular complications and mortality in people with type 2 diabetes and cardiovascular disease or risk factors: the ADVANCE study. Diabetes. 2014;63(3):1115-23. PMID: 24222348. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.24222348
232 Lowe GD, Sweetnam PM, Yarnell JW, . C-reactive protein, fibrin D-dimer, and risk of ischemic heart disease: the Caerphilly and Speedwell studies. Arterioscler Thromb Vasc Biol. 2004;24(10):1957-62. PMID: 15308549. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.15308549
233 Lowe GD, Yarnell JW, Rumley A, . C-reactive protein, fibrin D-dimer, and incident ischemic heart disease in the Speedwell study: are inflammation and fibrin turnover linked in pathogenesis? Arterioscler Thromb Vasc Biol. 2001;21(4):603-10. PMID: 11304479. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.11304479
234 Luna JM, Moon YP, Liu KM, . High-sensitivity C-reactive protein and interleukin-6-dominant inflammation and ischemic stroke risk: the northern Manhattan study. Stroke. 2014;45(4):979-87. PMID: 24627113. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24627113
235 Mahabadi AA, Lehmann N, Mohlenkamp S, . Noncoronary Measures Enhance the Predictive Value of Cardiac CT Above Traditional Risk Factors and CAC Score in the General Population. JACC Cardiovasc Imaging. 2016;9(10):1177-85. PMID: 27450878. KQ1E1, KQ2E11, KQ3E1, KQ4E1, KQ5E1.27450878
236 Mahabadi AA, Mohlenkamp S, Lehmann N, . CAC Score Improves Coronary and CV Risk Assessment Above Statin Indication by ESC and AHA/ACC Primary Prevention Guidelines. JACC Cardiovasc Imaging. 2017;10(2):143-53. PMID: 27665163. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.27665163
237 Makita S, Nakamura M, Satoh K, . Serum C-reactive protein levels can be used to predict future ischemic stroke and mortality in Japanese men from the general population. Atherosclerosis. 2009;204(1):234-8. PMID: 18790479. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18790479
238 Mamudu HM, Paul T, Veeranki SP, . Subclinical Atherosclerosis and Relationship With Risk Factors of Coronary Artery Disease in a Rural Population. American Journal of the Medical Sciences. 2015;350(4):257-62. PMID: 26332729. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.26332729
239 Mancini GB, Ryomoto A. Comparison of cardiovascular risk assessment algorithms to determine eligibility for statin therapy: implications for practice in Canada. Canadian Journal of Cardiology. 2014;30(6):661-6. PMID: 24882538. KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E1.24882538
240 Mann DM, Shimbo D, Cushman M, . C-reactive protein level and the incidence of eligibility for statin therapy: the multi-ethnic study of atherosclerosis. Clinical Cardiology. 2013;36(1):15-20. PMID: 22886783. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22886783
241 Marrugat J, D’Agostino R, Sullivan L, . An adaptation of the Framingham coronary heart disease risk function to European Mediterranean areas. J Epidemiol Community Health. 2003;57(8):634-8. PMID: 12883073. KQ1E1, KQ2E11, KQ3E4, KQ4E1, KQ5E1.12883073
242 Marti R, Parramon D, Garcia-Ortiz L, . Improving interMediAte risk management. MARK study. BMC Cardiovasc Disord. 2011;11:61. PMID: 21992621. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.21992621
243 Martin SS, Blaha MJ, Blankstein R, . Dyslipidemia, coronary artery calcium, and incident atherosclerotic cardiovascular disease: implications for statin therapy from the multiethnic study of atherosclerosis. Circulation. 2014;129(1):77-86. PMID: 24141324. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24141324
244 Matsuura N, Urashima M, Fukumoto W, . Radiation dose reduction at coronary artery calcium scoring by using a low tube current technique and hybrid iterative reconstruction. Journal of Computer Assisted Tomography. 2015;39(1):119-24. PMID: 25319604. KQ1E1, KQ2E1, KQ3E3, KQ4E1, KQ5E1.25319604
245 May M, Law lor DA, Brindle P, . Cardiovascular disease risk assessment in older women: can we improve on Framingham? British Women’s Heart and Health prospective cohort study. Heart. 2006;92(10):1396-401. PMID: 16547204. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.16547204
246 McClelland RL, Jorgensen NW, Budoff M, . 10-Year Coronary Heart Disease Risk Prediction Using Coronary Artery Calcium and Traditional Risk Factors: Derivation in the MESA (Multi-Ethnic Study of Atherosclerosis) With Validation in the HNR (Heinz Nixdorf Recall) Study and the DHS (Dallas Heart Study). Journal of the American College of Cardiology. 2015;66(15):1643-53. PMID: 26449133. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.26449133
247 McEvoy JW, Blaha MJ, DeFilippis AP, . Cigarette smoking and cardiovascular events: role of inflammation and subclinical atherosclerosis from the MultiEthnic Study of Atherosclerosis. Arteriosclerosis, Thrombosis & Vascular Biology. 2015;35(3):700-9. PMID: 25573855. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25573855
248 Melander O, New ton-Cheh C, Almgren P, . Novel and conventional biomarkers for prediction of incident cardiovascular events in the community. JAMA. 2009;302(1):49-57. PMID: 19567439. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.19567439
249 Mendall MA, Strachan DP, Butland BK, . C-reactive protein: relation to total mortality, cardiovascular mortality and cardiovascular risk factors in men. Eur Heart J. 2000;21(19):1584-90. PMID: 10988010. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.10988010
250 Mets OM, Vliegenthart R, Gondrie MJ, . Lung cancer screening CT-based prediction of cardiovascular events. Jacc: Cardiovascular Imaging. 2013;6(8):899-907. PMID: 23769488. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.23769488
251 Miedema MD, Duprez DA, Misialek JR, . Use of coronary artery calcium testing to guide aspirin utilization for primary prevention: estimates from the multi-ethnic study of atherosclerosis. Circulation Cardiovascular Quality & Outcomes. 2014;7(3):453-60. PMID: 24803472. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.24803472
252 Min JK, Labounty TM, Gomez MJ, . Incremental prognostic value of coronary computed tomographic angiography over coronary artery calcium score for risk prediction of major adverse cardiac events in asymptomatic diabetic individuals. Atherosclerosis. 2014;232(2):298-304. PMID: 24468142. KQ1E1, KQ2E5, KQ3E1, KQ4E1, KQ5E1.24468142
253 Mineoka Y, Fukui M, Tanaka M, . Relationship between cardio-ankle vascular index (CAVI) and coronary artery calcification (CAC) in patients with type 2 diabetes mellitus. Heart & Vessels. 2012;27(2):160-5. PMID: 21476051. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.21476051
254 Mlynarska A, Mlynarski R, Sosnow ski M. Effect of coronary artery calcium score on the reduction of global cardiovascular risk. Polskie Archiw um Medycyny Wew netrznej. 2014;124(3):88-96. PMID: 24463597. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24463597
255 Mody P, Joshi PH, Khera A, . Beyond Coronary Calcification, Family History, and C-Reactive Protein: Cholesterol Efflux Capacity and Cardiovascular Risk Prediction. J Am Coll Cardiol. 2016;67(21):2480-7. PMID: 27230043. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.27230043
256 Moebus S, Stang A, Mohlenkamp S, . Association of impaired fasting glucose and coronary artery calcification as a marker of subclinical atherosclerosis in a population-based cohort--results of the Heinz Nixdorf Recall Study. Diabetologia. 2009;52(1):81-9. PMID: 18979083. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18979083
257 Mohlenkamp S, Lehmann N, Greenland P, . Coronary artery calcium score improves cardiovascular risk prediction in persons without indication for statin therapy. Atherosclerosis. 2011;215(1):229-36. PMID: 21251655. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.21251655
258 Mols RE, Sand NP, Jensen JM, . Social factors and coping status in asymptomatic middle-aged Danes: association to coronary artery calcification. Scandinavian Journal of Public Health. 2013;41(7):737-43. PMID: 23740863. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23740863
259 Mora S, Glynn RJ, Boekholdt SM, . On-treatment non-high-density lipoprotein cholesterol, apolipoprotein b, triglycerides, and lipid ratios in relation to residual vascular risk after treatment with potent statin therapy: JUPITER (Justification for the Use of Statins in Prevention: An Intervention Trial Evaluating Rosuvastatin). Journal of the American College of Cardiology. 2012;59(17):1521-8. PMID: 22516441. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22516441
260 Mortensen MB, Fuster V, Muntendam P, . A Simple Disease-Guided Approach to Personalize ACC/AHA-Recommended Statin Allocation in Elderly People: The BioImage Study. J Am Coll Cardiol. 2016;68(9):881-91. PMID: 27561760. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.27561760
261 Mostaza JM, Gonzalez-Juanatey JR, Castillo J, . Prevalence of carotid stenosis and silent myocardial ischemia in asymptomatic subjects with a low ankle-brachial index. J Vasc Surg. 2009;49(1):104-8. PMID: 18829225 KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18829225
262 Muhlestein JB, Lappe DL, Lima JA, . Effect of screening for coronary artery disease using CT angiography on mortality and cardiac events in high-risk patients with diabetes: the FACTOR-64 randomized clinical trial. JAMA. 2014;312(21):2234-43. PMID: 25402757. KQ1E5, KQ2E5, KQ3E5, KQ4E5, KQ5E5.25402757
263 Mukamal KJ, Kizer JR, Djousse L, . Prediction and classification of cardiovascular disease risk in older adults with diabetes. Diabetologia. 2013;56(2):275-83. PMID: 23143166. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.23143166
264 Mulders TA, Sivapalaratnam S, Stroes ES, . Asymptomatic individuals with a positive family history for premature coronary artery disease and elevated coronary calcium scores benefit from statin treatment: a post hoc analysis from the St. Francis Heart Study. Jacc: Cardiovascular Imaging. 2012;5(3):252-60. PMID: 22421169. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22421169
265 Munir JA, Wu H, Bauer K, . Impact of coronary calcium on arterial age and coronary heart disease risk estimation using the MESA arterial age calculator. Atherosclerosis. 2010;211(2):467-70. PMID: 20378115. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20378115
266 Muntendam P, McCall C, Sanz J, . The BioImage Study: novel approaches to risk assessment in the primary prevention of atherosclerotic cardiovascular disease--study design and objectives. American Heart Journal. 2010;160(1):49-57.e1. PMID: 20598972. KQ1E4, KQ2E9, KQ3E1, KQ4E1, KQ5E1.20598972
267 Nakanishi R, Li D, Blaha MJ, . All-cause mortality by age and gender based on coronary artery calcium scores. Eur Heart J Cardiovasc Imaging. 2016. PMID: 26705490 KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.26705490
268 Nakanishi R, Li D, Blaha MJ, . The relationship between coronary artery calcium score and the long-term mortality among patients with minimal or absent coronary artery risk factors. International Journal of Cardiology. 2015;185:275-81. PMID: 25818539. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25818539
269 Nakazato R, Dey D, Gutstein A, . Coronary artery calcium scoring using a reduced tube voltage and radiation dose protocol with dual-source computed tomography. Journal of cardiovascular computed tomography. 2009;3(6):394-400. PMID: 20083060. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.20083060
270 Nambi V, Hoogeveen RC, Chambless L, . Lipoprotein-associated phospholipase A2 and high-sensitivity C-reactive protein improve the stratification of ischemic stroke risk in the Atherosclerosis Risk in Communities (ARIC) study. Stroke. 2009;40(2):376-81. PMID: 19095974. KQ1E1, KQ2E4a, KQ3E1, KQ4E1, KQ5E1.19095974
271 Naqvi TZ, Mendoza F, Rafii F, . High prevalence of ultrasound detected carotid atherosclerosis in subjects with low Framingham risk score: potential implications for screening for subclinical atherosclerosis. Journal of the American Society of Echocardiography. 2010;23(8):809-15. PMID: 20554155. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20554155
272 Nasir K, Bittencourt MS, Blaha MJ, . Implications of Coronary Artery Calcium Testing Among Statin Candidates According to American College of Cardiology/American Heart Association Cholesterol Management Guidelines: MESA (Multi-Ethnic Study of Atherosclerosis). Journal of the American College of Cardiology. 2015;66(15):1657-68. PMID: 26449135. KQ1E1, KQ2E10, KQ3E4c, KQ4E1, KQ5E1.26449135
273 Nasir K, Budoff MJ, Wong ND, . Family history of premature coronary heart disease and coronary artery calcification: Multi-Ethnic Study of Atherosclerosis (MESA). Circulation. 2007;116(6):619-26. PMID: 17646582. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.17646582
274 Nasir K, McClelland RL, Blumenthal RS, . Coronary artery calcium in relation to initiation and continuation of cardiovascular preventive medications: The Multi-Ethnic Study of Atherosclerosis (MESA). Circulation Cardiovascular Quality & Outcomes. 2010;3(3):228-35. PMID: 20371760. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.20371760
275 Nasir K, Rubin J, Blaha MJ, . Interplay of coronary artery calcification and traditional risk factors for the prediction of all-cause mortality in asymptomatic individuals. Circulation Cardiovascular imaging. 2012;5(4):467-73. PMID: 22718782. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.22718782
276 Nead KT, Cooke JP, Olin JW, . Alternative ankle-brachial index method identifies additional at-risk individuals. Journal of the American College of Cardiology. 2013;62(6):553-9. PMID: 23707317. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.23707317
277 Nead KT, Zhou MJ, Caceres RD, . Usefulness of the addition of beta-2-microglobulin, cystatin C and C-reactive protein to an established risk factors model to improve mortality risk prediction in patients undergoing coronary angiography. American Journal of Cardiology. 2013;111(6):851-6. PMID: 23290308. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.23290308
278 Nozaki T, Sugiyama S, Koga H, . Significance of a multiple biomarkers strategy including endothelial dysfunction to improve risk stratification for cardiovascular events in patients at high risk for coronary heart disease. Journal of the American College of Cardiology. 2009;54(7):601-8. PMID: 19660689. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.19660689
279 O’Doherty MG, Jorgensen T, Borglykke A, . Repeated measures of body mass index and C-reactive protein in relation to all-cause mortality and cardiovascular disease: results from the consortium on health and ageing network of cohorts in Europe and the United States (CHANCES). European Journal of Epidemiology. 2014;29(12):887-97. PMID: 25421782. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25421782
280 Okw uosa TM, Greenland P, Burke GL, . Prediction of coronary artery calcium progression in individuals with low Framingham Risk Score: the Multi-Ethnic Study of Atherosclerosis. Jacc: Cardiovascular Imaging. 2012;5(2):144-53. PMID: 22340820. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22340820
281 Okw uosa TM, Greenland P, Ning H, . Distribution of coronary artery calcium scores by Framingham 10-year risk strata in the MESA (Multi-Ethnic Study of Atherosclerosis) potential implications for coronary risk assessment. Journal of the American College of Cardiology. 2011;57(18):1838-45. PMID: 21527159. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.21527159
282 Okw uosa TM, Greenland P, Ning H, . Yield of screening for coronary artery calcium in early middle-age adults based on the 10-year Framingham Risk Score: the CARDIA study. Jacc: Cardiovascular Imaging. 2012;5(9):923-30. PMID: 22974805. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22974805
283 Olsen MH, Hansen TW, Christensen MK, . Cardiovascular risk prediction by N-terminal pro brain natriuretic peptide and high sensitivity C-reactive protein is affected by age and sex. Journal of Hypertension. 2008;26(1):26-34. PMID: 18090537 KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18090537
284 Olsen MH, Hansen TW, Christensen MK, . New risk markers may change the HeartScore risk classification significantly in one-fifth of the population. Journal of Human Hypertension. 2009;23(2):105-12. PMID: 18784734. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18784734
285 Olsen MH, Sehestedt T, Lyngbaek S, . Urine albumin/creatinine ratio, high sensitivity C-reactive protein and N-terminal pro brain natriuretic peptide--three new cardiovascular risk markers--do they improve risk prediction and influence treatment? Current Vascular Pharmacology. 2010;8(1):134-9. PMID: 19485906. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19485906
286 Pai JK, Pischon T, Ma J, . Inflammatory markers and the risk of coronary heart disease in men and women. N Engl J Med. 2004;351(25):2599-610. PMID: 15602020. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.15602020
287 Paixao AR, Ayers CR, El Sabbagh A, . Coronary Artery Calcium Improves Risk Classification in Younger Populations. J Am Coll Cardiol Img. 2015;8(11):1285-93. PMID: 26476504. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.26476504
288 Paixao AR, Ayers CR, Rohatgi A, . Cardiovascular lifetime risk predicts incidence of coronary calcification in individuals with low short-term risk: the Dallas Heart Study. Journal of the American Heart Association. 2014;3(6):e001280. PMID: 25424574. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25424574
289 Paixao AR, Berry JD. Beyond Framingham and coronary calcium: predicted lifetime risk identifies unfavorable risk trajectories. Journal of Nuclear Cardiology. 2014;21(1):42-5. PMID: 24357399. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.24357399
290 Paixao AR, Berry JD, Neeland IJ, . Coronary artery calcification and family history of myocardial infarction in the Dallas heart study. Jacc: Cardiovascular Imaging. 2014;7(7):679-86. PMID: 24954461. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24954461
291 Palacio D, Betancourt S, Gladish GW. Screening for coronary heart disease in asymptomatic patients using multidetector computed tomography: calcium scoring and coronary computed tomography angiography. Seminars in Roentgenology. 2015;50(2):111-7. PMID: 25770341. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.25770341
292 Park HE, Chun EJ, Choi SI, . Clinical and imaging parameters to predict cardiovascular outcome in asymptomatic subjects. The International Journal of Cardiovascular Imaging. 2013;29(7):1595-602. PMID: 23653248. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23653248
293 Park R, Detrano R, Xiang M, . Combined use of computed tomography coronary calcium scores and C-reactive protein levels in predicting cardiovascular events in nondiabetic individuals. Circulation. 2002;106(16):2073-7. PMID: 12379576. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.12379576
294 Parrinello CM, Lutsey PL, Ballantyne CM, . Six-year change in high-sensitivity C-reactive protein and risk of diabetes, cardiovascular disease, and mortality. American Heart Journal. 2015;170(2):380-9. PMID: 26299237. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.26299237
295 Patel J, Al Rifai M, Blaha MJ, . Coronary Artery Calcium Improves Risk Assessment in Adults With a Family History of Premature Coronary Heart Disease: Results From Multiethnic Study of Atherosclerosis. Circulation Cardiovascular imaging. 2015;8(6):e003186. PMID: 26047825. KQ1E1, KQ2E11, KQ3E1, KQ4E1, KQ5E1.26047825
296 Patel MJ, de Lemos JA, McGuire DK, . Evaluation of coronary artery calcium screening strategies focused on risk categories: the Dallas Heart Study. American Heart Journal. 2009;157(6):1001-9. PMID: 19464410. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19464410
297 Patterson CC, Blankenberg S, Ben-Shlomo Y, . Which biomarkers are predictive specifically for cardiovascular or for non-cardiovascular mortality in men? Evidence from the Caerphilly Prospective Study (CaPS). International Journal of Cardiology. 2015;201:113-8. PMID: 26298350. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.26298350
298 Patterson CC, Smith AE, Yarnell JW, . The associations of interleukin-6 (IL-6) and dow nstream inflammatory markers with risk of cardiovascular disease: the Caerphilly Study. Atherosclerosis. 2010;209(2):551-7. PMID: 19836021. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19836021
299 Pelletier P, Lapointe A, Laflamme N, . Discordances among different tools used to estimate cardiovascular risk in postmenopausal women. Canadian Journal of Cardiology. 2009;25(12):e413-6. PMID: 19960135. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19960135
300 Pennells L, Kaptoge S, White IR, . Assessing risk prediction models using individual participant data from multiple studies. American Journal of Epidemiology. 2014;179(5):621-32. PMID: 24366051. KQ1E1, KQ2E11, KQ3E1, KQ4E1, KQ5E1.24366051
301 Pessana F, Armentano R, Chironi G, . Subclinical atherosclerosis modeling: Integration of coronary artery calcium score to Framingham equation. Conference Proceedings: Annual International Conference of the IEEE Engineering in Medicine & Biology Society. 2009;2009:5348-51. PMID: 19964672. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19964672
302 Petretta M, Daniele S, Acampa W, . Prognostic value of coronary artery calcium score and coronary CT angiography in patients with intermediate risk of coronary artery disease. The International Journal of Cardiovascular Imaging. 2012;28(6):1547-56. PMID: 21922205. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.21922205
303 Pikula A, Beiser AS, DeCarli C, . Multiple biomarkers and risk of clinical and subclinical vascular brain injury: the Framingham Offspring Study. Circulation. 2012;125(17):2100-7. PMID: 22456473. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22456473
304 Pirro M, Bergeron J, Dagenais GR, . Age and duration of follow-up as modulators of the risk for ischemic heart disease associated with high plasma C-reactive protein levels in men. Arch Intern Med. 2001;161(20):2474-80. PMID: 11700160. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.11700160
305 Pischon T, Hu FB, Rexrode KM, . Inflammation, the metabolic syndrome, and risk of coronary heart disease in women and men. Atherosclerosis. 2008;197(1):392-9. PMID: 17681508 KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.17681508
306 Pischon T, Mohlig M, Hoffmann K, . Comparison of relative and attributable risk of myocardial infarction and stroke according to C-reactive protein and low-density lipoprotein cholesterol levels. European Journal of Epidemiology. 2007;22(7):429-38. PMID: 17557140. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.17557140
307 Pletcher MJ, Sibley CT, Pignone M, . Interpretation of the coronary artery calcium score in combination with conventional cardiovascular risk factors: the Multi-Ethnic Study of Atherosclerosis (MESA). Circulation. 2013;128(10):1076-84. PMID: 23884352. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23884352
308 Preis SR, Hw ang SJ, Fox CS, . Eligibility of individuals with subclinical coronary artery calcium and intermediate coronary heart disease risk for reclassification (from the Framingham Heart Study). Am J Cardiol. 2009;103(12):1710-5. PMID: 19539080. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19539080
309 Pursnani A, Massaro JM, D’Agostino RB, Sr., . Guideline-Based Statin Eligibility, Coronary Artery Calcification, and Cardiovascular Events. JAMA. 2015;314(2):134-41. PMID: 26172893. KQ1E1, KQ2E4, KQ3E4c, KQ4E1, KQ5E1.26172893
310 Rac-Albu M, Iliuta L, Guberna SM, . The role of ankle-brachial index for predicting peripheral arterial disease. Medica. 2014;9(3):295-302. PMID: 25705296. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.25705296
311 Radford NB, DeFina LF, Barlow CE, . Progression of CAC Score and Risk of Incident CVD. JACC Cardiovasc Imaging. 2016;9(12):1420-9. PMID: 27372023. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.27372023
312 Raggi P, Callister TQ, Cooil B, . Identification of patients at increased risk of first unheralded acute myocardial infarction by electron-beam computed tomography. Circulation. 2000;101(8):850-5. PMID: 10694523. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.10694523
313 Raggi P, Cooil B, Callister TQ. Use of electron beam tomography data to develop models for prediction of hard coronary events. Am Heart J. 2001;141(3):375-82. PMID: 11231434. KQ1E1, KQ2E7, KQ3E1, KQ4E1, KQ5E1.11231434
314 Raggi P, Gongora MC, Gopal A, . Coronary artery calcium to predict all-cause mortality in elderly men and women. Journal of the American College of Cardiology. 2008;52(1):17-23. PMID: 18582630. KQ1E1, KQ2E4, KQ3E4c, KQ4E1, KQ5E1.18582630
315 Raggi P, Shaw LJ, Berman DS, . Prognostic value of coronary artery calcium screening in subjects with and without diabetes. J Am Coll Cardiol. 2004;43(9):1663-9. PMID: 15120828. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.15120828
316 Rasmussen T, Kober L, Abdulla J, . Coronary artery calcification detected in lung cancer screening predicts cardiovascular death. Scandinavian Cardiovascular Journal. 2017;49(3):159-67. PMID: 25919145. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25919145
317 Ratchford EV, Carson KA, Jones SR, . Usefulness of coronary and carotid imaging rather than traditional atherosclerotic risk factors to identify firefighters at increased risk for cardiovascular disease. American Journal of Cardiology. 2014;113(9):1499-504. PMID: 24630792. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24630792
318 Resnick HE, Lindsay RS, McDermott MM, . Relationship of high and low ankle brachial index to all-cause and cardiovascular disease mortality: the Strong Heart Study. Circulation. 2004;109(6):733-9. PMID: 14970108. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.14970108
319 Ridker PM, Buring JE, Rifai N, . Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA. 2007;297(6):611-9. PMID: 17299196. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.17299196
320 Ridker PM, Buring JE, Shih J, . Prospective study of C-reactive protein and the risk of future cardiovascular events among apparently healthy women. Circulation. 1998;98(8):731-3. PMID: 9727541. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.9727541
321 Ridker PM, Cook N. Clinical usefulness of very high and very low levels of C-reactive protein across the full range of Framingham Risk Scores. Circulation. 2004;109(16):1955-9. PMID: 15051634. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.15051634
322 Ridker PM, Cushman M, Stampfer MJ, . Inflammation, aspirin, and the risk of cardiovascular disease in apparently healthy men. N Engl J Med. 1997;336(14):973-9. PMID: 9077376. KQ1E1, KQ2E1, KQ3E1, KQ4E5, KQ5E5.9077376
323 Ridker PM, Danielson E, Fonseca F, . Rosuvastatin in the prevention of cardiovascular events among 17,802 men and women with elevated levels of c-reactive protein: The JUPITER trial. Circulation. 2008;118(22):2310, Abstract no: 161. PMID: None. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.
324 Ridker PM, Danielson E, Fonseca FA, . Reduction in C-reactive protein and LDL cholesterol and cardiovascular event rates after initiation of rosuvastatin: a prospective study of the JUPITER trial. Lancet. 2009;373(9670):1175-82. PMID: 19329177. KQ1E1, KQ2E1, KQ3E1, KQ4E4, KQ5E4.19329177
325 Ridker PM, Genest J, Boekholdt SM, . HDL cholesterol and residual risk of first cardiovascular events after treatment with potent statin therapy: an analysis from the JUPITER trial. Lancet. 2010;376(9738):333-9. PMID: 20655105. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.20655105
326 Ridker PM, Hennekens CH, Buring JE, . C-reactive protein and other markers of inflammation in the prediction of cardiovascular disease in women. N Engl J Med. 2000;342(12):836-43. PMID: 10733371. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.10733371
327 Ridker PM, Kastelein JJ, Genest J, . C-reactive protein and cholesterol are equally strong predictors of cardiovascular risk and both are important for quality clinical care. European Heart Journal. 2013;34(17):1258-61. PMID: 23376447. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.23376447
328 Ridker PM, MacFadyen J, Libby P, . Relation of baseline high-sensitivity C-reactive protein level to cardiovascular outcomes with rosuvastatin in the Justification for Use of statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER). American Journal of Cardiology. 2010;106(2):204-9. PMID: 20599004. KQ1E1, KQ2E1, KQ3E1, KQ4E11, KQ5E4.20599004
329 Ridker PM, Macfadyen JG, Nordestgaard BG, . Rosuvastatin for primary prevention among individuals with elevated high-sensitivity c-reactive protein and 5% to 10% and 10% to 20% 10-year risk. Implications of the Justification for Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER) trial for “intermediate risk”. Circulation Cardiovascular Quality & Outcomes. 2010;3(5):447-52. PMID: 20736443. KQ1E1, KQ2E1, KQ3E1, KQ4E11, KQ5E4.20736443
330 Ridker PM, Paynter NP, Rifai N, . C-reactive protein and parental history improve global cardiovascular risk prediction: the Reynolds Risk Score for men. Circulation. 2008;118(22):2243-51, 4p follow ing 51. PMID: 18997194. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.18997194
331 Ridker PM, Rifai N, Cook NR, . Non-HDL cholesterol, apolipoproteins A-I and B100, standard lipid measures, lipid ratios, and CRP as risk factors for cardiovascular disease in women. JAMA. 2005;294(3):326-33. PMID: 16030277. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.16030277
332 Ridker PM, Rifai N, Rose L, . Comparison of C-reactive protein and low-density lipoprotein cholesterol levels in the prediction of first cardiovascular events. N Engl J Med. 2002;347(20):1557-65. PMID: 12432042. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.12432042
333 Rivera JJ, Nasir K, Cox PR, . Association of traditional cardiovascular risk factors with coronary plaque sub-types assessed by 64-slice computed tomography angiography in a large cohort of asymptomatic subjects. Atherosclerosis. 2009;206(2):451-7. PMID: 19524922. KQ1E1, KQ2E5, KQ3E1, KQ4E1, KQ5E1.19524922
334 Rizzo M, Corrado E, Coppola G, . Markers of inflammation are strong predictors of subclinical and clinical atherosclerosis in women with hypertension. Coronary Artery Disease. 2009;20(1):15-20. PMID: 19060627. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19060627
335 Romero-Corral A, Sierra-Johnson J, Lopez-Jimenez F, . Relationships between leptin and C-reactive protein with cardiovascular disease in the adult general population. Nature Clinical Practice Cardiovascular Medicine. 2008;5(7):418-25. PMID: 18431365. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18431365
336 Rosolova H, Nussbaumerova B. Cardiometabolic risk prediction should be superior to cardiovascular risk assessment in primary prevention of cardiovascular diseases. The EPMA Journal. 2011;2(1):15-26. PMID: 23199124. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.23199124
337 Roy RR, Hurst RT, Lester SJ, . Risk Stratification for Cardiovascular Disease in Women in the Primary Care Setting. Journal of the American Society of Echocardiography. 2015;28(10):1232-9. PMID: 26243701. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.26243701
338 Rutter MK, Wahid ST, McComb JM, . Significance of silent ischemia and microalbuminuria in predicting coronary events in asymptomatic patients with type 2 diabetes. J Am Coll Cardiol. 2002;40(1):56-61. PMID: 12103256. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.12103256
339 Santora LJ, Pillutla P, Norris T, . Coronary calcium scanning independently detects coronary artery disease in asymptomatic firefighters: a prospective study. Journal of cardiovascular computed tomography. 2013;7(1):46-50. PMID: 23394820. KQ1E1, KQ2E4, KQ3E4c, KQ4E1, KQ5E1.23394820
340 Santos RD, Rumberger JA, Budoff MJ, . Thoracic aorta calcification detected by electron beam tomography predicts all-cause mortality. Atherosclerosis. 2010;209(1):131-5. PMID: 19782363. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19782363
341 Sattar N, Murray HM, Welsh P, . Are markers of inflammation more strongly associated with risk for fatal than for nonfatal vascular events? PLoS Medicine / Public Library of Science. 2009;6(6):e1000099. PMID: 19554082. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.19554082
342 Schnabel RB, Yin X, Larson MG, . Multiple inflammatory biomarkers in relation to cardiovascular events and mortality in the community. Arteriosclerosis, Thrombosis & Vascular Biology. 2013;33(7):1728-33. PMID: 23640499. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23640499
343 Schneer S, Bachar GN, Atar E, . Evaluation of framingham and systematic coronary risk evaluation scores by coronary computed tomographic angiography in asymptomatic adults. American Journal of Cardiology. 2013;111(5):700-4. PMID: 23273527. KQ1E1, KQ2E5, KQ3E1, KQ4E1, KQ5E1.23273527
344 Schulman-Marcus J, Valenti V, Hartaigh BO, . Prognostic utility of coronary artery calcium scoring in active smokers: a 15-year follow-up study. International Journal of Cardiology. 2014;177(2):581-3. PMID: 25217211. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25217211
345 Scirica BM, Bhatt DL, Braunw ald E, . Prognostic Implications of Biomarker Assessments in Patients With Type 2 Diabetes at High Cardiovascular Risk: A Secondary Analysis of a Randomized Clinical Trial. JAMA Cardiol. 2016;1(9):989-98. PMID: 27681000. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.27681000
346 Sever PS, Poulter NR, Chang CL, . Evaluation of C-reactive protein prior to and on-treatment as a predictor of benefit from atorvastatin: observations from the Anglo-Scandinavian Cardiac Outcomes Trial. European Heart Journal. 2012;33(4):486-94. PMID: 21798891. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.21798891
347 Sever PS, Poulter NR, Chang CL, . Evaluation of C-reactive protein before and on-treatment as a predictor of benefit of atorvastatin: a cohort analysis from the Anglo-Scandinavian Cardiac Outcomes Trial lipid-lowering arm. Journal of the American College of Cardiology. 2013;62(8):717-29. PMID: 23948514. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23948514
348 Sever PSPNRCCLTSA HADWPSN. The Anglo-Scandinavian Cardiac Outcomes Trial (ASCOT): Testing C-Reactive Protein at Baseline and on-Treatment as an Independent Predictor of Cardiovascular Outcomes. Circulation. 2010;122:2219, Abstract no: 21685. PMID: None. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.
349 Shah RV, Spahillari A, Mw asongwe S, . Subclinical Atherosclerosis, Statin Eligibility, and Outcomes in African American Individuals: The Jackson Heart Study. JAMA Cardiol. 2017;2(6):644-52. PMID: 28315622. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.28315622
350 Shao L, Yan AT, Lebovic G, . Prognostic value of visually detected coronary artery calcification on unenhanced non-gated thoracic computed tomography for prediction of non-fatal myocardial infarction and all-cause mortality. J Cardiovasc Comput Tomogr. 2017;11(3):196-202. PMID: 28411031. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.28411031
351 Shaw LJ, Giambrone AE, Blaha MJ, . Long-Term Prognosis After Coronary Artery Calcification Testing in Asymptomatic Patients: A Cohort Study. Annals of Internal Medicine. 2015;163(1):14-21. PMID: 26148276. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.26148276
352 Shaw LJ, Polk DM, Kahute TA, . Prognostic accuracy of B-natriuretic peptide measurements and coronary artery calcium in asymptomatic subjects (from the Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research [EISNER] study). American Journal of Cardiology. 2009;104(9):1245-50. PMID: 19840570. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.19840570
353 Shaw LJ, Raggi P, Schisterman E, . Prognostic value of cardiac risk factors and coronary artery calcium screening for all-cause mortality. Radiology. 2003;228(3):826-33. PMID: 12869688. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.12869688
354 Shemesh J, Henschke CI, Shaham D, . Ordinal scoring of coronary artery calcifications on low-dose CT scans of the chest is predictive of death from cardiovascular disease.[Erratum appears in Radiology. 2011 May;259(2):617]. Radiology. 2010;257(2):541-8. PMID: 20829542. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20829542
355 Shemesh J, Motro M, Morag-Koren N, . Relation of coronary artery calcium to cardiovascular risk in patients with combined diabetes mellitus and systemic hypertension. American Journal of Cardiology. 2012;109(6):844-50. PMID: 22196788. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.22196788
356 Sillesen H, Muntendam P, Adourian A, . Carotid plaque burden as a measure of subclinical atherosclerosis: comparison with other tests for subclinical arterial disease in the High Risk Plaque BioImage study.[Erratum appears in JACC Cardiovasc Imaging. 2013 Jan;6(1):131-2]. Jacc: Cardiovascular Imaging. 2012;5(7):681-9. PMID: 22789936. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22789936
357 Silverman MG, Blaha MJ, Budoff MJ, . Potential implications of coronary artery calcium testing for guiding aspirin use among asymptomatic individuals with diabetes. Diabetes Care. 2012;35(3):624-6. PMID: 22228745. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.22228745
358 Silverman MG, Blaha MJ, Krumholz HM, . Impact of coronary artery calcium on coronary heart disease events in individuals at the extremes of traditional risk factor burden: the Multi-Ethnic Study of Atherosclerosis. Eur Heart J. 2014;35(33):2232-41. PMID: 24366919. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24366919
359 Smith DA. In adults without CVD, the MESA score, including coronary artery calcium, predicted 10-y risk for CHD events. Ann Intern Med. 2016;164(6):JC35. PMID: 26974735. KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E1.26974735
360 Smith JG, New ton-Cheh C, Almgren P, . Assessment of conventional cardiovascular risk factors and multiple biomarkers for the prediction of incident heart failure and atrial fibrillation. Journal of the American College of Cardiology. 2010;56(21):1712-9. PMID: 21070922. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.21070922
361 Sniderman AD, Thanassoulis G, Law ler PR, . Comparison of coronary calcium screening versus broad statin therapy for patients at intermediate cardiovascular risk. American Journal of Cardiology. 2012;110(4):530-3. PMID: 22579082. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.22579082
362 Soedamah-Muthu SS, Livingstone SJ, Charlton-Menys V, . Effect of atorvastatin on C-reactive protein and benefits for cardiovascular disease in patients with type 2 diabetes: analyses from the Collaborative Atorvastatin Diabetes Trial. Diabetologia. 2017;58(7):1494-502. PMID: 25899452. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25899452
363 Soejima H, Ogaw a H, Morimoto T, . Aspirin possibly reduces cerebrovascular events in type 2 diabetic patients with higher C-reactive protein level: subanalysis from the JPAD trial. Journal of Cardiology. 2013;62(3):165-70. PMID: 23778008. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23778008
364 Sondermeijer BM, Boekholdt SM, Rana JS, . Clinical implications of JUPITER in a contemporary European population: the EPIC-Norfolk prospective population study. European Heart Journal. 2013;34(18):1350-7. PMID: 23449857. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.23449857
365 Stein PK, Barzilay JI. Relationship of abnormal heart rate turbulence and elevated CRP to cardiac mortality in low, intermediate, and high-risk older adults. Journal of Cardiovascular Electrophysiology. 2011;22(2):122-7. PMID: 21134026. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.21134026
366 Stolzmann P, Leschka S, Betschart T, . Radiation dose values for various coronary calcium scoring protocols in dual-source CT. The International Journal of Cardiovascular Imaging. 2009;25(4):443-51. PMID: 19082870. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.19082870
367 Stork S, Feelders RA, van den Beld AW, . Prediction of mortality risk in the elderly. Am J Med. 2006;119(6):519-25. PMID: 16750966. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.16750966
368 St-Pierre AC, Cantin B, Bergeron J, . Inflammatory markers and long-term risk of ischemic heart disease in men A 13-year followup of the Quebec Cardiovascular Study. Atherosclerosis. 2005;182(2):315-21. PMID: 16159604. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.16159604
369 Straczek C, Ducimetiere P, Barberger-Gateau P, . Higher level of systemic C-reactive protein is independently predictive of coronary heart disease in older community-dw elling adults: the three-city study. Journal of the American Geriatrics Society. 2010;58(1):129-35. PMID: 20002508. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.20002508
370 Su HM, Voon WC, Lin TH, . Ankle-brachial pressure index measured using an automated oscillometric method as a predictor of the severity of coronary atherosclerosis in patients with coronary artery disease. Kaohsiung J Med Sci. 2004;20(6):268-72. PMID: 15253467 KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2.15253467
371 Sung J, Lim SJ, Choe Y, . Comparison of the coronary calcium score with the estimated coronary risk. Coronary Artery Disease. 2008;19(7):475-9. PMID: 18923243. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.18923243
372 Sung JH, Yeboah J, Lee JE, . Diagnostic Value of Coronary Artery Calcium Score for Cardiovascular Disease in African Americans: The Jackson Heart Study. Br J Med Med Res. 2016;11(2). PMID: 26949662 KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E1.26949662
373 Sung KC, Cho EJ, Lim YH, . HDL-C levels modify the association between C-reactive protein and coronary artery calcium score. Nutrition Metabolism & Cardiovascular Diseases. 2014;24(11):1240-5. PMID: 25096924. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25096924
374 Sung KC, Ryu S, Chang Y, . C-reactive protein and risk of cardiovascular and all-cause mortality in 268 803 East Asians. European Heart Journal. 2014;35(27):1809-16. PMID: 24569028. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.24569028
375 Syvanen K, Korhonen P, Jaatinen P, . High-sensitivity C-reactive protein and ankle brachial index in a finnish cardiovascular risk population. International Journal of Angiology. 2011;20(1):43-48. PMID: 22532770. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22532770
376 Takx RA, Isgum I, Willemink MJ, . Quantification of coronary artery calcium in nongated CT to predict cardiovascular events in male lung cancer screening participants: results of the NELSON study. Journal of cardiovascular computed tomography. 2015;9(1):50-7. PMID: 25533223. KQ1E1, KQ2E9, KQ3E4c, KQ4E1, KQ5E1.25533223
377 Takx RA, Vliegenthart R, Mohamed Hoesein FA, . Pulmonary function and CT biomarkers as risk factors for cardiovascular events in male lung cancer screening participants: the NELSON study. European Radiology. 2015;25(1):65-71. PMID: 25182625. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.25182625
378 Tasci I. Comment on: Hanssen . Associations between the ankle-brachial index and cardiovascular and all-cause mortality are similar in individuals without and with type 2 diabetes: nineteen-year follow-up of a population-based cohort study. Diabetes Care 2012;35:1731-1735. Diabetes Care. 2013;36(2):e25-6. PMID: 23349158. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.22699294
379 Tatsugami F, Higaki T, Fukumoto W, . Radiation dose reduction for coronary artery calcium scoring at 320-detector CT with adaptive iterative dose reduction 3D. The International Journal of Cardiovascular Imaging. 2015;31(5):1045-52. PMID: 25754302. KQ1E1, KQ2E1, KQ3E3, KQ4E1, KQ5E1.25754302
380 Taylor AJ, Bindeman J, Feuerstein I, . Coronary calcium independently predicts incident premature coronary heart disease over measured cardiovascular risk factors: mean three-year outcomes in the Prospective Army Coronary Calcium (PACC) project. J Am Coll Cardiol. 2005;46(5):807-14. PMID: 16139129. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.16139129
381 Taylor AJ, Fiorilli PN, Wu H, . Relation betw een the Framingham Risk Score, coronary calcium, and incident coronary heart disease among low-risk men. American Journal of Cardiology. 2010;106(1):47-50. PMID: 20609646. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20609646
382 Tison GH, Guo M, Blaha MJ, . Multisite extracoronary calcification indicates increased risk of coronary heart disease and all-cause mortality: The Multi-Ethnic Study of Atherosclerosis. Journal of cardiovascular computed tomography. 2015;9(5):406-14. PMID: 26043963. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.26043963
383 Tota-Maharaj R, Blaha MJ, Blankstein R, . Association of coronary artery calcium and coronary heart disease events in young and elderly participants in the multi-ethnic study of atherosclerosis: a secondary analysis of a prospective, population-based cohort. Mayo Clinic Proceedings. 2014;89(10):1350-9. PMID: 25236430. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25236430
384 Tota-Maharaj R, Blaha MJ, McEvoy JW, . Coronary artery calcium for the prediction of mortality in young adults <45 years old and elderly adults >75 years old. European Heart Journal. 2012;33(23):2955-62. PMID: 22843447. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.22843447
385 Tota-Maharaj R, Joshi PH, Budoff MJ, . Usefulness of regional distribution of coronary artery calcium to improve the prediction of all-cause mortality. American Journal of Cardiology. 2015;115(9):1229-34. PMID: 25743208. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25743208
386 Truong Q, Kallianos K, Cannon C. Coronary artery disease. Calcium score of zero: not a gatekeeper to rule out coronary artery disease. Reviews in Cardiovascular Medicine. 2010;11(4):271-3. PMID: 21389919. KQ1E1, KQ2E3, KQ3E1, KQ4E1, KQ5E1.21389919
387 Truong QA, Okada DR, Cannon CP. Cardiac risk - coronary calcium scoring for all? Reviews in Cardiovascular Medicine. 2009;10(2):121-4. PMID: 19593326. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.19593326
388 Tsai AW, Folsom AR, Rosamond WD, . Ankle-brachial index and 7-year ischemic stroke incidence: the ARIC study. Stroke. 2001;32(8):1721-4. PMID: 11486096. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.11486096
389 Tsuruda T, Kato J, Sumi T, . Combined use of brain natriuretic peptide and C-reactive protein for predicting cardiovascular risk in outpatients with type 2 diabetes mellitus. Vascular Health & Risk Management. 2007;3(4):417-23. PMID: 17969372 KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.17969372
390 Tzoulaki I, Murray GD, Lee AJ, . Relative value of inflammatory, hemostatic, and rheological factors for incident myocardial infarction and stroke: the Edinburgh Artery Study. Circulation. 2007;115(16):2119-27. PMID: 17404162. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.17404162
391 Valenti V, B OH, Heo R, . A 15-Year Warranty Period for Asymptomatic Individuals Without Coronary Artery Calcium: A Prospective Follow -Up of 9,715 Individuals. Jacc: Cardiovascular Imaging. 2015;8(8):900-9. PMID: 26189116. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.26189116
392 Valenti V, B OH, Heo R, . Long-term prognosis for individuals with hypertension undergoing coronary artery calcium scoring. International Journal of Cardiology. 2015;187:534-40. PMID: 25863296. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.25863296
393 Valenti V, Hartaigh BO, Cho I, . Absence of Coronary Artery Calcium Identifies Asymptomatic Diabetic Individuals at Low Near-Term But Not Long-Term Risk of Mortality: A 15-Year Follow-Up Study of 9715 Patients. Circulation Cardiovascular imaging. 2016;9(2):e003528. PMID: 26848062. KQ1E1, KQ2E4b, KQ3E1, KQ4E1, KQ5E1.26848062
394 van den Hoogen IJ, de Graaf MA, Roos CJ, . Prognostic value of coronary computed tomography angiography in diabetic patients without chest pain syndrome. Journal of Nuclear Cardiology. 2016;23(1):24-36. PMID: 26156098. KQ1E1, KQ2E5, KQ3E1, KQ4E1, KQ5E1.26156098
395 van der Leeuw J, Beulens JW, van Dieren S, . Novel Biomarkers to Improve the Prediction of Cardiovascular Event Risk in Type 2 Diabetes Mellitus. J Am Heart Assoc. 2016;5(6):31. PMID: 27247335. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.27247335
396 van der Meer IM, Bots ML, Hofman A, . Predictive value of noninvasive measures of atherosclerosis for incident myocardial infarction: the Rotterdam Study. Circulation. 2004;109(9):1089-94. PMID: 14993130. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.14993130
397 van der Meer IM, de Maat MP, Kiliaan AJ, . The value of C-reactive protein in cardiovascular risk prediction: the Rotterdam Study. Arch Intern Med. 2003;163(11):1323-8. PMID: 12796068. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.12796068
398 van Kempen BJ, Ferket BS, Steyerberg EW, . Comparing the cost-effectiveness of four novel risk markers for screening asymptomatic individuals to prevent cardiovascular disease (CVD) in the US population. International Journal of Cardiology. 2016;203:422-31. PMID: 26547049. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.26547049
399 van Wijk DF, Boekholdt SM, Wareham NJ, . C-reactive protein, fatal and nonfatal coronary artery disease, stroke, and peripheral artery disease in the prospective EPIC-Norfolk cohort study. Arteriosclerosis, Thrombosis & Vascular Biology. 2013;33(12):2888-94. PMID: 24072695. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.24072695
400 Velagaleti RS, Gona P, Larson MG, . Multimarker approach for the prediction of heart failure incidence in the community. Circulation. 2010;122(17):1700-6. PMID: 20937976. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.20937976
401 Verma S, Lonn EM, Nanji A, . Effect of angiotensin-converting enzyme inhibition on C-reactive protein levels: the ramipril C-reactive pRotein randomized evaluation (4R) trial results. Canadian Journal of Cardiology. 2009;25(7):e236-40. PMID: 19584979. KQ1E1, KQ2E1, KQ3E1, KQ4E4, KQ5E4.19584979
402 Villines TC, Taylor AJ. Multi-ethnic study of atherosclerosis arterial age versus framingham 10-year or lifetime cardiovascular risk. American Journal of Cardiology. 2012;110(11):1627-30. PMID: 22921999. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.22921999
403 Vliegenthart R, Oudkerk M, Hofman A, . Coronary calcification improves cardiovascular risk prediction in the elderly. Circulation. 2005;112(4):572-7. PMID: 16009800. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.16009800
404 Vogt MT, McKenna M, Wolfson SK, . The relationship between ankle brachial index, other atherosclerotic disease, diabetes, smoking and mortality in older men and women. Atherosclerosis. 1993;101(2):191-202. PMID: 8379964 KQ1E3, KQ2E3, KQ3E3, KQ4E3, KQ5E3.8379964
405 von Bonsdorff MB, Groffen DA, Vidal JS, . Coronary artery calcium and physical performance as determinants of mortality in older age: the AGES-Reykjavik Study. International Journal of Cardiology. 2013;168(3):2094-9. PMID: 23414742. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.23414742
406 Waheed S, Pollack S, Roth M, . Conventional cardiovascular risk modifies clinical outcomes among subjects with elevated coronary artery calcium score with and without statin therapy: Post HOC analysis from the St Francis heart study. Circulation. 2014;130. PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E11, KQ5E4.
407 Waheed S, Pollack S, Roth M, . Collective impact of conventional cardiovascular risk factors and coronary calcium score on clinical outcomes with or without statin therapy: The St Francis Heart Study. Atherosclerosis. 2016;255:193-9. PMID: 27693004. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.27693004
408 Wakugaw a Y, Kiyohara Y, Tanizaki Y, . C-reactive protein and risk of first-ever ischemic and hemorrhagic stroke in a general Japanese population: the Hisayama Study. Stroke. 2006;37(1):27-32. PMID: 16306468. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.16306468
409 Wang TJ, Wollert KC, Larson MG, . Prognostic utility of novel biomarkers of cardiovascular stress: the Framingham Heart Study. Circulation. 2012;126(13):1596-1604. PMID: 22907935. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.22907935
410 Wang Y, Mou Q, Zhao D, . Predictive value of ankle-brachial index and blood glucose on the outcomes of six-year all-cause mortality and cardiovascular mortality in a Chinese population of type 2 diabetes patients. International Angiology. 2012;31(6):586-94. PMID: 23222938. KQ1E1, KQ2E2, KQ3E1, KQ4E1, KQ5E1.23222938
411 Wannamethee SG, Whincup PH, Shaper AG, . Circulating inflammatory and hemostatic biomarkers are associated with risk of myocardial infarction and coronary death, but not angina pectoris, in older men. Journal of Thrombosis & Haemostasis. 2009;7(10):1605-11. PMID: 19682232. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.19682232
412 Ward-Caviness CK, Xu T, Aspelund T, . Improvement of myocardial infarction risk prediction via inflammation-associated metabolite biomarkers. Heart. 2017;103(16):1278-85. PMID: 28255100. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.28255100
413 Wassertheil-Smoller S, McGinn A, Allison M, . Improvement in stroke risk prediction: role of C-reactive protein and lipoprotein-associated phospholipase A2 in the women’s health initiative. International Journal of Stroke. 2014;9(7):902-9. PMID: 23088183. KQ1E1, KQ2E4a, KQ3E1, KQ4E1, KQ5E1.23088183
414 Whelton SP, Silverman MG, McEvoy JW, . Predictors of Long-Term Healthy Arterial Aging: Coronary Artery Calcium Nondevelopment in the MESA Study. Jacc: Cardiovascular Imaging. 2015;8(12):1393-1400. PMID: 26577261. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.26577261
415 Williams M, Shaw LJ, Raggi P, . Prognostic value of number and site of calcified coronary lesions compared with the total score. Jacc: Cardiovascular Imaging. 2008;1(1):61-9. PMID: 19356407. KQ1E1, KQ2E10, KQ3E1, KQ4E1, KQ5E1.19356407
416 Wiraw an IM, Wu R, Abernethy M, . Calcium scores in the risk assessment of an asymptomatic population: implications for airline pilots. Aviation Space & Environmental Medicine. 2014;85(8):812-7. PMID: 25199122. KQ1E1, KQ2E5, KQ3E1, KQ4E1, KQ5E1.25199122
417 Woo J, Leung J. Does measurement of ankle-brachial index contribute to prediction of adverse health outcomes in older Chinese people? Intern Med J. 2013;43(9):1017-23. PMID: 23425424 KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.23425424
418 Woodward M, Welsh P, Rumley A, . Do inflammatory biomarkers add to the discrimination of cardiovascular disease after allowing for social deprivation? Results from a 10-year cohort study in Glasgow, Scotland. European Heart Journal. 2010;31(21):2669-75. PMID: 19363058. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.19363058
419 Woznicka-Leskiew icz L, Posadzy-Malaczynska A, Juszkat R. The impact of ankle brachial index and pulse wave velocity on cardiovascular risk according to SCORE and Framingham scales and sex differences. Journal of Human Hypertension. 2015;29(8):502-10. PMID: 25252689. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.25252689
420 Xanthakis V, Sullivan LM, Vasan RS, . Assessing the incremental predictive performance of novel biomarkers over standard predictors. Statistics in Medicine. 2014;33(15):2577-84. PMID: 24719270. KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E1.24719270
421 Yeboah J, Carr JJ, Terry JG, . Computed tomography-derived cardiovascular risk markers, incident cardiovascular events, and all-cause mortality in nondiabetics: the Multi-Ethnic Study of Atherosclerosis. European Journal of Preventive Cardiology. 2014;21(10):1233-41. PMID: 23689526. KQ1E1, KQ2E11, KQ3E1, KQ4E1, KQ5E1.23689526
422 Yeboah J, Delaney JA, Nance R, . Mediation of cardiovascular risk factor effects through subclinical vascular disease: the Multi-Ethnic Study of Atherosclerosis. Arteriosclerosis, Thrombosis & Vascular Biology. 2014;34(8):1778-83. PMID: 24876350. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24876350
423 Yeboah J, Polonsky TS, Young R, . Utility of Nontraditional Risk Markers in Individuals Ineligible for Statin Therapy According to the 2013 American College of Cardiology/American Heart Association Cholesterol Guidelines. Circulation. 2015;132(10):916-22. PMID: 26224808. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26224808
424 Yokoyama H, Sone H, Honjo J, . Relationship between a low ankle brachial index and all-cause death and cardiovascular events in subjects with and without diabetes. Journal of Atherosclerosis & Thrombosis. 2014;21(6):574-81. PMID: 24492523. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.24492523
425 Yoo DH, Chun EJ, Choi SI, . Significance of noncalcified coronary plaque in asymptomatic subjects with low coronary artery calcium score: assessment with coronary computed tomography angiography. The International Journal of Cardiovascular Imaging. 2011;27 Suppl 1:27-35. PMID: 22113322. KQ1E1, KQ2E4, KQ3E1, KQ4E1, KQ5E1.22113322
426 Zaghloul A, Al-Bukhari TA, Al-Pakistani HA, . Soluble endothelial protein C receptor and high sensitivity C reactive protein levels as markers of endothelial dysfunction in patients with type 1 and type 2 diabetes mellitus: their role in the prediction of vascular complications. Diabetes Research & Clinical Practice. 2014;106(3):597-604. PMID: 25312870. KQ1E1, KQ2E2, KQ3E1, KQ4E1, KQ5E1.25312870
427 Zakai NA, Katz R, Jenny NS, . Inflammation and hemostasis biomarkers and cardiovascular risk in the elderly: the Cardiovascular Health Study. Journal of Thrombosis & Haemostasis. 2007;5(6):1128-35. PMID: 17388967. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.17388967
428 Zethelius B, Berglund L, Sundstrom J, . Use of multiple biomarkers to improve the prediction of death from cardiovascular causes. New England Journal of Medicine. 2008;358(20):2107-16. PMID: 18480203. KQ1E1, KQ2E9, KQ3E1, KQ4E1, KQ5E1.18480203
429 Zhao Q, Du JS, Han DM, . High-sensitive factor I and C-reactive protein based biomarkers for coronary artery disease. International journal of clinical and experimental medicine. 2014;7(12):5158-69. PMID: 25664018. KQ1E1, KQ2E6, KQ3E1, KQ4E1, KQ5E1.25664018