# Appendix C Included Studies

Below is a list of included studies and ancillary publications; organized by Key Question and listed by Cohort^*^:

* Articles may appear under more than one Key Question

## Key Question 1

### Eisner

Rozanski A, Gransar H, Shaw LJ, . Impact of coronary artery calcium scanning on coronary risk factors and downstream testing the EISNER (Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research) prospective randomized trial. J Am Coll Cardiol. 2011;57(15):1622-32. PMID: 21439754. https://doi.org/10.1016/j.jacc.2011.01.019 21439754

## Key Question 2

### ABI Collaboration

Fowkes FG, Murray GD, Butcher I, . Development and validation of an ankle brachial index risk model for the prediction of cardiovascular events. Eur J Prev Cardiol. 2014;21(3):310-20. PMID: 24367001. https://doi.org/10.1177/2047487313516564 24367001

### Aric

Folsom AR, Chambless LE, Ballantyne CM, . An assessment of incremental coronary risk prediction using C-reactive protein and other novel risk markers: the atherosclerosis risk in communities study. Arch Intern Med. 2006;166(13):1368-73. PMID: 16832001. https://doi.org/10.1001/archinte.166.13.1368 16832001
Murphy TP, Dhangana R, Pencina MJ, . Ankle-brachial index and cardiovascular risk prediction: an analysis of 11,594 individuals with 10-year follow-up. Atherosclerosis. 2012;220(1):160-7. PMID: 22099055. https://doi.org/10.1016/j.atherosclerosis.2011.10.037 22099055

### British Regional Heart Study

Wannamethee SG, Welsh P, Lowe GD, . N-terminal pro-brain natriuretic Peptide is a more useful predictor of cardiovascular disease risk than C-reactive protein in older men with and without pre-existing cardiovascular disease. J Am Coll Cardiol. 2011;58(1):56-64. PMID: 21700090. http://dx.doi.org/10.1016/j.jacc.2011.02.041 21700090

### EAS

Price JF, Tzoulaki I, Lee AJ, . Ankle brachial index and intima media thickness predict cardiovascular events similarly and increased prediction when combined. J Clin Epidemiol. 2007;60(10):1067-75. PMID: 17884603. https://doi.org/10.1016/j.jclinepi.2007.01.011 17884603
Shah T, Casas JP, Cooper JA, . Critical appraisal of CRP measurement for the prediction of coronary heart disease events: new data and systematic review of 31 prospective cohorts. Int J Epidemiol. 2009;38(1):217-31. PMID: 18930961. https://doi.org/10.1093/ije/dyn217 18930961

### Eisner

Rana JS, Gransar H, Wong ND, . Comparative value of coronary artery calcium and multiple blood biomarkers for prognostication of cardiovascular events. Am J Cardiol. 2012;109(10):1449-53. PMID: 22425333. http://dx.doi.org/10.1016/j.amjcard.2012.01.358 22425333

### Eisner + Referred Participant Database

Wong ND, Gransar H, Shaw L, . Thoracic aortic calcium versus coronary artery calcium for the prediction of coronary heart disease and cardiovascular disease events. JACC Cardiovasc Imaging. 2009;2(3):319-26. PMID: 19356578. http://dx.doi.org/10.1016/j.jcmg.2008.12.010 19356578

### Epic-Norfolk

Rana JS, Cote M, Despres JP, . Inflammatory biomarkers and the prediction of coronary events among people at intermediate risk: the EPIC-Norfolk prospective population study. Heart. 2009;95(20):1682-7. PMID: 19587389. http://dx.doi.org/10.1136/hrt.2009.170134 19587389

### Erfc Ipd Ma

Emerging Risk Factors Collaboration, Kaptoge S, Di Angelantonio E, . C-reactive protein, fibrinogen, and cardiovascular disease prediction. N Engl J Med. 2012;367(14):1310-20. PMID: 23034020. https://doi.org/10.1056/NEJMoa1107477 23034020

### Framingham + Framingham Offspring

Wilson PW, Nam BH, Pencina M, . C-reactive protein and risk of cardiovascular disease in men and women from the Framingham Heart Study. Arch Intern Med. 2005;165(21):2473-8. PMID: 16314543. https://doi.org/10.1001/archinte.165.21.2473 16314543

### Framingham Offspring

Wilson PW, Pencina M, Jacques P, . C-reactive protein and reclassification of cardiovascular risk in the Framingham Heart Study. Circ Cardiovasc Qual Outcomes. 2008;1(2):92-7. PMID: 20031795. http://dx.doi.org/10.1161/CIRCOUTCOMES.108.831198 20031795
Zhou QM, Zheng Y, Cai T. Subgroup specific incremental value of new markers for risk prediction. Lifetime Data Anal. 2013;19(2):142-69. PMID: 23263882. http://dx.doi.org/10.1007/s10985-012-9235-3 23263882

### Framingham Offspring + 3^rd^ Generation

Hoffmann U, Massaro JM, D’Agostino RB, Sr., . Cardiovascular Event Prediction and Risk Reclassification by Coronary, Aortic, and Valvular Calcification in the Framingham Heart Study. J Am Heart Assoc. 2016;5(2). PMID: 26903006. http://dx.doi.org/10.1161/JAHA.115.003144 26903006

### Health ABC

Rodondi N, Marques-Vidal P, Butler J, . Markers of atherosclerosis and inflammation for prediction of coronary heart disease in older adults. Am J Epidemiol. 2010;171(5):540-9. PMID: 20110287. https://doi.org/10.1093/aje/kwp428 20110287

### HNR

Erbel R, Mohlenkamp S, Moebus S, . Coronary risk stratification, discrimination, and reclassification improvement based on quantification of subclinical coronary atherosclerosis: the Heinz Nixdorf Recall study. J Am Coll Cardiol. 2010;56(17):1397-406. PMID: 20946997. https://doi.org/10.1016/j.jacc.2010.06.030 20946997
Geisel MH, Bauer M, Hennig F, . Comparison of coronary artery calcification, carotid intima-media thickness and ankle-brachial index for predicting 10-year incident cardiovascular events in the general population. Eur Heart J. 2017. PMID: 28379333. http://doi.org/10.1093/eurheartj/ehx120 28379333
Mohlenkamp S, Lehmann N, Moebus S, . Quantification of coronary atherosclerosis and inflammation to predict coronary events and all-cause mortality. J Am Coll Cardiol. 2011;57(13):1455-64. PMID: 21435514. http://dx.doi.org/10.1016/j.jacc.2010.10.043 21435514
Yeboah J, Erbel R, Delaney JC, . Development of a new diabetes risk prediction tool for incident coronary heart disease events: the Multi-Ethnic Study of Atherosclerosis and the Heinz Nixdorf Recall Study. Atherosclerosis. 2014;236(2):411-7. PMID: 25150939. http://dx.doi.org/10.1016/j.atherosclerosis.2014.07.035 25150939

### Houston Methodist DeBakey Heart and Vascular Center

Chang SM, Nabi F, Xu J, . Value of CACS compared with ETT and myocardial perfusion imaging for predicting long-term cardiac outcome in asymptomatic and symptomatic patients at low risk for coronary disease: clinical implications in a multimodality imaging world. JACC Cardiovasc Imaging. 2015;8(2):134-44. PMID: 25677886. http://dx.doi.org/10.1016/j.jcmg.2014.11.008 25677886

### Inter99

Seven E, Husemoen LL, Sehested TS, . Adipocytokines, C-reactive protein, and cardiovascular disease: a population-based prospective study. PLoS ONE. 2015;10(6):e0128987. PMID: 26035431. http://dx.doi.org/10.1371/journal.pone.0128987 26035431

### Mesa

Fudim M, Zalawadiya S, Patel DK, . Data on coronary artery calcium score performance and cardiovascular risk reclassification across gender and ethnicities. Data Brief. 2016;6:578-81. PMID: 26909370. https://dx.doi.org/10.1016/j.dib.2016.01.002 26909370
Malik S, Budoff MJ, Katz R, . Impact of subclinical atherosclerosis on cardiovascular disease events in individuals with metabolic syndrome and diabetes: the multi-ethnic study of atherosclerosis. Diabetes Care. 2011;34(10):2285-90. PMID: 21844289. http://dx.doi.org/10.2337/dc11-0816 21844289
Polak JF, Szklo M, O’Leary DH. Carotid Intima-Media Thickness Score, Positive Coronary Artery Calcium Score, and Incident Coronary Heart Disease: The Multi-Ethnic Study of Atherosclerosis. J Am Heart Assoc. 2017;6(1):21. PMID: 28110311. https://dx.doi.org/10.1161/JAHA.116.004612 28110311
Polonsky TS, McClelland RL, Jorgensen NW, . Coronary artery calcium score and risk classification for coronary heart disease prediction. JAMA. 2010;303(16):1610-6. PMID: 20424251. https://doi.org/10.1001/jama.2010.461 20424251
Yeboah J, Erbel R, Delaney JC, . Development of a new diabetes risk prediction tool for incident coronary heart disease events: the Multi-Ethnic Study of Atherosclerosis and the Heinz Nixdorf Recall Study. Atherosclerosis. 2014;236(2):411-7. PMID: 25150939. http://dx.doi.org/10.1016/j.atherosclerosis.2014.07.035 25150939
Yeboah J, McClelland RL, Polonsky TS, . Comparison of novel risk markers for improvement in cardiovascular risk assessment in intermediate-risk individuals. JAMA. 2012;308(8):788-95. PMID: 22910756. https://doi.org/10.1001/jama.2012.9624 22910756
Yeboah J, Young R, McClelland RL, . Utility of Nontraditional Risk Markers in Atherosclerotic Cardiovascular Disease Risk Assessment. J Am Coll Cardiol. 2016;67(2):139-147. PMID: 26791059. http://dx.doi.org/10.1016/j.jacc.2015.10.058 26791059

### Monica — Augsburg

Koenig W, Lowel H, Baumert J, . C-reactive protein modulates risk prediction based on the Framingham Score: implications for future risk assessment: results from a large cohort study in southern Germany. Circulation. 2004;109(11):1349-53. PMID: 15023871. https://doi.org/10.1161/01.CIR.0000120707.98922.E3 15023871

### Monica — Copenhagen

Lyngbaek S, Marott JL, Sehestedt T, . Cardiovascular risk prediction in the general population with use of suPAR, CRP, and Framingham Risk Score. Int J Cardiol. 2013;167(6):2904-11. PMID: 22909410. http://dx.doi.org/10.1016/j.ijcard.2012.07.018 22909410

### Nijmegen Biomendical Study

Holewijn S, den Heijer M, Kiemeney LA, . Combining risk markers improves cardiovascular risk prediction in women. Clinical Science. 2014;126(2):139-46. PMID: 23879211. http://dx.doi.org/10.1042/CS20130178 23879211

### NPHS II

Shah T, Casas JP, Cooper JA, . Critical appraisal of CRP measurement for the prediction of coronary heart disease events: new data and systematic review of 31 prospective cohorts. Int J Epidemiol. 2009;38(1):217-31. PMID: 18930961. https://doi.org/10.1093/ije/dyn217 18930961

### Prosper

Sattar N, Murray HM, McConnachie A, . C-reactive protein and prediction of coronary heart disease and global vascular events in the Prospective Study of Pravastatin in the Elderly at Risk (PROSPER). Circulation. 2007;115(8):981-9. PMID: 17283264 https://doi.org/10.1161/CIRCULATIONAHA.106.643114 17283264

### Regicor

Velescu A, Clara A, Penafiel J, . Adding low ankle brachial index to classical risk factors improves the prediction of major cardiovascular events. The REGICOR study. Atherosclerosis. 2015;241(2):357-63. PMID: 26071658. http://dx.doi.org/10.1016/j.atherosclerosis.2015.05.017 26071658

### Reykjavik

Danesh J, Wheeler JG, Hirschfield GM, . C-reactive protein and other circulating markers of inflammation in the prediction of coronary heart disease. N Engl J Med. 2004;350(14):1387-97. PMID: 15070788. https://doi.org/10.1056/NEJMoa032804 15070788

### Rotterdam

Bos D, Leening MJ, Kavousi M, . Comparison of Atherosclerotic Calcification in Major Vessel Beds on the Risk of All-Cause and Cause-Specific Mortality: The Rotterdam Study. Circ Cardiovasc Imaging. 2015;8(12). PMID: 26659376. http://dx.doi.org/10.1161/CIRCIMAGING.115.003843 26659376
Elias-Smale SE, Proenca RV, Koller MT, . Coronary calcium score improves classification of coronary heart disease risk in the elderly: the Rotterdam study. J Am Coll Cardiol. 2010;56(17):1407-14. PMID: 20946998. https://doi.org/10.1016/j.jacc.2010.06.029 20946998
Kavousi M, Elias-Smale S, Rutten JH, . Evaluation of newer risk markers for coronary heart disease risk classification: a cohort study. Ann Intern Med. 2012;156(6):438-44. PMID: 22431676. https://doi.org/10.7326/0003-4819-156-6-201203200-00006 22431676

### Scottish Health Survey

Hamer M, Chida Y, Stamatakis E. Utility of C-reactive protein for cardiovascular risk stratification across three age groups in subjects without existing cardiovascular diseases. Am J Cardiol. 2009;104(4):538-42. PMID: 19660608. http://dx.doi.org/10.1016/j.amjcard.2009.04.020 19660608

### Ship

Schneider HJ, Wallaschofski H, Volzke H, . Incremental effects of endocrine and metabolic biomarkers and abdominal obesity on cardiovascular mortality prediction. PLoS ONE. 2012;7(3):e33084. PMID: 22438892. http://dx.doi.org/10.1371/journal.pone.0033084 22438892

### Singapore Chinese Health Study

Salim A, Tai ES, Tan VY, . C-reactive protein and serum creatinine, but not haemoglobin A1c, are independent predictors of coronary heart disease risk in non-diabetic Chinese. Eur J Prev Cardiol. 2016;12:1339-49. PMID: 26780920 https://doi.org/10.1177/2047487315626547 26780920

### South Bay Heart Watch

Greenland P, LaBree L, Azen SP, . Coronary artery calcium score combined with Framingham score for risk prediction in asymptomatic individuals. JAMA. 2004;291(2):210-5. PMID: 14722147. https://doi.org/10.1001/jama.291.2.210 14722147

### WHS

Cook NR, Buring JE, Ridker PM. The effect of including C-reactive protein in cardiovascular risk prediction models for women. Ann Intern Med. 2006;145(1):21-9. PMID: 16818925.16818925

### Woscops

Welsh P, Doolin O, Willeit P, . N-terminal pro-B-type natriuretic peptide and the prediction of primary cardiovascular events: results from 15-year follow-up of WOSCOPS. Eur Heart J. 2013;34(6):443-50. PMID: 22942340. http://dx.doi.org/10.1093/eurheartj/ehs239 22942340

Pooled Analysis of 5 Cohorts of Low Risk Women (the Dallas Heart Study, the Framingham Heart Study (FHS), the Heinz Nixdorf Recall study (HNR), the Multi-Ethnic Study of Atherosclerosis (MESA), and the Rotterdam Study)

Kavousi M, Desai CS, Ayers C, . Prevalence and Prognostic Implications of Coronary Artery Calcification in Low-Risk Women: A Meta-analysis. JAMA. 2016;316(20):2126-34. PMID: 27846641. https://dx.doi.org/10.1001/jama.2016.17020 27846641

## Key Question 3

### Active-duty Army personnel

O’Malley PG, Feuerstein IM, Taylor AJ. Impact of electron beam tomography, with or without case management, on motivation, behavioral change, and cardiovascular risk profile: a randomized controlled trial. JAMA. 2003;289(17):2215-23. PMID: 12734132. https://doi.org/10.1001/jama.289.17.2215 12734132

### Eisner

Rozanski A, Gransar H, Shaw LJ, . Impact of coronary artery calcium scanning on coronary risk factors and downstream testing the EISNER (Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research) prospective randomized trial. J Am Coll Cardiol. 2011;57(15):1622-32. PMID: 21439754. https://doi.org/10.1016/j.jacc.2011.01.019 21439754

### DanRisk

Nielsen AD, Videbech P, Gerke O, . Population screening for coronary artery calcification does not increase mental distress and the use of psychoactive medication. J Thorac Imaging. 2012;27(3):202-6. PMID: 22336666. http://dx.doi.org/10.1097/RTI.0b013e31824752bd 22336666

### Framingham Offspring + 3^rd^ Generation

Hoffmann U, Massaro JM, D’Agostino RB, Sr., . Cardiovascular Event Prediction and Risk Reclassification by Coronary, Aortic, and Valvular Calcification in the Framingham Heart Study. J Am Heart Assoc. 2016;5(2). PMID: 26903006. http://dx.doi.org/10.1161/JAHA.115.003144 26903006

### HealthCore Integrated Research Database

Chi WC, Sylwestrzak G, Barron J, . Does CAC testing alter downstream treatment patterns for cardiovascular disease? Am J Manag Car. 2014;20(8):e330-9. PMID: 25295796.25295796

### Medicare

Shreibati JB, Baker LC, McConnell MV, . Outcomes after coronary artery calcium and other cardiovascular biomarker testing among asymptomatic medicare beneficiaries. Circ Cardiovasc Imaging. 2014;7(4):655-62. PMID: 24777939. http://dx.doi.org/10.1161/CIRCIMAGING.113.001869 24777939

### MESA

Messenger B, Li D, Nasir K, . Coronary calcium scans and radiation exposure in the multi-ethnic study of atherosclerosis. Int J Cardiovasc Imaging. 2016;32(3):525-9. PMID: 26515964. http://dx.doi.org/10.1007/s10554-015-0799-3 26515964

### Rotterdam

Bos D, Leening MJ, Kavousi M, . Comparison of Atherosclerotic Calcification in Major Vessel Beds on the Risk of All-Cause and Cause-Specific Mortality: The Rotterdam Study. Circ Cardiovasc Imaging. 2015;8(12). PMID: 26659376. http://dx.doi.org/10.1161/CIRCIMAGING.115.003843 26659376

## Key Question 4

### AAA

Fowkes FG, Price JF, Stewart MC, . Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303(9):841-8. PMID: 20197530. https://doi.org/10.1001/jama.2010.221 20197530

### Jupiter

Mora S, Glynn RJ, Hsia J, . Statins for the primary prevention of cardiovascular events in women with elevated high-sensitivity C-reactive protein or dyslipidemia: results from the Justification for the Use of Statins in Prevention: An Intervention Trial Evaluating Rosuvastatin (JUPITER) and meta-analysis of women from primary prevention trials. Circulation. 2010;121(9):1069-77. PMID: 20176986. http://dx.doi.org/10.1161/CIRCULATIONAHA.109.906479 20176986
Ridker PM, Danielson E, Fonseca FA, . Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. N Engl J Med. 2008;359(21):2195-207. PMID: 18997196. https://doi.org/10.1056/NEJMoa0807646 18997196

### POPADAD

Belch J, MacCuish A, Campbell I, . The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. PMID: 18927173. https://doi.org/10.1136/bmj.a1840 18927173

### St. Francis Heart Study

Arad Y, Spadaro LA, Roth M, . Treatment of asymptomatic adults with elevated coronary calcium scores with atorvastatin, vitamin C, and vitamin E: the St. Francis Heart Study randomized clinical trial. J Am Coll Cardiol. 2005;46(1):166-72. PMID: 15992652. https://doi.org/10.1016/j.jacc.2005.02.089 15992652

## Key Question 5

### AAA

Fowkes FG, Price JF, Stewart MC, . Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303(9):841-8. PMID: 20197530. https://doi.org/10.1001/jama.2010.221 20197530

### Jupiter

Ridker PM, Danielson E, Fonseca FA, . Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. N Engl J Med. 2008;359(21):2195-207. PMID: 18997196. https://doi.org/10.1056/NEJMoa0807646 18997196

### Popadad

Belch J, MacCuish A, Campbell I, . The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. PMID: 18927173. https://doi.org/10.1136/bmj.a1840 18927173