# Appendix B Detailed Methods

## Literature Search Strategies

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) <1946 to Present>, Ovid MEDLINE(R) Daily Update <May 19, 2017>

Search Strategy:

1. exp Cardiovascular Diseases/ ()
2. (heart or coronar* or cardiac* or cardio* or myocardi* or vascular* or CVD or cerebrovascular or stroke or cerebral or atheroscler*).ti. ()
3. (heart or coronar* or cardiac* or cardio* or myocardi* or vascular* or CVD or cerebrovascular or stroke or cerebral or atheroscler*).ti,ab. ()
4. limit 3 to (“in data review” or in process or “pubmed not medline”) ()
5. 1 or 2 or 4 ()
6. Ankle Brachial Index/ ()
7. Blood Pressure/ ()
8. Ankle/ ()
9. 7 and 8 ()
10. Ankle/bs [Blood Supply] ()
11. Brachial Artery/ph, pp, us [Physiology, Physiopathology, Ultrasonography] ()
12. (brachial adj1 ankle adj4 (ratio* or index* or indices or gradient* or pressur*)).ti,ab. ()
13. (arm adj1 ankle adj4 (ratio* or index* or indices or gradient* or pressur*)).ti,ab. ()
14. ankle index*.ti,ab. ()
15. 6 or 9 or 10 or 11 or 12 or 13 or 14 ()
16. C-Reactive Protein/ ()
17. (c-reactive protein or crp or hscrp).ti. ()
18. (c-reactive protein or crp or hscrp).ti,ab. ()
19. limit 18 to (“in data review” or in process or “pubmed not medline”) ()
20. exp Biomarkers/ ()
21. exp Inflammation/ ()
22. 18 and 20 and 21 ()
23. 16 or 17 or 19 or 22 ()
24. Coronary Vessels/ ()
25. Coronary Artery Disease/ ()
26. Coronary Angiography/ ()
27. Tomography, X-Ray Computed/ ()
28. Four-Dimensional Computed Tomography/ ()
29. Tomography, Spiral Computed/ ()
30. Multidetector Computed Tomography/ ()
31. 24 or 25 or 26 or 27 or 28 or 29 or 30 ()
32. Calcinosis/ ()
33. Vascular Calcification/ ()
34. Calcium/ ()
35. 32 or 33 or 34 ()
36. 31 and 35 ()
37. (coronary adj3 calci*).ti,ab. ()
38. cac.ti,ab. ()
39. calcium scor*.ti,ab. ()
40. coronary computed tomographic angiogra*.ti,ab. ()
41. ccta.ti,ab. ()
42. 36 or 37 or 38 or 39 or 40 or 41 ()
43. 5 and 15 ()
44. limit 43 to yr=“2012 -Current” ()
45. 5 and 23 ()
46. limit 45 to yr=“2007 -Current” ()
47. 5 and 42 ()
48. limit 47 to yr=“2008 -Current” ()
49. 44 or 46 or 48 ()
50. Animal/ not (Human/ and Animal/) ()
51. 49 not 50 ()
52. limit 51 to english language ()

PubMed [Publisher Supplied]

Search | Query
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #18 AND Publisher[sb] AND English[Language]
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #13 OR #15 OR #17
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #11 Filters: Publication date from 2008/01/01 to 2017/12/31
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #11
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #5 Filters: Publication date from 2007/01/01 to 2017/12/31
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #5
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #4 Filters: Publication date from 2012/01/01 to 2017/12/31
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #1 AND #4
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #6 OR #7 OR #8 OR #9 OR #10
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ccta[tiab]
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “coronary computed tomographic angiography”[tiab] OR “coronary computed tomographic angiograph”[tiab] OR “coronary computed tomographic angiographic”[tiab] OR “coronary computed tomographic angiogram”[tiab]
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “calcium score”[tiab] OR “calcium scores”[tiab] OR “calcium scoring”[tiab]
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search cac[tiab]
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search coronary[tiab] AND (calcium*[tiab] OR calcify*[tiab] OR calcifi*[tiab] OR calcinos*[tiab])
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “c-reactive protein”[tiab] OR “c-reactive proteins”[tiab] OR crp[tiab] OR hscrp[tiab]
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #2 OR #3
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ankle[tiab] AND (brachial[tiab] OR arm[tiab])
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “ankle index”[tiab] OR “ankle indexes”[tiab] OR “ankle indices ”[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search heart[ti] OR coronar*[ti] OR cardiac*[ti] OR cardio[ti] OR cardiog*[ti] OR cardiol*[ti] OR cardiom*[ti] OR cardiop*[ti] OR cardiov*[ti] OR myocardi*[ti] OR vascular*[ti] OR CVD[ti] OR cerebrovascular[ti] OR stroke[ti] OR cerebral[ti] OR atheroscler*[ti]

Cochrane Central Register of Controlled Trials : Issue 4 of 12, April 2017

#1 (heart or coronar* or cardiac* or cardio* or myocardi* or vascular* or CVD or cerebrovascular or stroke or cerebral or atheroscler*):ti
#2 ankle:ti,ab,kw near/2 brachial:ti,ab,kw
#3 arm:ti,ab,kw near/2 ankle:ti,ab,kw
#4 “ankle index”:ti,ab,kw or “ankle indexes”:ti,ab,kw or “ankle indices”:ti,ab,kw
#5 #2 or #3 or #4
#6 “c-reactive protein”:ti,ab,kw or “c-reactive proteins”:ti,ab,kw or crp:ti,ab,kw or hscrp:ti,ab,kw
#7 coronary:ti,ab,kw near/3 calci*:ti,ab,kw
#8 cac:ti,ab,kw
#9 “calcium score”:ti,ab,kw or “calcium scores”:ti,ab,kw or “calcium scoring”:ti,ab,kw
#10 “coronary computed tomographic angiography”:ti,ab,kw or “coronary computed tomographic angiograph”:ti,ab,kw or “coronary computed tomographic angiographic”:ti,ab,kw or “coronary computed tomographic angiogram“:ti,ab,kw
#11 ccta:ti,ab,kw
#12 #7 or #8 or #9 or #10 or #11
#13 #1 and #5 Publication Year from 2012 to 2017, in Trials
#14 #1 and (#6) Publication Year from 2007 to 2017, in Trials
#15 #1 and #12 Publication Year from 2008 to 2017, in Trials
#16 #13 or #14 or #15

## NRI and Confidence Interval Calculations

When a study reported a full reclassification table, a cross-tabulation of risk categories between a base model (in this case, a model with traditional risk factors only) and an extended model (which adds a nontraditional risk factor of interest to the base model), we used these data to calculate event and nonevent NRI for the overall population when these separate measures were not reported. Additionally, the full reclassification table was used to calculate a bias-corrected NRI for the intermediate risk group (NRI_int_). Not having individual-level data, we derived confidence intervals using a simple variance formula, a conservative estimation when compared to bootstrapping techniques as shown by Paytner and Cook.^70^

To calculate the overall event and nonevent NRIs, we first defined the upward movement (up) as a change into higher category and downward movement (down) as a change into lower category, per Pencina and colleagues.^69^

Event NRI = P(up|event) - P(down|event)

Non-event NRI = P(down|nonevent) - P(up|nonevent)

Overall NRI = [Event NRI] + [Nonevent NRI]

NRIs can be calculated separately for individual risk strata reported in a study, and calculation of the NRI_int_ is of the most clinical interest given potential treatment uncertainty in this group.

However, unlike the overall NRI for which the null hypothesis of reclassification table is symmetrical and the expected NRI overall is 0, the expected NRI for the intermediate-risk group is not 0 and nonsymmetrical.^70,^ ^71^ Thus, the intermediate-risk group NRI would be biased, overestimating the reclassification movements (potential increase in Type I error) if not corrected.

A bias-corrected NRI_int_ was calculated by subtracting the expected NRI_int_ from the biased NRIINT.^70^ Based on symmetry assumption, we constructed separate expected reclassification tables using the whole observed table for events and nonevents. The expected number in the diagonal cells equaled numbers in the diagonal cells of the observed table. The expected numbers of the off-diagonal cells would be the average of the observed number in row r, column c and in row c, column r.^70^

From the expected table, we calculated the expected NRI_int_ as follows:

Expected NRI_int_ = [P(INT_up| INT _event) - P(INT _down| INT _event)] + [P(INT _down| INT _nonevent) - P(INT _up| INT _nonevent)]

From the observed table, we calculated the biased NRI_int_ the same way as for expected NRI_int_. Thus,

bias-corrected NRI_int_ = biased NRI_int_ - expected NRI_int_

Confidence intervals for the NRIs (above) were constructed using the simple variance estimator based n binary outcome data and derived from Z-statistics formula:^70^

Variance of NRI = [(P(up|event) + P(down|event)) / # events-2] + [(P(down|nonevent) + P(up|nonevent)) / #non-events^2]

95% confidence interval = NRI ± 1.96^∗^ sqrt(variance of NRI)

Appendix B Figure 1 Literature Flow Diagram

^a^ Studies may appear in more than one Key Question

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CRP = C-reactive protein

Appendix B Figure 1 displays the literature search results and article flow for the review. A total of 22,573 articles were identified through database searches and 134 were identified through other sources. 22,707 articles were screened and 483 full-text articles were assessed for eligibility. 54 publications (43 studies) were included for KQs 1-5.

Appendix B Table 1 Search Terms Used in the Abstract and Keywords Fields of EndNote

Search Terms in Abstract or Keyword Fields | Search Terms in Abstract Field Only^†^
Braz^*^ Chin^*^ Egypt^*^ India^*^ Iran^*^ Iraq^*^ Keny^*^ Mexic^*^ Sahara^*^ Turk^*^ Adoles^*^ Autoimmun^*^ Child^*^ Infant^*^ Mice^*^ Neonat^*^ Preg^*^ Primat^*^ Rheum^*^ Sickle^*^ Arthrit^*^ Cancer^*^ Hepati^*^ HIV^*^ Infect^*^ Kidney^*^ Lupus^*^ Pancrea^*^ Renal^*^ Transplant^*^ Cuba^*^ Haiti^*^ Lanka^*^ Libya^*^ Niger^*^ Peru^*^ Russ^*^ South Africa^*^ Ukrain^*^ Wille^*^ | Animal^*^ Bovin^*^ Canin^*^ Felin^*^ Mammal^*^ Mouse^*^ Murine^*^ Pig^*^ Sprag^*^ Sw in^*^

* Asterisk indicates truncation of search term

† Due to limited number of search terms and groups of search terms in EndNote, most animal-related terms only searched for in the abstract field

Appendix B Table 2 Inclusion Criteria

Category | Inclusion Criteria
Condition definition | Atherosclerotic cardiovascular disease (CVD), including coronary heart disease, cerebrovascular disease, and peripheral artery disease
Populations | Adults without known cardiovascular disease; - By sex, race/ethnicity, and diabetes
Risk Factors | High-sensitivity C-reactive protein, coronary artery calcium, ankle-brachial index
Treatments | KQs 4&5: interventions aimed at preventing CVD events (i.e., aspirin, HMG Co-A reductase inhibitors, antihypertension medications, and lifestyle modifications such as diet and/or exercise)
Comparisons | KQs 1–3: existing cardiovascular disease risk assessment models (focus on cardiovascular disease as opposed to coronary heart disease risk assessment) KQs 4&5: no treatment or usual care (as defined by the study)
Outcomes | KQs 1&4: CVD events (e.g., myocardial infarction, cerebrovascular accident) and/or mortality KQ 2: measures of reclassification (e.g., net reclassification index, integrated discrimination improvement), discrimination (e.g., area under the curve, c-statistic), and calibration (e.g., agreement between observed and predicted risks) KQs 3&5: serious adverse events from risk factor assessment or aggressive risk factor modification resulting in unexpected or unwanted medical attention (e.g., major bleeding, development of diabetes), exposure to radiation
Countries | Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Program)
Study designs | KQs 1&4: systematic review of trials, RCT, CCT KQ 2: systematic review of trials, RCT, CCT, well-designed large prospective cohort studies, risk prediction studies KQs 3&5: systematic reviews, RCT, CCT, well-designed large prospective or retrospective cohort studies, well designed case-control studies (only for rare events)
Language | English language only
Study Quality | “Fair” or “Good” quality only

Abbreviations: CCT = controlled clinical trial; CVD = cardiovascular disease; HMG Co-A reductase inhibitors = 3-hydroxy-3-methyl-glutaryl-coenzyme A reductase inhibitors; KQ = key question; RCT = randomized controlled trial

Appendix B Table 3 Quality Assessment Criteria

Study Design | Criteria
Randomized and nonrandomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^51^ | - Valid random assignment? (NA for non-randomized controlled trials); - Was allocation concealed?; - Were eligibility criteria specified?; - Were groups similar at baseline?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was there adequate adherence to the intervention?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there acceptable follow up?; - Was there evidence of selective reporting of outcomes?; - Was there risk of contamination?
Cohort studies, adapted from the New castle-Ottaw a Scale^52^ | - Was the exposed cohort(s) representative of the general population?; - Was the non-exposed cohort selective from the same community as exposed cohort?; - How was “exposure” ascertained?; - Demonstrated that outcome of interest was not present at start of study?; - Were the cohorts comparable on the basis of the design or analysis?; - Were outcome assessors blind?; - Was followup long enough for outcomes to occur?; - Was there adequate of followup of cohorts?
Risk prediction study, adapted from CHARMS^53^ with selected domains pertaining to IPD meta-analyses^54^ (if applicable) | - *Does the IPD-MA a priori define the rationale, methods, and conduct of methods? If no, what don’t they state?; - *How does the IPD-MA identify relevant studies?; - Source of data; - Does study sample adequately represent population of interest (participant eligibility and recruitment)?; - Was there selective inclusion of participants in the model based on data availability?; - If participants are from a treatment RCT, is treatment accounted for?; - Is a definition and method for measurement of the outcome reported?; - Was the same outcome definition (and method for measurement) used in all patients?; - Was the outcome assessed without knowledge of the candidate predictors (i.e., blinded)?; - Time of outcome occurrence (average follow-up) and time horizon predicted; - Is a definition and method for measurement of candidate predictors reported?; - Were predictors assessed blinded for each other?; - How was the predictor of interest (ABI, CAC, CRP) handled in the modelling?; - Number of participants and number of outcomes/events; - Number of outcomes/events in relation to the number of candidate predictors (Events Per Variable); - Number of participants with any missing value (include predictors and outcomes); - How was missing data handled?; - *Does IPD-MA use methods to investigate and account for between study heterogeneity?; - Were both calibration and discrimination measures reported? Were confidence intervals reported?; - Were a priori cut points used for classification measures (e.g., sensitivity, specificity, predictive values, NRI)?; - Was a bias-corrected NRI used? This applies only to studies presenting NRI for a specific risk strata.; - In what way was the population a separate external validation from the FRS or PCE?; - Was the FRS or PCE recalibrated in the population before the NTRF w as added to the model?

* Applicable for IPD meta-analyses only

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CHARMS = Checklist for Critical Appraisal and Data Extraction for Systematic Review of Prediction Modelling Studies; CRP = C-reactive protein; FRS = Framingham Risk Score; IPD MA = individual participant data meta-analyses; NA = not applicable; NRI = net reclassification improvement; PCE = Pooled Cohort Equations; RCT = randomized controlled trial