# Appendix A USPSTF Recommendations

Appendix A Table 1 USPSTF Recommendations With Reference to CVD Risk Assessment

Type | Topic, Year [Grade] Recommendation^*^ | Clinical Considerations Around CVD Risk Assessment
Screening | Abnormal Glucose and Type 2 Diabetes Mellitus in Adults, 2015 [B] The USPSTF recommends screening for abnormal blood glucose as part of cardiovascular risk assessment in adults aged 40 to 70 years who are overweight or obese. Clinicians should offer or refer patients with abnormal blood glucose to intensive behavioral counseling interventions to promote a healthful diet and physical activity. | The target population includes persons who are most likely to have glucose abnormalities that are associated with increased CVD risk and can be expected to benefit from primary prevention of CVD through risk factor modification.
Screening | High Blood Pressure in Adults, 2015 [A] The USPSTF recommends screening for high blood pressure in adults aged 18 years or older. The USPSTF recommends obtaining measurements outside of the clinical setting for diagnostic confirmation before starting treatment. | Recommendation applies to adults without known hypertension. Blood pressure screening interval shorter for those with risk factors for hypertension: age ≥40 years, high-normal blood pressure, overweight or obese, and African American.
Screening | Abdominal Aortic Aneurysm, 2014 [B] Men Ages 65 to 75 Years who Have Ever Smoked: The USPSTF recommends one-time screening for abdominal aortic aneurysm (AAA) with ultrasonography in men ages 65 to 75 years who have ever smoked. [C] Men Ages 65 to 75 Years who Have Never Smoked: The USPSTF recommends that clinicians selectively offer screening for AAA in men ages 65 to 75 years who have never smoked rather than routinely screening all men in this group. [I] Women Ages 65 to 75 Years who Have Ever Smoked: The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for AAA in women ages 65 to 75 years who have ever smoked. [D] Women Who Have Never Smoked: The USPSTF recommends against routine screening for AAA in women who have never smoked. | Recommendation applies to older adults stratified by sex and smoking history. In nonsmokers, clinicians should consider a patient’s risk factors and the potential for harm before screening. Risk factors for increased risk of AAA include: older age, first-degree relative with an AAA, history of other vascular aneurysms, known CVD, hyperlipidemia, obesity, and hypertension.
Screening | Carotid Artery Stenosis, 2014 [D] The USPSTF recommends against screening for asymptomatic carotid artery stenosis in the general adult population. | Recommendation did not review new evidence for assessment of CIMT as a nontraditional risk factor in CVD risk assessment.
Screening | PAD and CVD in Adults: Risk Assessment with ABI, 2013^†^ [I] The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for peripheral artery disease (PAD) and cardiovascular disease (CVD) risk assessment with the ankle–brachial index (ABI) in adults. | Recommendation included ABI to screen for PAD as well as measurement of ABI as a nontraditional risk factor in CVD risk assessment.
Screening | Coronary Heart Disease: Screening with ECG, 2012^†^ [D] Adults at Low Risk: The USPSTF recommends against screening with resting or exercise electrocardiography (ECG) for the prediction of coronary heart disease (CHD) events in asymptomatic adults at low risk for CHD events. [I] Adults at Intermediate or High Risk: The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening with resting or exercise ECG for the prediction of CHD events in asymptomatic adults at intermediate or high risk for CHD events. | Recommendation applies to all adults without known CVD, stratified by risk. Framingham ATP-III model referenced in clinical considerations. High risk defined as 10-year risk >20%, 10-20% as intermediate risk and <10% as low-risk.
Counseling | Healthful Diet and Physical Activity for CVD Prevention in Adults with Cardiovascular Risk Factors, 2014 [B] The USPSTF recommends offering or referring adults who are overweight or obese and have additional cardiovascular disease (CVD) risk factors to intensive behavioral counseling interventions to promote a healthful diet and physical activity for CVD prevention. | Recommendation applies to adults who are overweight or obese and have existing CVD risk factors (hypertension, hyperlipidemia, impaired fasting glucose, or metabolic syndrome), or are considered to be at high risk based on CVD risk assessment.
Counseling | Healthful Diet and Physical Activity for CVD Prevention in Adults, 2017 [C] The USPSTF recommends that primary care professionals individualize the decision to offer or refer adults without obesity who do not have hypertension, dyslipidemia, abnormal blood glucose, or diabetes to behavioral counseling to promote a healthful diet and physical activity. Existing evidence indicates a positive but small benefit of behavioral counseling for the prevention of cardiovascular disease (CVD) in this population. Individuals who are interested and ready to make behavioral changes may be most likely to benefit from behavioral counseling. | Recommendation applies to adults ages 18 years or older who are normal weight or overweight, with a BMI between 18.5 and 30 kg/m^2^. It does not apply to persons who have known CVD risk factors (hypertension, dyslipidemia, abnormal blood glucose, or diabetes) or persons who have obesity or are underweight.
Preventive Medication | Statin Use for the Primary Prevention of Cardiovascular Disease in Adults, 2016 [B] The USPSTF recommends that adults without a history of cardiovascular disease (CVD) (i.e., symptomatic coronary artery disease or ischemic stroke) use a low-to moderate-dose statin for the prevention of CVD events and mortality when all of the following criteria are met: 1) they are aged 40 to 75 years; 2) they have 1 or more CVD risk factors (i.e., dyslipidemia, diabetes, hypertension, or smoking); and 3) they have a calculated 10-year risk of a cardiovascular event of 10% or greater. Identification of dyslipidemia and calculation of 10-year CVD event risk requires universal lipids screening in adults aged 40 to 75 years. [C] Although statin use may be beneficial for the primary prevention of CVD events in some adults with a 10-year CVD event risk of less than 10%, the likelihood of benefit is smaller because of a lower probability of disease and uncertainty in individual risk prediction. Clinicians may choose to offer a low - to moderate-dose statin to certain adults without a history of CVD when all of the following criteria are met: 1) they are aged 40 to 75 years; 2) they have 1 or more CVD risk factors (i.e., dyslipidemia, diabetes, hypertension, or smoking); and 3) they have a calculated 10-year risk of a cardiovascular event of 7.5% to 10%. [I] The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of initiating statin use for the primary prevention of CVD events and mortality in adults 76 years and older without a history of heart attack or stroke. | To determine whether a patient is a candidate for statin therapy, clinicians must first determine the patient’s risk of having a future CVD event. However, clinicians’ ability to accurately identify a patient’s true risk is imperfect, because the best currently available risk estimation tool, which uses the Pooled Cohort Equations from the 2013 American College of Cardiology/American Heart Association (ACC/AHA) guidelines on the assessment of cardiovascular risk, has been shown to overestimate actual risk in multiple external validation cohorts. The reasons for this possible overestimation are still unclear. The Pooled Cohort Equations were derived from prospective cohorts of volunteers from studies conducted in the 1990s and may not be generalizable to a more contemporary and diverse patient population seen in current clinical practice. Furthermore, no statin clinical trials enrolled patients based on a specific risk threshold calculated using a CVD risk prediction tool; rather, patients had 1 or more CVD risk factors other than age and sex as a requirement for trial enrollment. Because the Pooled Cohort Equations lack precision, the risk estimation tool should be used as a starting point to discuss with patients their desire for lifelong statin therapy. The likelihood that a patient will benefit from statin use depends on his or her absolute baseline risk of having a future CVD event, a risk estimation that is imprecise based on the currently available risk estimation tool. Thus, clinicians should discuss with patients the potential risk of having a CVD event and the expected benefits and harms of statin use. Patients who place a higher value on the potential benefits than on the potential harms and inconvenience of taking a daily medication may choose to initiate statin use for reduction of CVD risk. The USPSTF has made several other recommendations relevant to the prevention of CVD in adults (see the “Other Approaches to Prevention” section).
Preventive Medication | Aspirin for the Prevention of CVD and Colorectal Cancer, 2016 [B] The USPSTF recommends initiating low-dose aspirin use for the primary prevention of cardiovascular disease (CVD) and colorectal cancer (CRC) in adults aged 50 to 59 years who have a 10% or greater 10-year CVD risk, are not at increased risk for bleeding, have a life expectancy of at least 10 years, and are willing to take low-dose aspirin daily for at least 10 years. [C] The decision to initiate low-dose aspirin use for the primary prevention of CVD and CRC in adults aged 60 to 69 years who have a 10% or greater 10-year CVD risk should be an individual one. Persons who are not at increased risk for bleeding, have a life expectancy of at least 10 years, and are willing to take low - dose aspirin daily for at least 10 years are more likely to benefit. Persons who place a higher value on the potential benefits than the potential harms may choose to initiate low-dose aspirin. [I] The current evidence is insufficient to assess the balance of benefits and harms of initiating aspirin use for the primary prevention of CVD and CRC in adults younger than 50 years. [I] The current evidence is insufficient to assess the balance of benefits and harms of initiating aspirin use for the primary prevention of CVD and CRC in adults aged 70 years or older. | The primary risk factors for CVD include older age, male sex, race/ethnicity, abnormal lipid levels, high blood pressure, diabetes, and smoking. The USPSTF used a calculator derived from the American College of Cardiology/American Heart Association (ACC/AHA) pooled cohort equations to predict 10-year risk for first hard atherosclerotic CVD event (defined as nonfatal myocardial infarction [MI], coronary heart disease [CHD] death, and fatal or nonfatal stroke). Although concerns have been raised about the equations’ potential to overpredict risk and their moderate discrimination, they are the only U.S.-based, externally validated equations that report risk as a combination of cerebrovascular and CHD events.

* The following CVD-related recommendations do not explicitly involve CVD risk assessment: Vitamin Supplementation to Prevent Cancer and CVD (2014); Obesity in Adults: Screening and Management (2012)^†^; Tobacco Use in Adults and Pregnant Women: Counseling and Interventions (2015)

† Update in progress

Abbreviations: AAA = abdominal aortic aneurysm; ABI = ankle-brachial index; ACC = American College of Cardiology; AHA = American Heart Association; ATP III = Adult Treatment Panel III; BMI = body mass index; CAC = coronary artery calcium; CHD = coronary heart disease; CRC = colorectal cancer; CVD = cardiovascular disease; DM = diabetes mellitus; kg/m = kilogram per meter; PAD = peripheral artery disease; USPSTF = United States Preventive Services Task Force