# References

1 Hiatt WR, Goldstone J, Smith SC, Jr., . Atherosclerotic Peripheral Vascular Disease Symposium II: nomenclature for vascular diseases. Circulation. 2008;118(25):2826-9. PMID: 19106403. 10.1161/CIRCULATIONAHA.108.191171 19106403
2 Hirsch AT, Haskal ZJ, Hertzer NR, . ACC/AHA 2005 Practice Guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic): a collaborative report from the American Association for Vascular Surgery/Society for Vascular Surgery, Society for Cardiovascular Angiography and Interventions, Society for Vascular Medicine and Biology, Society of Interventional Radiology, and the ACC/AHA Task Force on Practice Guidelines (Writing Committee to Develop Guidelines for the Management of Patients With Peripheral Arterial Disease): endorsed by the American Association of Cardiovascular and Pulmonary Rehabilitation; National Heart, Lung, and Blood Institute; Society for Vascular Nursing; TransAtlantic Inter-Society Consensus; and Vascular Disease Foundation. Circulation. 2006;113(11):e463-654. PMID: 16549646. 10.1161/CIRCULATIONAHA.106.174526 16549646
3 LeFevre ML, U. S. Preventive Services Task Force. Screening for asymptomatic carotid artery stenosis: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(5):356-62. PMID: 25003392. 10.7326/M14-1333 25003392
4 LeFevre ML, U. S. Preventive Services Task Force. Screening for abdominal aortic aneurysm: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(4):281-90. PMID: 24957320. 10.7326/M14-1204 24957320
5 Hiatt WR. Medical treatment of peripheral arterial disease and claudication. N Eng J Med. 2001;344(21):1608-21. PMID: 11372014. 10.1056/NEJM200105243442108 11372014
6 Pande RL, Perlstein TS, Beckman JA, . Secondary prevention and mortality in peripheral artery disease: National Health and Nutrition Examination Study, 1999 to 2004. Circulation. 2011;124(1):17-23. PMID: 21690489. 10.1161/CIRCULATIONAHA.110.003954 21690489
7 Centers for Disease Control and Prevention. Lower extremity disease among persons aged > or =40 years with and without diabetes--United States, 1999-2002. MMWR Morb Mortal Wkly Rep. 2005;54(45):1158-60. PMID: 16292250.16292250
8 Razzouk L, Rockman CB, Patel MR, . Co-existence of vascular disease in different arterial beds: Peripheral artery disease and carotid artery stenosis--Data from Life Line Screening(). Atherosclerosis. 2015;241(2):687-91. PMID: 26122189. 10.1016/j.atherosclerosis.2015.06.029 26122189
9 Menke A, Muntner P, Wildman RP, . Relation of borderline peripheral arterial disease to cardiovascular disease risk. Am J Cardiol. 2006;98(9):1226-30. PMID: 17056334. 10.1016/j.amjcard.2006.05.056 17056334
10 Hirsch AT, Criqui MH, Treat-Jacobson D, . Peripheral arterial disease detection, awareness, and treatment in primary care. JAMA. 2001;286(11):1317-24. PMID: 11560536. 10.1001/jama.286.11.1317 11560536
11 Cimminiello C, Kownator S, Wautrecht JC, . The PANDORA study: peripheral arterial disease in patients with non-high cardiovascular risk. Intern Emerg Med. 2011;6(6):509-19. PMID: 21298363. 10.1007/s11739-011-0511-0 21298363
12 Hiatt WR, Hoag S, Hamman RF. Effect of diagnostic criteria on the prevalence of peripheral arterial disease. The San Luis Valley Diabetes Study. Circulation. 1995;91(5):1472-9. PMID: 7867189. 10.1161/01.CIR.91.5.1472 7867189
13 Aboyans V, Criqui MH, McClelland RL, . Intrinsic contribution of gender and ethnicity to normal ankle-brachial index values: the Multi-Ethnic Study of Atherosclerosis (MESA). Journal of Vascular Surgery. 2007;45(2):319-27. PMID: 17264011. 10.1016/j.jvs.2006.10.032 17264011
14 Hiramoto JS, Katz R, Ix JH, . Sex differences in the prevalence and clinical outcomes of subclinical peripheral artery disease in the Health, Aging, and Body Composition (Health ABC) study. Vascular. 2014;22(2):142-8. PMID: 23512905. 10.1177/1708538113476023 23512905
15 Fowkes FG, Rudan D, Rudan I, . Comparison of global estimates of prevalence and risk factors for peripheral artery disease in 2000 and 2010: a systematic review and analysis. Lancet. 2013;382(9901):1329-40. PMID: 23915883. 10.1016/S01406736(13)61249-0 23915883
16 Ostchega Y, Paulose-Ram R, Dillon CF, . Prevalence of peripheral arterial disease and risk factors in persons aged 60 and older: data from the National Health and Nutrition Examination Survey 1999-2004. J Am Geriatr Soc. 2007;55(4):583-9. PMID: 17397438. 10.1111/j.1532-5415.2007.01123.x 17397438
17 Selvin E, Erlinger TP. Prevalence of and risk factors for peripheral arterial disease in the United States: results from the National Health and Nutrition Examination Survey, 19992000. Circulation. 2004;110(6):738-43. PMID: 15262830. 10.1161/01.CIR.0000137913.26087.F0 15262830
18 Allison MA, Ho E, Denenberg JO, . Ethnic-specific prevalence of peripheral arterial disease in the United States. Am J Prev Med. 2007;32(4):328-33. PMID: 17383564. 10.1016/j.amepre.2006.12.010 17383564
19 Eraso LH, Fukaya E, Mohler ER, III, . Peripheral arterial disease, prevalence and cumulative risk factor profile analysis. Eur J Prev Cardiol. 2012;21(6):704-11. PMID: 22739687. 10.1177/2047487312452968 22739687
20 O'Hare AM, Katz R, Shlipak MG, . Mortality and cardiovascular risk across the anklearm index spectrum: results from the Cardiovascular Health Study. Circulation. 2006;113(3):388-93. PMID: 16432070. 10.1161/CIRCULATIONAHA.105.570903 16432070
21 Wattanakit K, Folsom AR, Duprez DA, . Clinical significance of a high ankle-brachial index: insights from the Atherosclerosis Risk in Communities (ARIC) Study. Atherosclerosis. 2007;190(2):459-64. PMID: 16574125. 10.1016/j.atherosclerosis.2006.02.039 16574125
22 Allison MA, Hiatt WR, Hirsch AT, . A high ankle-brachial index is associated with increased cardiovascular disease morbidity and lower quality of life. Journal of the American College of Cardiology. 2008;51(13):1292-8. PMID: 18371562. 10.1016/j.jacc.2007.11.064 18371562
23 Signorelli SS, Fiore V, Catanzaro S, . Prevalence of high ankle-brachial index (ABI) in general population of Southern Italy, risk factor profiles and systemic cardiovascular co-morbidity: an epidemiological study. Arch Gerontol Geriatr. 2011;53(1):55-9. PMID: 20591512. 10.1016/j.archger.2010.05.020 20591512
24 Grondal N, Sogaard R, Lindholt JS. Baseline prevalence of abdominal aortic aneurysm, peripheral arterial disease and hypertension in men aged 65-74 years from a population screening study (VIVA trial). Br J Surg. 2015;102(8):902-6. PMID: 25923784. 10.1002/bjs.9825 25923784
25 Kvist T, Lindholt J, Rasmussen L, . The DanCavas Pilot Study of Multifaceted Screening for Subclinical Cardiovascular Disease in Men and Women Aged 65-74 Years. Eur J Vasc Endovasc Surg. 2017;53(1):123-31. PMID: 27890524. 10.1016/j.ejvs.2016.10.010 27890524
26 Fowkes FG, Aboyans V, Fowkes FJ, . Peripheral artery disease: epidemiology and global perspectives. Nat Rev Cardiol. 2017;14(3):156-70. PMID: 27853158. 10.1038/nrcardio.2016.179 27853158
27 Marrett E, DiBonaventura M, Zhang Q. Burden of peripheral arterial disease in Europe and the United States: a patient survey. Health Qual Life Outcomes. 2013;11:175. PMID: 24148832. 10.1186/1477-7525-11-175 24148832
28 Jones WS, Patel MR, Dai D, . Temporal trends and geographic variation of lowerextremity amputation in patients with peripheral artery disease: results from U.S. Medicare 2000-2008. J Am Coll Cardiol. 2012;60(21):2230-6. PMID: 23103040. 10.1016/j.jacc.2012.08.983 23103040
29 Jones WS, Patel MR, Dai D, . High mortality risks after major lower extremity amputation in Medicare patients with peripheral artery disease. Am Heart J. 2013;165(5):809-15, 15 e1. PMID: 23622919. 10.1016/j.ahj.2012.12.002 23622919
30 Dynamed. Peripheral arterial disease (PAD) of lower extremities. EbscoHOST; 2015. Available from: http://web.a.ebscohost.com/dynamed/detail?vid=3&sid=52046c47-c49b4781-9e74841cf55b9743%40sessionmgr4001&hid=4212&bdata=JnNpdGU9ZHluYW1lZC1saXZlJnNjb3BlPXNpdGU%3d.
31 Criqui MH, Aboyans V. Epidemiology of peripheral artery disease. Circ Res. 2015;116(9):1509-26. PMID: 25908725. 10.1161/CIRCRESAHA.116.303849 25908725
32 Rooke TW, Hirsch AT, Misra S, . 2011 ACCF/AHA Focused Update of the Guideline for the Management of Patients With Peripheral Artery Disease (updating the 2005 guideline): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2011;58(19):2020-45. PMID: 21963765. 10.1016/j.jacc.2011.08.023 21963765
33 McDermott MM. Lower extremity manifestations of peripheral artery disease: the pathophysiologic and functional implications of leg ischemia. Circ Res. 2015;116(9):1540-50. PMID: 25908727. 10.1161/CIRCRESAHA.114.303517 25908727
34 Sigvant B, Lundin F, Wahlberg E. The Risk of Disease Progression in Peripheral Arterial Disease is Higher than Expected: A Meta-Analysis of Mortality and Disease Progression in Peripheral Arterial Disease. Eur J Vasc Endovasc Surg. 2016;51(3):395-403. PMID: 26777541. 10.1016/j.ejvs.2015.10.022 26777541
35 McDermott MM, Liu K, Greenland P, . Functional decline in peripheral arterial disease: associations with the ankle brachial index and leg symptoms. JAMA. 2004;292(4):453-61. PMID: 15280343. 10.1001/jama.292.4.453 15280343
36 Bendermacher BL, Teijink JA, Willigendael EM, . A clinical prediction model for the presence of peripheral arterial disease--the benefit of screening individuals before initiation of measurement of the ankle-brachial index: an observational study. Vasc Med. 2007;12(1):5-11. PMID: 17451087.17451087
37 Ramos R, Baena-Diez JM, Quesada M, . Derivation and validation of REASON: a risk score identifying candidates to screen for peripheral arterial disease using ankle brachial index. Atherosclerosis. 2011;214(2):474-9. PMID: 21167488. 10.1016/j.atherosclerosis.2010.11.015 21167488
38 Fowkes FG, Murray GD, Butcher I, . Ankle brachial index combined with Framingham Risk Score to predict cardiovascular events and mortality: a meta-analysis. JAMA. 2008;300(2):197-208. PMID: 18612117. 10.1001/jama.300.2.197 18612117
39 Leng GC, Lee AJ, Fowkes FG, . Incidence, natural history and cardiovascular events in symptomatic and asymptomatic peripheral arterial disease in the general population. Int J Epidemiol. 1996;25(6):1172-81. PMID: 9027521.9027521
40 Diehm C, Allenberg JR, Pittrow D, . Mortality and vascular morbidity in older adults with asymptomatic versus symptomatic peripheral artery disease. Circulation. 2009;120(21):2053-61. PMID: 19901192. 10.1161/CIRCULATIONAHA.109.865600 19901192
41 Hooi JD, Kester AD, Stoffers HE, . Asymptomatic peripheral arterial occlusive disease predicted cardiovascular morbidity and mortality in a 7-year follow-up study. J Clin Epidemiol. 2004;57(3):294-300. PMID: 15066690. 10.1016/j.jclinepi.2003.09.003 15066690
42 Criqui MH, Langer RD, Fronek A, . Mortality over a period of 10 years in patients with peripheral arterial disease. N Engl J Med. 1992;326(6):381-6. PMID: 1729621. 10.1056/NEJM199202063260605 1729621
43 Hirsch AT, Hartman L, Town RJ, . National health care costs of peripheral arterial disease in the Medicare population. Vasc Med. 2008;13(3):209-15. PMID: 18687757. 10.1177/1358863X08089277 18687757
44 Cassar K. Peripheral arterial disease. BMJ Clin Evid. 2011;2011. PMID: 21477401.21477401
45 Bali V, Yermilov I, Coutts K, . Novel screening metric for the identification of at-risk peripheral artery disease patients using administrative claims data. Vasc Med. 2015. PMID: 26608733. 10.1177/1358863x15616687 26608733
46 Taylor-Piliae RE, Fair JM, Varady AN, . Ankle brachial index screening in asymptomatic older adults. Am Heart J. 2011;161(5):979-85. PMID: 21570532. 10.1016/j.ahj.2011.02.003 21570532
47 Eason SL, Petersen NJ, Suarez-Almazor M, . Diabetes mellitus, smoking, and the risk for asymptomatic peripheral arterial disease: whom should we screen? J Am Board Fam Pract. 2005;18(5):355-61. PMID: 16148245.16148245
48 Alzamora MT, Fores R, Baena-Diez JM, . The peripheral arterial disease study (PERART/ARTPER): prevalence and risk factors in the general population. BMC Public Health. 2010;10:38. PMID. 10.1186/1471-2458-10-38 20529387
49 Ramos R, Quesada M, Solanas P, . Prevalence of symptomatic and asymptomatic peripheral arterial disease and the value of the ankle-brachial index to stratify cardiovascular risk. Eur J Vasc Endovasc Surg. 2009;38(3):305-11. PMID. 10.1016/j.ejvs.2009.04.013 19515589
50 Berger JS, Hochman J, Lobach I, . Modifiable risk factor burden and the prevalence of peripheral artery disease in different vascular territories. Journal of Vascular Surgery. 2013;58(3):673-81.e1. PMID: 23642926. 10.1016/j.jvs.2013.01.053 23642926
51 Collins R, Burch J, Cranny G, . Duplex ultrasonography, magnetic resonance angiography, and computed tomography angiography for diagnosis and assessment of symptomatic, lower limb peripheral arterial disease: systematic review. BMJ. 2007;334(7606):1257. PMID: 17548364. 10.1136/bmj.39217.473275.55 17548364
52 Abramson BL, Huckell V, Anand S, . Canadian Cardiovascular Society Consensus Conference: peripheral arterial disease - executive summary. Can J Cardiol. 2005;21(12):997-1006. PMID: 16234879.16234879
53 Mohler E, 3rd, Giri J, Acc, . Management of peripheral arterial disease patients: comparing the ACC/AHA and TASC-II guidelines. Curr Med Res Opin. 2008;24(9):2509-22. PMID: 18664318. 10.1185/03007990802274379 18664318
54 Menke J, Larsen J. Meta-analysis: Accuracy of contrast-enhanced magnetic resonance angiography for assessing steno-occlusions in peripheral arterial disease. Ann Intern Med. 2010;153(5):325-34. PMID: 20820041. 10.7326/0003-4819-153-5-201009070-00007 20820041
55 Met R, Bipat S, Legemate DA, . Diagnostic performance of computed tomography angiography in peripheral arterial disease: a systematic review and meta-analysis. JAMA. 2009;301(4):415-24. PMID: 19176443. 10.1001/jama.301.4.415 19176443
56 Society for Vascular Surgery Lower Extremity Guidelines Writing Group, Conte MS, Pomposelli FB, . Society for Vascular Surgery practice guidelines for atherosclerotic occlusive disease of the lower extremities: management of asymptomatic disease and claudication. J Vasc Surg. 2015;61(3 Suppl):2S-41S. PMID: 25638515. 10.1016/j.jvs.2014.12.009 25638515
57 Hiatt WR. Medical treatment of peripheral arterial disease and claudication. N Engl J Med. 2001;344(21):1608-21. PMID. 10.1056/NEJM200105243442108 11372014
58 Gornik HL, Garcia B, Wolski K, . Validation of a method for determination of the ankle-brachial index in the seated position. J Vasc Surg. 2008;48(5):1204-10. PMID: 18829231. 10.1016/j.jvs.2008.06.052 18829231
59 Hamel JF, Foucaud D, Fanello S. Comparison of the automated oscillometric method with the gold standard Doppler ultrasound method to access the ankle-brachial pressure index. Angiology. 2010;61(5):487-91. PMID: 20211935. 10.1177/0003319709360522 20211935
60 Reed JF, 3rd, Eid S, Edris B, . Prevalence of peripheral artery disease varies significantly depending upon the method of calculating ankle brachial index. Eur J Cardiovasc Prev Rehabil. 2009;16(3):377-81. PMID: 19369879. 10.1097/HJR.0b013e32832955e2 19369879
61 Allison MA, Aboyans V, Granston T, . The relevance of different methods of calculating the ankle-brachial index: the multi-ethnic study of atherosclerosis. Am J Epidemiol. 2010;171(3):368-76. PMID: 20042436. 10.1093/aje/kwp382 20042436
62 Lange SF, Trampisch HJ, Pittrow D, . Profound influence of different methods for determination of the ankle brachial index on the prevalence estimate of peripheral arterial disease. BMC Public Health. 2007;7:147. PMID.18293542
63 Aboyans V, Criqui MH, Abraham P, . Measurement and interpretation of the anklebrachial index: a scientific statement from the American Heart Association. Circulation. 2012;126(24):2890-909. PMID: 23159553. 10.1161/CIR.0b013e318276fbcb 23159553
64 Andras A, Ferket B. Screening for peripheral arterial disease. Cochrane Database of Systematic Reviews. 2014;7(4). PMID: 24711093. 10.1002/14651858.CD010835.pub2 24711093
65 Gerhard-Herman MD, Gornik HL, Barrett C, . 2016 AHA/ACC Guideline on the Management of Patients With Lower Extremity Peripheral Artery Disease: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2016;135(12):e726-e79. PMID: 27840333. 10.1161/CIR.0000000000000471 27840333
66 Rosero EB, Kane K, Clagett GP, . A systematic review of the limitations and approaches to improve detection and management of peripheral arterial disease in Hispanics. J Vasc Surg. 2010;51(4 Suppl):27S-35S. PMID: 19939610. 10.1016/j.jvs.2009.08.085 19879096
67 Mohler ER, III, Treat-Jacobson D, Reilly MP, . Utility and barriers to performance of the ankle-brachial index in primary care practice. Vasc Med. 2004;9(4):253-60. PMID: 15678616. 10.1191/1358863x04vm559oa 15678616
68 Levin DC, Gardiner GA, Jr., Parker L, . Vascular Ultrasound and Noninvasive Physiological Testing for Peripheral Arterial Disease: Are These Tests Being Overused? J Am Coll Radiol. 2015. PMID: 26603096. 10.1016/j.jacr.2015.08.024 26603096
69 Alahdab F, Wang AT, Elraiyah TA, . A systematic review for the screening for peripheral arterial disease in asymptomatic patients. Journal of Vascular Surgery. 2015;61(3 Suppl):42S-53S. PMID: 25721066. 10.1016/j.jvs.2014.12.008 25721066
70 Rooke TW, Hirsch AT, Misra S, . Management of patients with peripheral artery disease (compilation of 2005 and 2011 ACCF/AHA Guideline Recommendations): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2013;61(14):1555-70. PMID: 23473760. 10.1016/j.jacc.2013.01.004 23473760
71 Goff DC, Jr., Lloyd-Jones DM, Bennett G, . 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2935-59. PMID: 24239921. 10.1016/j.jacc.2013.11.005 24998130
72 American Academy of Family Physicians. Peripheral Arterial Disease. Leawood, KS: American Academy of Family Physicians; 2015. Available from: http://www.aafp.org/patient-care/clinical-recommendations/all/pad.html.
73 Moyer VA, U. S. Preventive Services Task Force. Screening for peripheral artery disease and cardiovascular disease risk assessment with the ankle-brachial index in adults: U.S. Preventive Services Task Force recommendation statement.[Summary for patients in Ann Intern Med. 2013 Sep 3;159(5):I-28; PMID: 24026333]. Annals of Internal Medicine. 2013;159(5):342-8. PMID: 24026320. 10.7326/0003-4819-159-5-201309030-00008 24026320
74 Lin JS, Evans CV, Johnson E, . Nontraditional Risk Factors in Cardiovascular Disease Risk Assessment: A Systematic Evidence Report for the U.S. Preventive Services Task Force. Rockville, MD.: Agency for Healthcare Research and Quality; 2017.
75 Lin JS, Olson CM, Johnson ES, . The Ankle Brachial Index for Peripheral Artery Disease Screening and Cardiovascular Disease Prediction in Asymptomatic Adults: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2013. 12-05162-EF-1.
76 Brownrigg JR, Hinchliffe RJ, Apelqvist J, . Effectiveness of bedside investigations to diagnose peripheral artery disease among people with diabetes mellitus: a systematic review. Diabetes/Metabolism Research Reviews. 2016;32 Suppl 1:119-27. PMID: 26342170. 10.1002/dmrr.2703 26342170
77 Crawford F, Welch K, Andras A, . Ankle brachial index for the diagnosis of lower limb peripheral arterial disease. 2016. 1465-1858. Available from: 10.1002/14651858.CD010680.pub2.
78 Lane R, Ellis B, Watson L, . Exercise for intermittent claudication. Cochrane Database of Systematic Reviews. 2014;7:CD000990. PMID: 25037027. 10.1002/14651858.CD000990.pub3 25037027
79 Lyu X, Li S, Peng S, . Intensive walking exercise for lower extremity peripheral arterial disease: A systematic review and meta-analysis. J Diabetes. 2016;8(3):363-77. PMID: 25940390. 10.1111/1753-0407.12304 25940390
80 Parmenter BJ, Dieberg G, Phipps G, . Exercise training for health-related quality of life in peripheral artery disease: a systematic review and meta-analysis. Vascular Medicine. 2015;20(1):30-40. PMID: 25432991. 10.1177/1358863X14559092 25432991
81 Qian J, Yang XH. A Meta-Analysis of Randomized Controlled Trials on Antiplatelet Agents Versus Placebo/Control for Treating Peripheral Artery Disease. Medicine. 2015;94(31):e1293. PMID: 26252306. 10.1097/MD.0000000000001293 26252306
82 Raparelli V, Proietti M, Napoleone L, . Asymptomatic peripheral artery disease and antiplatelet management. Vasa. 2014;43(5):309-25. PMID: 25147008. 10.1024/0301-1526/a000369 25147008
83 Xu D, Zou L, Xing Y, . Diagnostic value of ankle-brachial index in peripheral arterial disease: a meta-analysis. Canadian Journal of Cardiology. 2013;29(4):492-98. PMID: 22926041. 10.1016/j.cjca.2012.06.014 22926041
84 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. Available from: http://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes
85 Regensteiner JG, Steiner JF, Hiatt WR. Exercise training improves functional status in patients with peripheral arterial disease. J Vasc Surg. 1996;23(1):104-15. PMID: 8558725.8558725
86 Jain A, Liu K, Ferrucci L, . The Walking Impairment Questionnaire stair-climbing score predicts mortality in men and women with peripheral arterial disease. Journal of Vascular Surgery. 2012;55(6):1662-73.e2. PMID: 22608041. 10.1016/j.jvs.2011.12.010 22608041
87 Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978;299(17):926-30. PMID: 692598. 10.1056/NEJM197810262991705 692598
88 Lijmer JG, Mol BW, Heisterkamp S, . Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282(11):1061-6. PMID: 10493205. 10.1001/jama.282.11.1061 10493205
89 Whiting P, Rutjes AW, Reitsma JB, . Sources of variation and bias in studies of diagnostic accuracy: a systematic review. Ann Intern Med. 2004;140(3):189-202. PMID: 14757617. 10.7326/0003-4819-140-3-200402030-00010 14757617
90 Rutjes AW, Reitsma JB, Di Nisio M, . Evidence of bias and variation in diagnostic accuracy studies. CMAJ. 2006;174(4):469-76. PMID: 16477057. 10.1503/cmaj.050090 16477057
91 Leeflang MM, Bossuyt PM, Irwig L. Diagnostic test accuracy may vary with prevalence: implications for evidence-based diagnosis. J Clin Epidemiol. 2009;62(1):5-12. PMID: 18778913. 10.1016/j.jclinepi.2008.04.007 18778913
92 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
93 Lewis JE, Owens DR. The pulse volume recorder as a measure of peripheral vascular status in people with diabetes mellitus. Diabetes Technol Ther. 2010;12(1):75-80. PMID: 20082588. 10.1089/dia.2009.0061 20082588
94 McDermott MM, Tiukinhoy S, Greenland P, . A pilot exercise intervention to improve lower extremity functioning in peripheral arterial disease unaccompanied by intermittent claudication. J Cardiopulm Rehabil. 2004;24:187-96. PMID: 15235301.15235301
95 Mehler PS, Coll JR, Estacio R, . Intensive blood pressure control reduces the risk of cardiovascular events in patients with peripheral arterial disease and type 2 diabetes. Circulation. 2003;107(5):753-6. PMID: 12578880. 10.1161/01.CIR.0000049640.46039.52 12578880
96 Agresti A, Coull BA. Approximate is Better than “Exact” for Interval Estimation of Binomial Proportions. The American Statistician. 1998;52(2):119-26. 10.2307/2685469
97 Guirguis-Blake JM, Evans CV, Senger CA, . Aspirin for the Primary Prevention of Cardiovascular Events: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 131. Rockville, MD: Agency for Healthcare Research and Quality; 2015. 13-05195-EF-1. Available from: http://www.ncbi.nlm.nih.gov/pubmed/26491760.
98 Belch J, MacCuish A, Campbell I, . The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. PMID: 18927173. 10.1136/bmj.a1840 18927173
99 Abrams KR, Gillies CL, Lambert PC. Meta-analysis of heterogeneously reported trials assessing change from baseline. Stat Med. 2005;24(24):3823-44. PMID: 16320285. 10.1002/sim.2423 16320285
100 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314-49.
101 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
102 Fowkes FG, Price JF, Stewart MC, . Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303(9):841-8. PMID: 20197530. 10.1001/jama.2010.221 20197530
103 Wikstrom J, Hansen T, Johansson L, . Ankle brachial index <0.9 underestimates the prevalence of peripheral artery occlusive disease assessed with whole-body magnetic resonance angiography in the elderly. Acta Radiol. 2008;49(2):143-9. PMID: 18300136. 10.1080/02841850701732957 18300136
104 Wikstrom J, Hansen T, Johansson L, . Lower extremity artery stenosis distribution in an unselected elderly population and its relation to a reduced ankle-brachial index. J Vasc Surg. 2009;50(2):330-4. PMID: 19446989. 10.1016/j.jvs.2009.03.008 19446989
105 Collins TC, Johnson SL, Souchek J. Unsupervised walking therapy and atherosclerotic riskfactor management for patients with peripheral arterial disease: a pilot trial. Ann Behav Med. 2007;33(3):318-24. PMID: 17600459. 10.1080/08836610701360181 17600459
106 Fowler B, Jamrozik K, Norman P, . Improving maximum walking distance in early peripheral arterial disease: randomised controlled trial. Aust J Physiother. 2002;48(4):269-75. PMID: 12443521. 10.1016/S0004-9514(14)60166-5 12443521
107 Diederichsen AC, Rasmussen LM, Sogaard R, . The Danish Cardiovascular Screening Trial (DANCAVAS): study protocol for a randomized controlled trial. Trials. 2015;16:554. PMID: 26637993. 10.1186/s13063-015-1082-6 26637993
108 Betriu A, Farras C, Abajo M, . Randomised intervention study to assess the prevalence of subclinical vascular disease and hidden kidney disease and its impact on morbidity and mortality: The ILERVAS project. Nefrologia. 2016;36(4):389-96. PMID: 27044887. 10.1016/j.nefro.2016.02.008 27044887
109 Lindholt JS, Søgaard R. Population screening and intervention for vascular disease in Danish men (VIVA): a randomised controlled trial. Lancet. 2017;390(10109):2256-65. PMID: 28859943. 10.1016/S0140-6736(17)32250-X 28859943
110 Lind L, Fors N, Hall J, . A comparison of three different methods to evaluate endothelium-dependent vasodilation in the elderly: the Prospective Investigation of the Vasculature in Uppsala Seniors (PIVUS) study. Arterioscler Thromb Vasc Biol. 2005;25(11):2368-75. PMID: 16141402. 10.1161/01.ATV.0000184769.22061.da 16141402
111 Calfas KJ, Long BJ, Sallis JF, . A controlled trial of physician counseling to promote the adoption of physical activity. Prev Med. 1996;25(3):225-33. PMID: 8780999. 10.1006/pmed.1996.0050 8780999
112 Grondal N, Sogaard R, Henneberg EW, . The Viborg Vascular (VIVA) screening trial of 65-74 year old men in the central region of Denmark: study protocol. Trials [Electronic Resource]. 2010;11:67. PMID: 20507582. 10.1186/1745-6215-11-67 20507582
113 Tehan PE, Chuter VH. A targeted screening method for non-invasive vascular assessment of the lower limb. J Foot Ankle Res. 2016;9:48. PMID: 27980685. 10.1186/s13047-016-0181-2 27980685
114 McDermott MM, Guralnik JM, Greenland P, . Statin use and leg functioning in patients with and without lower-extremity peripheral arterial disease. Circulation. 2003;107(5):757-61. PMID: 12578881. 10.1161/01.CIR.0000050380.64025.07 12578881
115 Vidula H, Tian L, Liu K, . Comparison of effects of statin use on mortality in patients with peripheral arterial disease with versus without elevated C-reactive protein and d-dimer levels. Am J Cardiol. 2010;105(9):1348-52. PMID: 20403491. 10.1016/j.amjcard.2009.12.054 20403491
116 Sander K, Bickel H, Schulze Horn C, . [Peripheral arterial disease: predictors and treatment intensity. Two-years of data from the population-based INVADE project]. Dtsch Med Wochenschr. 2008;133(10):455-9. PMID: 18302095. 10.1055/s-20081046731 18302095
117 Ramos R, García-Gil M, Comas-Cufí M, . Statins for Prevention of Cardiovascular Events in a Low-Risk Population With Low Ankle Brachial Index. J Am Coll Cardiol. 2016;67(6):630-40. PMID: 26868687. 10.1016/j.jacc.2015.11.052 26868687
118 Centers for Medicare & Medicaid Services. Decision Memo for Supervised Exercise Therapy (SET) for Symptomatic Peripheral Artery Disease (PAD) (CAG-00449N). https://www.cms.gov/medicare-coverage-database/details/nca-decisionmemo.aspx?NCAId=287. Accessed: August 25, 2017.
119 Davies JH, Richards J, Conway K, . Primary care screening for peripheral arterial disease: a cross-sectional observational study. Br J Gen Pract. 2017;67(655):e103-e10. PMID: 28126882. 10.3399/bjgp17X689137 28126882
120 Grau M, Baena-Diez JM, Felix-Redondo FJ, . Estimating the risk of peripheral artery disease using different population strategies. Preventive Medicine. 2013;57(4):328-33. PMID: 23769902. 10.1016/j.ypmed.2013.06.007 23769902
121 Zhan Y, Zhuang J, Dong Y, . Predicting the prevalence of peripheral arterial diseases: modelling and validation in different cohorts. Vasa. 2016;45(1):31-6. PMID: 26986707. 10.1024/0301-1526/a000492 26986707
122 Shah S, Antoniou GA, Torella F. Evidence-based analysis of peripheral arterial disease screening based on the WHO criteria. Int Angiol. 2015;4:4. PMID: 26344513. 10.23736/S0392-9590.17.03468-X 26344513
123 Bedenis R, Stewart M, Cleanthis M, . Cilostazol for intermittent claudication. Cochrane Database of Systematic Reviews. 2014;10:CD003748. PMID: 25358850. 10.1002/14651858.CD003748.pub4 25358850
124 Salhiyyah K, Senanayake E, Abdel-Hadi M, . Pentoxifylline for intermittent claudication. Cochrane Database of Systematic Reviews. 2012;1:CD005262. PMID: 22258961. 10.1002/14651858.CD005262.pub2 22258961
125 Wong PF, Chong LY, Mikhailidis DP, . Antiplatelet agents for intermittent claudication. Cochrane Database of Systematic Reviews. 2011;11:CD001272. PMID: 22071801. 10.1002/14651858.CD001272.pub2 22071801
126 Aung PP, Maxwell HG, Jepson RG, . Lipid-lowering for peripheral arterial disease of the lower limb. Cochrane Database Syst Rev. 2007(4):CD000123. PMID: 17943736. 10.1002/14651858.CD000123.pub2 17943736
127 Lauret GJ, Fakhry F, Fokkenrood HJ, . Modes of exercise training for intermittent claudication. Cochrane Database Syst Rev. 2014(7):CD009638. PMID: 24993079. 10.1002/14651858.CD009638.pub2 24993079
128 Jude EB, Oyibo SO, Chalmers N, . Peripheral arterial disease in diabetic and nondiabetic patients: a comparison of severity and outcome. Diabetes Care. 2001;24(8):1433-7. PMID: 11473082. 10.2337/diacare.24.8.1433 11473082
129 Faglia E, Caravaggi C, Marchetti R, . Screening for peripheral arterial disease by means of the ankle-brachial index in newly diagnosed Type 2 diabetic patients. Diabetic Medicine. 2005;22(10):1310-4. PMID: 16176188. 10.1111/j.1464-5491.2005.01612.x 16176188
130 Criqui MH, McClelland RL, McDermott MM, . The ankle-brachial index and incident cardiovascular events in the MESA (Multi-Ethnic Study of Atherosclerosis). J Am Coll Cardiol. 2010;56(18):1506-12. PMID: 20951328. 10.1016/j.jacc.2010.04.060 20951328
131 Murabito JM, Evans JC, Nieto K, . Prevalence and clinical correlates of peripheral arterial disease in the Framingham Offspring Study. Am Heart J. 2002;143(6):961-5. PMID: 12075249. 10.1067/mhj.2002.122871 12075249
132 Faglia E. Characteristics of peripheral arterial disease and its relevance to the diabetic population. Int J Low Extrem Wounds. 2011;10(3):152-66. PMID: 21856972. 10.1177/1534734611417352 21856972
133 American Diabetes Association. Standards of Medical Care in Diabetes-2017. Diabetes Care. 2017;40(Suppl 1):S1-S135. PMID: 27979887. 10.2337/dc17-S003 27979885
134 McDermott MM, Guralnik JM, Ferrucci L, . Asymptomatic peripheral arterial disease is associated with more adverse lower extremity characteristics than intermittent claudication. Circulation. 2008;117(19):2484-91. PMID: 18458172. 10.1161/CIRCULATIONAHA.107.736108 18458172
135 McDermott MM, Applegate WB, Bonds DE, . Ankle brachial index values, leg symptoms, and functional performance among community-dwelling older men and women in the lifestyle interventions and independence for elders study. J Am Heart Assoc. 2013;2(6):e000257. PMID: 24222666. 10.1161/JAHA.113.000257 24222666
136 McDermott MM, Kerwin DR, Liu K, . Prevalence and significance of unrecognized lower extremity peripheral arterial disease in general medicine practice*. J Gen Intern Med. 2001;16(6):384-90. PMID: 11422635 10.1046/j.15251497.2001.016006384.x 11422635
137 Wassel CL, Allison MA, Ix JH, . Ankle-brachial index predicts change over time in functional status in the San Diego Population Study. J Vasc Surg. 2016;64(3):656-62e1. PMID: 27139783. 10.1016/j.jvs.2016.02.066 27139783
138 McDermott MM, Fried L, Simonsick E, . Asymptomatic peripheral arterial disease is independently associated with impaired lower extremity functioning: the women's health and aging study. Circulation. 2000;101(9):1007-12. PMID: 10704168. 10.1161/01.CIR.101.9.1007 10704168
139 Collins TC, Petersen NJ, Suarez-Almazor M, . The prevalence of peripheral arterial disease in a racially diverse population. Arch Intern Med. 2003;163(12):1469-74. PMID: 12824097. 10.1001/archinte.163.12.1469 12824097
140 McDermott MM, Liu K, Guralnik JM, . Home-based walking exercise intervention in peripheral artery disease: a randomized clinical trial. JAMA. 2013;310(1):57-65. PMID: 23821089. 10.1001/jama.2013.7231 23821089
141 McDermott MM, Ades P, Guralnik JM, . Treadmill exercise and resistance training in patients with peripheral arterial disease with and without intermittent claudication: a randomized controlled trial. JAMA. 2009;301(2):165-74. PMID: 19141764. 10.1001/jama.2008.962 19141764
142 McDermott MM, Guralnik JM, Criqui MH, . Home-based walking exercise in peripheral artery disease: 12-month follow-up of the GOALS randomized trial. J Am Heart Assoc. 2014;3(3):e000711. PMID: 24850615. 10.1161/JAHA.113.000711 24850615
143 Rejeski WJ, Spring B, Domanchuk K, . A group-mediated, home-based physical activity intervention for patients with peripheral artery disease: effects on social and psychological function. J Transl Med. 2014;12:29. PMID: 24467875. 10.1186/1479-5876-12-29 24467875
144 Fowkes FG, Murray GD, Butcher I, . Development and validation of an ankle brachial index risk model for the prediction of cardiovascular events. Eur J Prev Cardiol. 2014;21(3):310-20. PMID: 24367001. 10.1177/2047487313516564 24367001
145 Campens L, Backer T, Simoens S, . Accuracy of oscillometric determination of the anklebrachial index as screening method for peripheral artery disease. Acta Cardiol. 2012;67(1):136-7.
146 Kollias A, Xilomenos A, Protogerou A, . Automated determination of the ankle-brachial index using an oscillometric blood pressure monitor: validation vs. Doppler measurement and cardiovascular risk factor profile. Hypertens Res. 2011;34(7):825-30. PMID: 21593742. 10.1038/hr.2011.53 21593742
147 McDermott MM, Reed G, Greenland P, . Activating peripheral arterial disease patients to reduce cholesterol: a randomized trial. Am J Med. 2011;124(6):557-65. PMID: 21605733. 10.1016/j.amjmed.2010.11.032 21605733
148 de Vries M, Ouwendijk R, Kessels AG, . Comparison of generic and disease-specific questionnaires for the assessment of quality of life in patients with peripheral arterial disease. J Vasc Surg. 2005;41(2):261-8. PMID: 15768008. 10.1016/j.jvs.2004.11.022 15768008
149 U. S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(19):1997-2007. PMID: 27838723. 10.1001/jama.2016.15450 27838723
150 Stone NJ, Robinson JG, Lichtenstein AH, . 2013 ACC/AHA guideline on the treatment of blood cholesterol to reduce atherosclerotic cardiovascular risk in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2889-934. PMID: 24239923. 10.1016/j.jacc.2013.11.002 24239923
151 Bibbins-Domingo K, Force USPST. Aspirin Use for the Primary Prevention of Cardiovascular Disease and Colorectal Cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2016. PMID. 10.7326/M16-0577
152 Dehmer SP, Maciosek MV, Flottemesch TJ. Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: A Decision Analysis: Technical Report. Rockville (MD) 2015.
153 The Danish Cardiovascular Screening Trial (DANCAVAS). ISRCTN12157806.. http://www.isrctn.com/ISRCTN12157806. Accessed.
154 Aboyans V, Ricco JB, Bartelink MEL, . 2017 ESC Guidelines on the Diagnosis and Treatment of Peripheral Arterial Diseases, in collaboration with the European Society for Vascular Surgery (ESVS): Document covering atherosclerotic disease of extracranial carotid and vertebral, mesenteric, renal, upper and lower extremity arteriesEndorsed by: the European Stroke Organization (ESO)The Task Force for the Diagnosis and Treatment of Peripheral Arterial Diseases of the European Society of Cardiology (ESC) and of the European Society for Vascular Surgery (ESVS). Eur Heart J. 2018;39(9):763-816. PMID: 28886620. 10.1093/eurheartj/ehx095 28886620
155 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. Leawood, Kansas: American Academy of Family Physicians; 2017. Available from: https://www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cpsrecommendations.pdf.
156 Layden J, Michaels J, Bermingham S, . Diagnosis and management of lower limb peripheral arterial disease: summary of NICE guidance. BMJ. 2012;345:e4947. PMID: 22875949. 10.1136/bmj.e4947 22875949
157 Lim LS, Haq N, Mahmood S, . Atherosclerotic cardiovascular disease screening in adults: American College Of Preventive Medicine position statement on preventive practice. Am J Prev Med. 2011;40(3):381-10. PMID: 21335273. 10.1016/j.amepre.2010.11.021 21335273
158 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services: Report of the U.S. Preventive Services Task Force. Baltimore, MD: Williams & Wilkins; 1996. 9780683085082.
159 Screening for Peripheral Arterial Disease: A Brief Evidence Update for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality; 2005.
160 Vogt MT, Cauley JA, Newman AB, . Decreased ankle/arm blood pressure index and mortality in elderly women. JAMA. 1993;270(4):465-9. PMID: 8320785. 10.1001/jama.1993.03510040069031 8320785
161 Moneta GL, Strandness DE, Jr. Peripheral arterial duplex scanning. J Clin Ultrasound. 1987;15(9):645-51. PMID: 3119669.3119669
162 Strandness DE, Didisheim P, Clowes AW, . Vascular Diseases: Current Research and Clinical Applications. 1987.
163 Criqui MH, Fronek A, Klauber MR, . The sensitivity, specificity, and predictive value of traditional clinical evaluation of peripheral arterial disease: results from noninvasive testing in a defined population. Circulation. 1985;71(3):516-22. PMID: 3156007. 10.1161/01.CIR.71.3.516 3156007
164 Barnes RW. Noninvasive diagnostic techniques in peripheral vascular disease. Am Heart J. 1979;97(2):241-58. PMID: 153709.153709
165 Hanssen NM, Huijberts MS, Schalkwijk CG, . Associations Between the AnkleBrachial Index and Cardiovascular and All-Cause Mortality Are Similar in Individuals Without and With Type 2 Diabetes: Nineteen-year follow-up of a population-based cohort study. Diabetes Care. 2012;35(8):1731-5. PMID: 22699294. 10.2337/dc12-0178 22699294
166 Kavousi M, Elias-Smale S, Rutten JH, . Evaluation of newer risk markers for coronary heart disease risk classification: a cohort study. Ann Intern Med. 2012;156(6):438-44. PMID: 22431676. 10.7326/0003-4819-156-6-201203200-00006 22431676
167 Murphy TP, Dhangana R, Pencina MJ, . Ankle-brachial index and cardiovascular risk prediction: An analysis of 11,594 individuals with 10-year follow-up. Atherosclerosis. 2012;220(1):160-7. PMID: 22099055. 10.1016/j.atherosclerosis.2011.10.037 22099055
168 Yeboah J, McClelland RL, Polonsky TS, . Comparison of novel risk markers for improvement in cardiovascular risk assessment in intermediate-risk individuals. JAMA. 2012;308(8):788-95. PMID: 22910756. 10.1001/jama.2012.9624 22910756
169 Rodondi N, Marques-Vidal P, Butler J, . Markers of atherosclerosis and inflammation for prediction of coronary heart disease in older adults. Am J Epidemiol. 2010;171(5):540-9. PMID: 20110287. 10.1093/aje/kwp428 20110287
170 Sutton-Tyrrell K, Venkitachalam L, Kanaya AM, . Relationship of ankle blood pressures to cardiovascular events in older adults. Stroke. 2008;39(3):863-9. PMID: 18258843. 10.1161/STROKEAHA.107.487439 18258843
171 Price JF, Tzoulaki I, Lee AJ, . Ankle brachial index and intima media thickness predict cardiovascular events similarly and increased prediction when combined. J Clin Epidemiol. 2007;60(10):1067-75. PMID: 17884603. 10.1016/j.jclinepi.2007.01.011 17884603
172 Weatherley BD, Nelson JJ, Heiss G, . The association of the ankle-brachial index with incident coronary heart disease: the Atherosclerosis Risk In Communities (ARIC) study, 1987-2001. BMC Cardiovasc Disord. 2007;7:3. PMID: 17227586. 10.1186/1471-2261-7-3 17227586
173 Lee AJ, Price JF, Russell MJ, . Improved prediction of fatal myocardial infarction using the ankle brachial index in addition to conventional risk factors: the Edinburgh Artery Study. Circulation. 2004;110(19):3075-80. PMID: 15477416. 10.1161/01.CIR.0000143102.38256.DE 15477416
174 van der Meer IM, Bots ML, Hofman A, . Predictive value of noninvasive measures of atherosclerosis for incident myocardial infarction: the Rotterdam Study. Circulation. 2004;109(9):1089-94. PMID: 14993130. 10.1161/01.CIR.0000120708.59903.1B 14993130
175 Abbott RD, Rodriguez BL, Petrovitch H, . Ankle-brachial blood pressure in elderly men and the risk of stroke: the Honolulu Heart Program. J Clin Epidemiol. 2001;54(10):973-8. PMID: 11576807. 10.1016/S0895-4356(01)00373-0 11576807
176 Abbott RD, Petrovitch H, Rodriguez BL, . Ankle/brachial blood pressure in men >70 years of age and the risk of coronary heart disease. Am J Cardiol. 2000;86(3):280-4. PMID: 10922433. 10.1016/S0002-9149(00)00914-0 10922433
177 Tsai AW, Folsom AR, Rosamond WD, . Ankle-brachial index and 7-year ischemic stroke incidence: the ARIC study. Stroke. 2001;32(8):1721-4. PMID: 11486096. 10.1161/01.STR.32.8.1721 11486096
178 Tornwall M, Virtamo J, Haukka JK, . Effect of alpha-tocopherol (vitamin E) and betacarotene supplementation on the incidence of intermittent claudication in male smokers. Arterioscler Thromb Vasc Biol. 1997;17(12):3475-80. PMID: 9437195. 10.1161/01.ATV.17.12.3475 9437195
179 Berger JS, Lala A, Krantz MJ, . Aspirin for the prevention of cardiovascular events in patients without clinical cardiovascular disease: a meta-analysis of randomized trials. Am Heart J. 2011;162(1):115-24 e2. PMID: 21742097. 10.1016/j.ahj.2011.04.006 21742097
180 McDermott MM, Liu K, Guralnik JM, . Measurement of walking endurance and walking velocity with questionnaire: validation of the walking impairment questionnaire in men and women with peripheral arterial disease. J Vasc Surg. 1998;28(6):1072-81. PMID: 9845659. 10.1016/S0741-5214(98)70034-5 9845659