# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Elisabeth U. Kato, MD, MRP, formerly of AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Smyth Lai, MLS, for creating and conducting literature searches; Selvi B. Williams, MD, MPH, for assistance with abstract review; Diane Reid, MD, for providing federal partner review of the draft report; Gerry Fowkes, MD, Mary McDermott, MD, and Joshua Beckman, MD, MSc, who provided expert review of the draft report; and Erin L. Coppola, MPH, and Katherine Essick, BS, for technical and editorial assistance at the Center for Health Research.