# 4 Discussion

## Summary of Evidence

There is no direct evidence addressing the effectiveness of screening for PAD with the ABI to reduce PAD- or CVD-related morbidity or mortality. We are aware of three in-progress trials that include PAD screening as part of combination vascular screening (Appendix D Table 1);^107,^ ^112^ however, the multicomponent nature of the screening intervention will preclude definitive conclusions about the effectiveness of screening with the ABI alone. The indirect chain of evidence presented in this review is limited. A single diagnostic accuracy study demonstrates that the ABI has poor sensitivity for detecting PAD in unselected populations. In contrast, other systematic reviews of largely symptomatic populations have reported much higher diagnostic accuracy compared with our review.^69,^ ^76,^ ^77,^ ^83^ For example, pooled sensitivities and specificities for an ABI ≤0.9 compared with an angiographic gold standard have been reported at 75 percent (95% CI, 71% to 79%) and 86 percent (95% CI, 83% to 90%), respectively, with significant heterogeneity.^83^ The far lower sensitivity in our single included study compared with the larger literature in symptomatic populations is likely due to an expected poorer accuracy in screening populations. These populations have lower pretest probability of disease compared with symptomatic populations, as well as issues of study quality in a single study population. One recent diagnostic accuracy study comparing two algorithms for targeted screening in high-risk populations as defined per AHA guidelines^65^ (>65 years; 50 to 64 years with a traditional CVD risk factor or family history of PAD; <50 years with diabetes and a traditional CVD risk factor) reported a sensitivity of 49 percent and specificity of 94 percent; this study used the TBI in place of the ABI as the diagnostic test in those with an ABI above 1.4, and was thus excluded from our review.^113^ For treatment benefit, our review identified two primary prevention trials of aspirin that recruited asymptomatic individuals with a low ABI. These trials demonstrate that aspirin is not effective in reducing composite CVD morbidity or mortality over 6 to 8 years of followup. Both trials defined a low ABI using higher thresholds than in standard clinical practice (i.e., ≤0.95 or ≤0.99); the aim was to use the ABI as a nontraditional risk factor and identify a population with a higher risk for CVD events that might potentially benefit from aspirin, not to diagnose PAD in a screening population. With a median baseline ABI of 0.90 in POPADAD, half of the population did not have PAD by traditional definitions, and this may have reduced the observed benefit of aspirin; however, subgroup analyses by baseline ABI did not show heterogeneity of treatment effect (p for interaction of 0.17). Similarly, in AAA which had a mean baseline ABI of 0.86, post hoc subgroup analyses did not show different results for the primary composite outcome by baseline ABI. Other systematic reviews of antiplatelet therapy have similarly reported no overall reduction in CVD events with aspirin, compared with control in populations with a low ABI.^69,^ ^81,^ ^82^ Our review did not identify any other pharmacologic trials in screen-detected PAD populations reporting patient health outcomes; observational studies suggest both functional and mortality benefits of statins, but confidence in results is substantially limited by the nonrandomized nature of study designs.^69,^ ^114-117^ In our review, two underpowered, short-term exercise trials in participants recruited through screening or oversampling of individuals without symptoms or with atypical symptoms show no statistically significant treatment effect on quality of life or development of symptoms at 3 and 12 months of followup, with the exception of one trial showing an improvement in the stair-climbing component of the WIQ. In contrast, several systematic reviews of exercise therapy in largely symptomatic populations have concluded that exercise programs are associated with improved maximum walking distance and time, pain-free walking distance, 6-minute walk, WIQ scores, and quality of life.^69,^ ^78-80^ Consistent with this evidence, the Centers for Medicare & Medicaid Services recently approved coverage of supervised exercise therapy in beneficiaries with intermittent claudication for the treatment of symptomatic PAD.^118^

Evidence is summarized in the Summary of Evidence (Table 18).

Table 18 Summary of Evidence

KQ | No. of studies (k), No. of participants randomized (n) | Outcome | No. of trials (k), number of participants analyzed (n) | Summary of findings by outcome | Consistency/Precision | Reporting bias | EPC assessment of strength of evidence | Study quality | Body of evidence limitations | Applicability
KQ1: Direct evidence for screening | k=0 | Morbidity or mortality | 0 | NA | | | | NA
KQ2: Diagnostic accuracy | k=1 (0 new), n=307 | Sensitivity, specificity, PPV, NPV | k=1, n=306 | The ABI has low sensitivity (7-34%) and high specificity (96-100%) compared to MRA gold standard imaging | Consistency-NA (single study) Imprecise | Not detected | Insufficient | 1 Fair | Single study, not clear if MRA interpreters were blind to ABI results; harms (aside from FP and FN) not reported other than single vasovagal episode | Screening population of older adults (age 70) in Sweden. The low sensitivity reported in this single study is well below the sensitivities reported in symptomatic populations.
KQ3: Harms | k=1 (0 new), n=307 | Harms | k=1, n=306 | The ABI has a high false negative rate (>80%) reflecting the low sensitivity in screening for PAD. | Consistency-NA (single study) Imprecise | Not detected | Insufficient | 1 Fair | Single study, not clear if MRA interpreters were blind to ABI results; harms (aside from FP and FN) not reported other than single vasovagal episode | Screening population of older adults (age 70) in Sweden. The low sensitivity reported in this single study is well below the sensitivities reported in symptomatic populations.
KQ4: Treatment benefit | Aspirin k=2 (1 new), n=4,626 | CVD composite, ACM, individual CVD outcomes | k=2, n=4,626 | Aspirin 100 mg daily showed no effect on CVD composite events in the two trials: Adj HR (95% CI): 1.00 (0.81 to 1.23) HR (95% CI): 0.98 (0.76 to 1.26) No effect on ACM: HR (95% CI): 0.95 (0.77 to 1.16) HR (95% CI): 0.93 (0.71 to 1.24) No statistically significant difference in individual CVD outcomes including: MI, CVA, development of intermittent claudication and need for peripheral arterial revascularization or above the ankle amputation procedures | Reasonably consistent Imprecise | Not detected | Low-to-Moderate | 2 Good | Studies designed to detect differences in CVD composites but not individual CVD outcomes. | Two Scottish trials in asymptomatic patients with a low ABI defined as ≤0.95 and ≤0.99 (thresholds not typically used to define an abnormal ABI in clinical practice). 1 trial exclusively in patients with diabetes. Populations at intermediate to high CVD risk.
KQ4: Treatment benefit | Exercise k=2 (2 new), n=932 | Quality of Life | k=2, n=745 | No difference in quality of life changes from baseline (as measured by MOS SF-36 and Rosser HrQOL questionnaire) | Reasonably consistent Imprecise | Not detected | Insufficient | 1 Good, 1 Fair | One feasibility trial in almost exclusively men was short (12 weeks) and underpowered (n=50) to detect difference in primary or secondary outcomes. Second trial (N=882) powered to detect walking ability before onset of symptoms | Unclear whether population representative of screen-detected population; included participants almost 100% male
KQ4: Treatment benefit | Exercise k=2 (2 new), n=932 | WIQ | k=1; n=48 | No difference in WIQ score change from baseline for distance or speed components; statistically significant improvement in stair climbing component in IG compared to CG | NA | Not detected | Insufficient | 1 Fair | | Unclear whether population representative of screen-detected population; included participants almost 100% male
KQ4: Treatment benefit | Exercise k=2 (2 new), n=932 | Proportion of participants with symptoms | k=2, n=722 | No change in proportion of participants who develop IC or atypical symptoms | Reasonably consistent Imprecise | Not detected | Insufficient | 1 Good, 1 Fair | | Unclear whether population representative of screen-detected population; included participants almost 100% male
KQ4a: Treatment benefit by subgroup | Aspirin k=2 (1 new), n=4,626 | CVD composite, individual CVD outcomes, fatal CVD events, ACM | k=2, n=4,626 | No compelling evidence to support a differential treatment effect by age, sex, or diabetes status. Within trial comparisons revealed overlapping CIs and the single trial (POPADAD) reporting heterogeneity testing for CVD outcomes by age and sex reported nonstatistically significant interaction testing. Results exclusively in participants with diabetes (POPADAD) showing similar outcomes to those almost exclusively without diabetes (AAA) | Inconsistent (age) Reasonably consistent (sex) Imprecise (age, sex) | Not detected | Insufficient | 2 Good | Only 1 trial performed interaction testing by age, sex and unclear if a priori planned analysis. Other trial prespecified subgroup analysis but did not perform interaction testing. No available data for within-group comparisons by diabetes status. CIs wide and overlapping across subgroups analyzed. | Both Scottish trials in asymptomatic patients with a low ABI defined as ≤0.95 and ≤0.99 (thresholds not typically used to define an abnormal ABI in clinical practice). One trial exclusively in patients with diabetes. Populations at intermediate to high CVD risk.
KQ4a: Treatment benefit by subgroup | Exercise: k=0 | - | - | No exercise trials examine the differential treatment effect by subpopulation. | - | - | - | - | - | -
KQ5: Treatment harms | Aspirin k=2 (1 new), n=4,626 | Major GI bleeding requiring admission | k=1, n=3,350 | Major GI bleeding requiring hospital admission was similar in one reporting trial (AAA) of 100 mg enteric coated aspirin at 8.2 year followup: 0.5% versus 0.5%; RR (95% CI): 1.13 (0.44 to 2.91)). Limited evidence from this trial demonstrates a trend towards higher risk for major bleeding events with the use of aspirin. Two trials reported conflicting results on total or fatal hemorrhagic CVA risk with wide confidence intervals due to rare event rate. | Consistency-NA (single study) Imprecise | Not detected | Low | 1 Good | Rare events, wide CIs | Asymptomatic patients with a low ABI defined as ≤0.95 with intermediate CVD risk
KQ5: Treatment harms | Aspirin k=2 (1 new), n=4,626 | Major hemorrhage (defined as nonfatal or fatal hemorrhagic CVA, fatal or nonfatal subarachnoid subdural hemorrhage, GI bleed requiring admission, and other bleeding requiring hospital admission) | K=1, n=3,350 | Major hemorrhage did not reach statistical significance but was slightly higher in the aspirin group: 2.0% vs. 1.2%; HR (95% CI): 1.71 (0.99 to 2.97) | Consistency-NA (single study) Imprecise | Not detected | Low | 1 Good | Single trial, relatively rare event with wide CIs | Asymptomatic patients with a low ABI defined as ≤0.95 with intermediate CVD risk
KQ5: Treatment harms | Aspirin k=2 (1 new), n=4,626 | Hemorrhagic CVA | k=2, n=4,626 | Trend of higher risk for total hemorrhagic CVA with aspirin in AAA (0.3% v 0.2%; RR 1.25 (95% CI, 0.34 to 4.65) and a lower risk for fatal hemorrhagic CVA in POPADAD (0.3% vs. 0.5%; RR 0.67 [95% CI, 0.11 to 3.98]) but CIs were wide due to rare events | Inconsistent, Imprecise | Not detected | Low/insufficient | 2 Good | Somewhat conflicting results when comparing total and fatal hemorrhagic across 2 trials which recruited different populations (diabetic and nondiabetic trials) | Asymptomatic patients with a low ABI defined as ≤0.95 with intermediate CVD risk
| Exercise | - | No trials reporting harms | - | - | - | No evidence | - | - | -

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; ACM = all-cause mortality; Adj = adjusted; CG = control group; CI = confidence interval; CVA = cerebrovascular accident; CVD = cardiovascular disease; EPC = Evidence-based Practice Center; GI = gastrointestinal; HR = hazard ratio; IG = intervention group; KQ = key question; MI = myocardial infarction; NA = not applicable; NPV: negative predictive value; NR = not reported; PPV = positive predictive value; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk

## Targeting High-Prevalence Subpopulations

Overall, the evidence base addressing screening for PAD in either general or high-risk asymptomatic populations remains scant. While universal screening in primary care populations is inefficient,^119^ there is much interest in targeted screening in subpopulations with higher PAD prevalence, such as older adults and patients with diabetes, hypertension, hyperlipidemia, and increased global CVD risk.^120^ Screening guidance provided by several professional organizations targets these subpopulations (Table 1).^56,^ ^65^ In particular, older age, diabetes, and cigarette smoking have been highlighted as risk factors associated with the highest risk for PAD in high-income countries.^15^ Several groups have derived models to predict prevalent PAD from population-based cohorts, and some have externally validated these models in non-U.S. populations, demonstrating reasonable sensitivity but low specificity (e.g., sensitivity 85%, specificity 47%);^37,^ ^45,^ ^120,^ ^121^ there remains an inadequate evidence base to apply any models in U.S. clinical practice.

The argument in favor of screening follows a logic that these high-prevalence populations can be easily identified based on established risk factors for PAD; that the ABI is relatively accurate based on studies in symptomatic patients; and that cardiovascular risk-factor modification is appropriate because CVD morbidity and mortality are high in adults with PAD regardless of symptoms.^56^ Conversely, even when higher-prevalence populations are identified for screening, the missing link in the indirect evidence chain remains the effectiveness of screening in identifying individuals who are not already candidates for pharmacologic and exercise treatment based on their global CVD risk.^122^ While there is a robust evidence base supporting treatment benefit in patients with intermittent claudication (exercise, statins, and cilostazol improve walking performance measures; antiplatelet agents reduce revascularization and cardiovascular and all-cause mortality),^123-127^ some treatments will be recommended regardless of the ABI (exercise, statins, antiplatelet drugs) based on global CVD risk, while other treatments are only for symptomatic PAD (cilostazol).

Diabetes is a classic example of a disease where early detection is particularly desirable to halt lower-extremity disease progression because PAD outcomes (amputation and mortality) are substantially worse.^128^ However, screening considerations in individuals with diabetes have added complexity as an abnormal ABI (both low and high ABI) is quite prevalent;^19,^ ^50,^ ^129-131^ the presence of peripheral neuropathy confounds both clinical presentation and ABI accuracy;^76,^ ^132^ and most importantly, medical management of CVD risk with tight blood-pressure control, aspirin, statins, and exercise recommendations along with routine foot examination has become the standard of diabetes clinical practice guidelines.^133^ It is unclear how screening for PAD would change clinical management in persons with diabetes. This logic holds for other PAD risk factors as well: since the risk factors for PAD (one manifestation of atherosclerotic disease) overlap with the major risk factors for global CVD risk,^71^ it is not clear how detection of PAD would alter medical decisionmaking.^73^

## Lower-Extremity Treatment Benefit in Screen-Detected Populations

On one hand, expecting unselected, generally asymptomatic populations to achieve improvements in PAD-related morbidity seems unreasonable; on the other hand, if patients unaware of symptoms because of limited activity underwent treatment, there could be potential to improve overall function, ability to ambulate, and quality of life. Supporting this theory is evidence that patients with a low ABI have worse lower-extremity function and quality of life than those with intermittent claudication, positing that perhaps those with asymptomatic PAD reduce their walking to avoid symptoms with subsequent development of muscle wasting and questioning the traditional thinking that presence of symptoms or their severity directly correlates to atherosclerotic occlusive disease severity.^134^ Several observational studies of screen-detected or asymptomatic populations demonstrated that those with a low ABI have statistically significantly worse subjective and objective measures of function (6-minute walk distance, 4-meter walking velocity, 400-meter walk time, SF-36 physical functioning subscale scores, WIQ distance and speed scores) compared with those with a normal ABI.^134-139^ Two notable exercise-based intervention trials in patients with PAD or a low ABI have shown improved lower-extremity functional outcomes.^140,^ ^141^ The GOALS trial demonstrated that a home-based walking program incorporating a group-mediated cognitive behavioral intervention was associated with statistically significant improvements in 6-minute walk, WIQ distance, and speed scores at 6 months, and short physical performance battery and mobility loss at 12 months.^140,^ ^142,^ ^143^ Another trial of supervised treadmill exercise and lower-extremity resistance training with similar recruitment to the GOALS trial showed improved 6-minute walk and QOL at 6 months.^141^ Both of these trials were not included in our systematic review because although the recruitment approach solicited community as well as clinical referrals with a minority of patients with classic intermittent claudication, the baseline ABIs and WIQ distance and speed scores reflect a more severe functional impairment and disease severity than would be expected in an unselected primary care population. Replication of these findings in screened populations is needed.

## Use of the ABI to Improve CVD Risk Prediction and Subsequent Medical Management

Aside from lower-extremity function improvement as a potential benefit from early identification of PAD, a common argument in support of early case-finding is that the detection of PAD signals the presence of widespread atherosclerotic disease, where its detection may lead to CVD risk reclassification and intensive medical management.^38^ In this case, the sensitivity and specificity of the ABI in detecting PAD is not relevant as the ABI would be used as a nontraditional CVD risk marker. This critically important question is addressed in a concurrent systematic review evaluating whether the addition of the ABI and other nontraditional risk factors to traditional cardiovascular risk assessment could improve risk prediction in terms of calibration, discrimination, and risk reclassification.^74^ This systematic review identified a large body of evidence from 21 unique cohorts, including one IPD meta-analysis of 18 cohorts for the ABI as a nontraditional risk factor.^144^ The extension of the Framingham risk prediction model to include the ABI in the IPD MA was performed in a development/internal validation data set of over 27,000 participants and evaluated in an external validation dataset of over 20,000 participants.

Collectively, evidence suggests that the addition of the ABI to traditional risk factors can improve risk prediction in some subpopulations. Results are more robust for discrimination and reclassification (as opposed to calibration), and point to a larger improvement in predictive accuracy for women, particularly those at intermediate risk. The ability of the ABI to improve risk prediction is particularly notable when the performance of traditional cardiovascular risk prediction models is poor (for example, in women) or when clinical action is uncertain (e.g., intermediate risk individuals). While the ABI added to traditional cardiovascular risk assessment may improve predictive accuracy in some subpopulations, the clinical impact of such changes is unknown, limiting application to clinical practice.

## Limitations of the Review

Our review captured a single trial of ABI accuracy because this was the only accuracy trial in which the ABI was used in an unselected population applicable for screening. Trials using convenience samples from vascular labs were excluded as they would represent an enriched sample and such studies are subject to spectrum bias when applying them to screening populations.^87-91^ We recognize that there is much broader and higher-quality literature reporting ABI accuracy, with sensitivities and specificities ranging from 17 to 100 percent and 80 to 100 percent.^56,^ ^63^ We also recognize that in clinical practice, an abnormal ABI is often considered diagnostic of PAD, and that duplex, CTA, MRA, and DSA are used for localization of stenoses for the purpose of surgical intervention rather than for confirmation of PAD. The scope of this review did not include diagnostic accuracy of other screening methods or modalities such as automated oscillometric ABI measurement methods,^145,^ ^146^ the postexercise ABI (which may be relevant in clinically “asymptomatic” populations that self-limit exertion), and the toe-brachial index.

For treatment trials, our review’s requirement that the treated population could be considered an unselected population with population-based or primary care recruitment could be considered unnecessarily limiting. However, in order to develop an indirect chain of evidence in support of screening, it is critical that treatment trials are applicable to a population that reflects the screen-detected population in terms of disease severity and treatment effectiveness. The prespecified hard health outcomes abstracted in this review include CVD and PAD morbidity or mortality or quality of life with the exclusion of intermediate outcomes (behavior changes, intermediate measures of lower limb function [6-minute walk test or lower-extremity strength], the ABI, or intermediate cardiovascular risk factors). We did exclude a 12-month study of 355 adults with PAD or a low ABI that evaluated a telephone counseling intervention designed to motivate patients to request more intensive cholesterol-lowering therapy from their physician.^147^ This study found that LDL-cholesterol reduction was not statistically significantly greater in the intervention compared with the usual care group (mean between-group difference of 5.1 mg/dL (95% CI, -2.9 to 13.1]). No studies of asymptomatic populations were excluded on the basis of reporting the 6-minute walk but not CVD or PAD morbidity and mortality. The included treatment trials reporting QOL most commonly used the SF-36, and none of the included studies used the Vasculo-QOL questionnaire, which is better able to discriminate between severe and mild disease at baseline and between large and small change in disease severity after followup;^148^ this reflects a limitation in the literature rather than in the review approach.^148^

## Population-Based Multicomponent Screening Trials

There are three population-based screening trials that examine the effectiveness of the combination of multiple vascular screening tests on all-cause mortality and/or cardiovascular morbidity and mortality at 10 to 15 years of followup; one trial has reported results and two are in progress. The Viborg Vascular (VIVA) screening trial enrolled 50,156 men ages 65 to 74 years from 2008—2011.^109^ Participants were randomized to screening versus no screening for hypertension, PAD, and abdominal aortic aneurysm (AAA). After screening, VIVA participants who had confirmed AAA or PAD were counseled on the need to initiate preventive interventions including walking, smoking cessation, a low-fat diet, and cholesterol testing, with aspirin and statin therapy prescribed to those meeting a total cholesterol threshold value. An interim analysis at median 4.4 years of followup reported a 0.006 (95% CI, 0.001 to 0.011) absolute decrease in all-cause mortality (hazard ratio, 0.93 [95% CI, 0.88 to 0.98]) in the screened group and a reduction in PAD-specific hospital days (HR 0.81 [95% CI, 0.76-0.87]). Based on post-hoc sensitivity analyses removing smokers or those initiating hypertensive therapy, which did not alter the results, authors hypothesize that the benefit was largely seen from preventive measures including statin and aspirin use. Applicability of such findings in the context of current treatment thresholds for pharmacotherapy based on global CVD risk^149-151^ is uncertain as nearly all participants would have ≥10% 10-year CVD risk based on age and male sex alone,^152^ thus would already be candidates for consideration of statins or aspirin. Secondary analyses including cost-effectiveness analyses to isolate the effect of ABI screening are planned, but these analyses would be considered exploratory; it is unlikely that such analyses would definitively demonstrate ABI screening effectiveness given the aforementioned considerations. The second trial, the Danish Cardiovascular Screening Trial (DANCAVAS), has an estimated enrollment of 45,000 men ages 65 to 74 years who are randomized to no screening or screening including the following components: brachial and ankle blood-pressure index to detect PAD and hypertension, low-dose CT scan to detect coronary artery calcification and aortic/iliac aneurysms, telemetric assessment of heart rhythm, and measurement of cholesterol and plasma glucose levels.^107^ The primary outcome of this study is overall mortality. Enrollment began in October 2014 and 10 years of followup is planned. An interim publication is planned for mid-2018.^153^ The third trial, the ILERVAS project in Spain, is currently enrolling adults ages 45 to 70 years with at least one cardiovascular risk factor, recruited from primary health care centers; the planned N is 19,800.^108^ The intervention group will receive multicomponent screening for subclinical arterial disease (including ABI assessment) and chronic kidney disease. Ten years of followup for cardiovascular disease is planned.

## Future Research Needs

Given the paucity of included studies and the high prevalence of undetected PAD—particularly in high-risk populations—there is opportunity for future research to clarify the role of PAD screening in primary care. First, a population-based screening trial of ABI screening versus no screening with robust subpopulation analyses ideally would answer this question definitively. The VIVA trial, as well as two ongoing trials,^107,^ ^108^ include the ABI in addition to other vascular screening tests, so it will not be possible to estimate the independent effect of the ABI. Nonetheless, population-based trials of screening ABI alone compared with no screening would represent the highest-quality evidence examining the effectiveness of screening. In the absence of direct evidence, additional studies of ABI accuracy against a duplex ultrasound gold standard in unselected populations would be useful to estimate accuracy in a population with a spectrum of disease reflective of a screened population. Exercise and statin trials specifically recruiting screen-detected populations may support screening, and inclusion of populations at clinically accepted diagnostic thresholds (i.e., <0.9) would enhance the applicability of evidence. If treatment effectiveness has been established in this population, then validated risk models would be useful to identify individuals for targeted screening in primary care.

## Conclusion

The current evidence base is limited, with no direct evidence examining the effectiveness of ABI screening alone for PAD. Indirect evidence is scant and includes a single ABI accuracy study in an unselected population showing poor sensitivity; two aspirin trials in screen-detected populations (with and without diabetes) with a low ABI defined as ≤0.95 or ≤0.99 show no benefit for primary composite cardiovascular outcomes. Two underpowered exercise trials in screen-detected, atypical, or asymptomatic populations show no statistically significant effect on hard health outcomes.