# 3 Results

## Description of Included Studies

Our literature search yielded 4,194 unique citations. From these, we provisionally accepted 105 articles for review based on titles and abstracts (Appendix A Figure 1). After reviewing the full-text articles and performing quality rating, we included five trials that were reported in six publications.^98,^ ^102-106^ Appendix B contains a full list of included studies. We carried forward two trials (reported in three articles)^102-104^ from the previous review^75^ and added three trials.^98,^ ^105,^ ^106^ A comparison of trials included in this systematic review and previous USPSTF evidence reviews is provided in Table 2.

Table 2 Comparison Of Studies Included In Previous And Present USPSTF Reviews

USPSTF Recommendation | | USPSTF Reviews and Recommendations
USPSTF Recommendation | | D^*^ for routine screening | D^*^ for routine screening | I^†^ for screening and risk assessment with the ABI
KQ | Study | 1996^158^ | 2005^159^ | 2012^75^ | Current
KQ1 Morbidity | Fowler 2002^106^ | | ×
KQ2 Diagnostic Accuracy | Wikstrom 2009^104^ | | | × | ×
KQ2 Diagnostic Accuracy | Wikstrom 2008^103^ | | | × | ×
KQ2 Diagnostic Accuracy | Vogt 1993^160^ | ×
KQ2 Diagnostic Accuracy | Moneta 1987^161^ | ×
KQ2 Diagnostic Accuracy | Strandness 1987^162^ | ×
KQ2 Diagnostic Accuracy | Criqui 1985^163^ | ×
KQ2 Diagnostic Accuracy | Barnes 1979^164^ | ×
KQ3 Screening Harms | Wikstrom 2009^104^ | | | | ×
KQ3 Screening Harms | Wikstrom 2008^103^ | | | | ×
Risk Prediction^*^ | Hoorn 2012^165^ | | | ×
Risk Prediction^*^ | Kavousi 2012^166^ | | | ×
Risk Prediction^*^ | Murphy 2012^167^ | | | ×
Risk Prediction^*^ | Yeboah 2012^168^ | | | ×
Risk Prediction^*^ | Rodondi 2010^169^ | | | ×
Risk Prediction^*^ | Fowkes 2008^38^ | | | ×
Risk Prediction^*^ | Sutton-Tyrrell 2008^170^ | | | ×
Risk Prediction^*^ | Price 2007^171^ | | | ×
Risk Prediction^*^ | Weatherley 2007^172^ | | | ×
Risk Prediction^*^ | O'Hare 2006^20^ | | | ×
Risk Prediction^*^ | Lee 2004^173^ | | | ×
Risk Prediction^*^ | Van der Meer 2004^174^ | | | ×
Risk Prediction^*^ | Abbott 2001^175^ | | | ×
Risk Prediction^*^ | Abbott 2000^176^ | | | ×
Risk Prediction^*^ | Tsai 2001^177^ | | | ×
Risk Prediction^*^ | Vogt 1993^160^ | ×
KQ4 Treatment Benefit | McDermott 2011^147^ | | | ×
KQ4 Treatment Benefit | Fowkes 2010^102^ | | | × | ×
KQ4 Treatment Benefit | Belch 2008^98^ | | | | ×
KQ4 Treatment Benefit | Collins 2007^105^ | | | | ×
KQ4 Treatment Benefit | McDermott 2003^114^ | | ×
KQ4 Treatment Benefit | Fowler 2002^106^ | | | | ×
KQ4 Treatment Benefit | Tornwall 1997^178^ | | ×
KQ5 Treatment Harms | Fowkes 2010^102^ | | | × | ×
KQ5 Treatment Harms | Belch 2008^98^ | | | | ×

* A D Recommendation is defined as: “The USPSTF recommends against the service. There is moderate or high certainty that the service has no net benefit or that the harms outweigh the benefits.”

† An I Statement is defined as: “The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of the service. Evidence is lacking, of poor quality, or conflicting, and the balance of benefits and harms cannot be determined.”

Abbreviations: ABI = ankle-brachial index; KQ = key question; USPSTF = United States Preventive Service Task Force

For the 105 articles that we reviewed in full, the most common reasons for exclusion were aim (i.e., not a study of screening or treatment for PAD), population (e.g., inclusion of symptomatic patients), absence of a reference standard (for accuracy studies), and absence of relevant health outcomes. Appendix C contains a list of all excluded trials and their reasons for exclusion.

## KQ1 Is Screening for PAD in Generally Asymptomatic Adults With the ABI Effective in Reducing CVD or PAD Morbidity or Mortality? KQ1a. Does the Effectiveness of Screening for PAD Vary by Subpopulations at Greater Risk for PAD?

No population-based randomized trials of PAD screening were identified that reported results for ABI screening alone. There are two in-progress multicomponent screening trials, one in Denmark and one in Spain, that include PAD screening as part of a combined vascular screening program.^107,^ ^108^ None of these trials tests the independent effectiveness of ABI screening. See the Discussion section for results of the Viborg Vascular (VIVA) multicomponent screening trial.^109^

## KQ2 What Is the Diagnostic Accuracy of the ABI as a Screening Test for PAD in Generally Asymptomatic Adults? KQ2a. Does the Diagnostic Accuracy of Screening With the ABI Vary by Subpopulations at Greater Risk for PAD?

### Summary of Results

A single diagnostic accuracy study^103,^ ^104^ in a screen-detected older population of adults (N=306) showed that the ABI has low sensitivity (7-34%) and high specificity (95-100%) characteristics compared with MRA gold standard imaging. Overall, these data are limited but suggest that the ABI may not be a sufficiently sensitive screening test to detect PAD in unselected populations.

### Study Characteristics

No new trials of diagnostic accuracy in screen-detected or generally asymptomatic populations were identified. In the last review,^75^ we identified one fair-quality Swedish diagnostic accuracy study (N=306) examining the accuracy of the ABI for the diagnosis of MRA-confirmed PAD.^103,^ ^104^ This study reported the sensitivity, specificity, and negative and positive predictive values of the ABI.

### Population Characteristics

The study recruited older adults age 70 years at study entry from a random subset of the population-based Prospective Investigation of the Vasculature in Uppsala Seniors (PIVUS) cohort study (n=1,016) (Table 3).^110^ Nearly half (47.4%) were women, and all were white. A small number of participants had a history of CVD (6.9% with history of MI and 3.9% with history of CVA), and 10.6 percent had diabetes. One-third of participants were taking antihypertensive medications, and 7.8 percent were current smokers. Prevalence of PAD symptoms (intermittent claudication or atypical leg pain) was not reported.

Table 3 Study And Participant Characteristics For KQ2: What Is The Diagnostic Accuracy Of The ABI As A Screening Test For PAD In Generally Asymptomatic Adults?

Study name Author, Year | Quality | Country | N Analyzed | Recruitment setting and method | ABI cutoff | Reference standard | Mean age, years | % Women | % White | % Risk factor
PIVUS Wikstrom, 2008^103^ Wikstrom, 2009^104^ | Fair | Sweden | 306 (analyzed as 268^*^ right and 265^*^ left limbs) | Community; Population-based | <0.9 | MRA | 70 | 47.4 | 100^†^ | Current smoker: 7.8 Hx MI: 6.9 Hx CVA: 3.9 HTN meds: 33 Hx DM: 10.6

* Number for whom ABI recordings and assessable MRA examinations were obtained

† Assumed

Abbreviations: ABI = ankle-brachial index; DM = diabetes mellitus; HTN meds = anti-hypertensive medications; Hx = history; KQ = key question; MI = myocardial infarction; MRA = magnetic resonance angiography; N = sample size; PAD = peripheral artery disease; PIVUS = Prospective Investigation of the Vasculature in Uppsala Seniors

### Intervention Details

#### ABI

All measurements were performed in the supine position after 30 minutes of rest. Brachial artery systolic measurements were made with a manual sphygmomanometer using an average of three recordings. Posterior tibial artery systolic blood pressure was measured bilaterally using Doppler. The ABI was calculated for each leg by dividing the posterior tibial artery systolic pressure by the brachial artery systolic pressure. The threshold for a low ABI was <0.9.

#### MRA

The gold standard was whole-body MRA. This test was performed on all subjects in four anatomic locations: supra-aortic arteries and thoracic aorta, abdominal aorta, external iliac arteries continuing to the popliteal arteries, and below the ankle. Gadodiamide contrast was used, and scan time for each of the four stations was 17 s. The threshold for PAD diagnosis was ≥50% stenosis on MRA.

The mean interval between the ABI test and MRA was 16 months (range 3-24 months). Authors did not report whether the personnel performing the MRA were blinded to ABI results.

### Study Quality

This publication is a substudy of a population-based screening study of 70-year-old Swedish men and women; therefore, results reflect screening accuracy in older adults who have a higher PAD prevalence. Time lag between the ABI and MRA could have resulted in a lower ABI sensitivity, but it is unlikely that substantial interim development of atherosclerotic lesions would occur; reported sensitivity analyses by time lag showed similar sensitivity and specificity results. Lack of reporting on blinding of MRA technicians to ABI results is a study limitation.

### Results

In this study, ABI recordings and interpretable MRAs were obtained in 268 right limbs and 265 left limbs from the 306 participants. The prevalence of an ABI <0.9 was 4.5 percent in the right leg and 4.2 percent in the left leg (Table 4). The prevalence of MRA-confirmed PAD defined as 50 percent or greater stenosis was 19.0 and 23.0 percent in the right and left legs, respectively. One-hundred percent stenosis was detected by MRA in 12.7 and 14.0 percent of right and left legs, respectively.

Table 4 Results For KQ2: What Is The Diagnostic Accuracy Of The ABI As A Screening Test For PAD In Generally Asymptomatic Adults?

Study name Author, Year | % with ABI <0.9 | % Stenosis on MRA | % Sensitivity/Specificity (95% CI) | % PPV/NPV (95% CI) | FPR/FNR (95% CI)
PIVUS Wikstrom, 2008^103^ Wikstrom, 2009^104^ | Right leg 12/268=4.5% Left leg 11/265=4.2% | ≥ 50% stenosis Right leg 51/268 =19.0% Left leg 61/265= 23.0% | Right leg Sensitivity: 20 (10 to 34) Specificity: 99 (96 to 100) Left leg Sensitivity: 15 (7 to 27) Specificity: 99 (96 to 100) | Right leg PPV: 83 (51 to 97) NPV: 84 (79 to 88) Left leg PPV: 82 (48 to 97) NPV: 80 (74 to 84) | Right leg FPR: 0.9% (0.0% to 3.5%) FNR: 80.4% (67.4% to 89.2%) Left leg FPR: 1.0% (0.0% to 3.7%) FNR: 85.2% (74.0% to 92.3%)
PIVUS Wikstrom, 2008^103^ Wikstrom, 2009^104^ | Right leg 12/268=4.5% Left leg 11/265=4.2% | 100% stenosis Right leg 34/268 =12.7% Left leg 37/265=14.0% | Right leg Sensitivity: 24 (11 to 42) Specificity: 98 (95 to 99) Left leg Sensitivity: 16 (7 to 33) Specificity: 98 (95 to 99) | Right leg PPV: 67 (35 to 89) NPV: 90 (85 to 93) Left leg PPV: 55 (25 to 82) NPV: 88 (83 to 91) | Not calculated

Abbreviations: ABI = ankle-brachial index; CI = confidence interval; FNR = false negative rate; FPR= false positive rate; KQ = key question; MRA = magnetic resonance angiography; NPV = negative predictive value; PAD = peripheral artery disease; PIVUS = Prospective Investigation of the Vasculature in Uppsala Seniors; PPV = positive predictive value

Based on gold standard MRA-detected stenosis of 50 percent or greater, 20 percent (95% CI, 10 to 34%) and 15 percent (95% CI, 7 to 27%) sensitivity was reported in the right and left legs, respectively. Specificity was 99 percent (95% CI, 96 to 100%) in both limbs. PPV was 83 percent (95% CI, 51 to 97%) and 82 percent (95% CI, 48 to 97%) in the right and left legs, respectively. NPV was 84 percent (95% CI, 79 to 88%) and 80 percent (95% CI, 74 to 84%) in the right and left legs, respectively.

There were no subgroup analyses to examine whether the accuracy results vary by subpopulation.

## KQ3 What Are the Harms of Screening for PAD With the ABI? KQ3a. Do the Harms of Screening for PAD Vary by Subpopulations at Greater Risk for PAD?

### Summary of Results

The included diagnostic accuracy study reported a high false-negative rate (>80%), reflecting the low sensitivity of ABI in screening for PAD. This single study suggests that screening ABI misses a large proportion of patients with PAD. No other studies addressing screening harms (e.g., anxiety, further diagnostic testing) were identified.

### Results

The aforementioned diagnostic accuracy study provided data for the calculation of false positive and false negative rates (Table 4). The false positive rate is 0.9 percent (95% CI, 0.0% to 3.5%) and 1.0 percent (0.0% to 3.7%), and the false negative rate is 80.4 percent (67.4% to 89.2%) and 85.2 percent (74.0% to 92.3%) in the right and left legs, respectively. A single participant had a vasovagal attack prior to contrast injection for MRA and was excluded from the study but this adverse event was not due to the ABI. No other harms were reported in this trial and no additional trials were identified examining the harms of screening for PAD with the ABI.

## KQ4 Does Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI Lead to Improved Patient Health Outcomes? KQ4a. Does the Effectiveness of Treatment Vary by Subpopulations at Greater Risk for PAD?

### Summary of Results

We included two trials of aspirin, one new^98^ and one from the previous review.^102^ The newly included trial exclusively recruited participants with diabetes, thus was not eligible for inclusion in the previous review excluding this population. These two trials powered for composite outcomes in asymptomatic populations with a low ABI with and without diabetes showed no statistically significant effect of aspirin for those composite CVD outcomes or individual CVD outcomes compared with placebo control after 6 to 8 years of followup. There is no compelling evidence to support a differential treatment effect by age, sex, or diabetes status.

Two new trials of exercise therapy were included;^105,^ ^106^ supervised exercise and physical therapy were an excluded intervention type in the previous review, although exercise interventions were allowed if their primary aim was to reduce CVD risk or treat CVD risk factors. These exercise trials in participants with a low ABI showed no statistically significant differences in their primary outcomes of walking distance or secondary outcomes of quality of life or self-reported symptoms (intermittent claudication or atypical). One trial was an underpowered 12-week RCT of veterans with atypical or no symptoms; the other was an adequately powered 52-week RCT that recruited participants from an Australian population-based screening trial. Overall, there is inadequate evidence to assess whether exercise interventions improve health outcomes in screendetected populations with a low ABI.

### Aspirin Trials

#### Study Characteristics

We identified two good-quality Scottish trials (N=4,626) examining the effectiveness of aspirin in populations with a low ABI.^98,^ ^102^ The Aspirin for Asymptomatic Atherosclerosis (AAA) trial^102^ (N=3,350) was a placebo-controlled randomized trial, and the Prevention of Progression of Arterial Disease and Diabetes (POPADAD) trial^98^ (N=1,276) was a factorial-designed RCT of aspirin and antioxidants (Table 5). Primary outcomes were composite cardiovascular endpoints. Both trials included fatal and nonfatal MI and CVA in this composite; in addition, the AAA trial included revascularization in the composite, while POPADAD included above-the-ankle amputation for critical limb ischemia in its composite. A second primary endpoint in POPADAD was CVD mortality (due to MI or CVA). Other reported outcomes included fatal and nonfatal MI and CVA, angina, intermittent claudication, TIA, and all-cause mortality. Mean followup was 8.2 years in AAA, which was terminated early due to futility, and median followup was 6.7 years in POPADAD.

Table 5 Methodological And Intervention Characteristics For Included Aspirin Studies For KQ4: Does Treatment Of Screen-Detected Or Generally Asymptomatic Adults With PAD Or An Abnormal ABI Lead To Improved Patient Health Outcomes?

Trial name Author, Year | N | Study design | Inclusion | Recruitment | ASA dose & formulation | ASA duration & mean followup | Primary endpoint | Secondary endpoints | Adherence & crossover
AAA Fowkes, 2010^102^ | 3,350 | RCT | Men and women ages 50-75 years with no history of vascular disease and an ABI <0.95 | Community health registry and community volunteer | 100 mg daily, tablet, enteric coated | 8.2 years^*^ | Composite outcome: initial fatal or nonfatal coronary event or CVA or revascularization | 1) All initial vascular events, defined as a composite outcome: primary end point event or angina, intermittent claudication, or TIA; 2) all-cause mortality | Participants adhered to study medication for 60% of p-y of F/U. Effect on primary end point did not differ between those taking and not taking medication at 5 years
POPADAD Belch, 2008^98^ | 1,276 | 2x2 RCT, Antioxidant | Men and women age ≥40 years with diabetes, no symptomatic CVD, and an ABI ≤0.99 | Diabetes clinics | 100 mg daily, tablet, not enteric coated | 6.7 years^†^ | 2 composite end points: 1) death from CHD or CVA, nonfatal MI or CVA, above ankle amputation for critical limb ischemia; 2) death from CHD or CVA | All-cause mortality; nonfatal MI; and occurrence of other individual vascular events | At 1 year, 14% of participants stopped taking trial drugs; at 5 years, 50% (cumulative) of patients withdrew from trial therapy

* Terminated early

† Median

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle-brachial index; ASA = aspirin; CHD = coronary heart disease; CVA = cerebrovascular accident; F/U = followup; MI = myocardial infarction; N = number; PAD = peripheral arterial disease; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RCT = randomized controlled trial; p-y = patient years; TIA = transient ischemic attack

#### Population Characteristics

The AAA trial recruited men and women ages 50 to 75 years with an ABI ≤0.95 and no history of vascular disease; those recruited were from a community health registry and community volunteers. The POPADAD trial recruited men and women ages ≥40 years with an ABI ≤0.99, diabetes, and no symptomatic CVD from diabetes clinics. Mean age was 62.0 and 60.3 years in the two trials. Approximately half (55.9%) and nearly three-quarters (71.5%) of participants were female in the POPADAD and AAA trials, respectively. All participants had diabetes in the POPADAD trial and 2.6 percent had diabetes in the AAA trial. The mean ABI was 0.86 in AAA and the median ABI was 0.90 in POPADAD. Nearly one-third were current smokers in both trials. Mean HgbA1c was 8.0 in the POPADAD trial. Calculated annual CVD events in the control groups were 0.99 and 2.53 percent in the AAA and POPADAD trials, respectively, indicating that POPADAD participants had higher baseline CVD risk. All participants were asymptomatic in terms of PAD in both trials. Statin use was reported in AAA to be 4.2 percent at baseline and 25 percent at 5 years of followup. Cholesterol and blood pressure values in each trial are reported in Table 6.

Table 6 Participant Characteristics For Included Aspirin Studies For KQ4: Does Treatment Of Screen-Detected Or Generally Asymptomatic Adults With PAD Or An Abnormal ABI Lead To Improved Patient Health Outcomes?^**^

Trial name Author, Year | Quality | Country | N | Age, years (mean) | % Female | SBP/DBP, mm Hg (mean)^*^ | TC, mg/dL (mean) | LDL, mg/dL | HDL, mg/dL | % with DM^†^ | % with Low ABI | % Asymptomatic | ABI (mean) | % Current smokers | Annual risk of CVD events (%)^‡^
AAA Fowkes, 2010^102^ | Good | Scotland | 3,350 | 62.0 | 71.5 | 148/84 | 238^§^ | NR | NR | 2.6 | 100.00 with an ABI ≤0.95ǁ | 100.0 | 0.86 | 33.0 | 0.99
POPADAD Belch, 2008^98^ | Good | Scotland | 1,276 | 60.3 | 55.9 | 145/79 | 213.3 | 120^¶^ | 47^¶^ | 100.0 | 100.0 with an ABI ≤0.99^#^ | 100.0 | 0.90ǁ | 31.1 | 2.53

* Percent with hypertension not reported in either trial. In AAA, 15.2% were treated with a diuretic, 6.4% were treated with a nitrate or calcium channel blocker, 6.2% were treated with an angiotensin-converting enzyme inhibitor or angiotensin II receptor blocker, and 9.8% were treated with a beta blocker. Hypertension treatment was not reported in POPADAD.

† Mean fasting plasma glucose not reported; mean HbAlc was 8.0% in POPADAD and was not reported in AAA

‡ Data are from Berger 2011 meta-analysis;^179^ calculated as percent with cardiovascular events in control group/years followup

§ 4.2% were on lipid-lowering treatment at baseline and 25% were treated at 5 years; use of lipid-lowing treatment was not reported in POPADAD.

ǁ Referred to as low ABI (not PAD)

¶ Median

# Referred to as asymptomatic PAD

** Mean CVD risk score was not reported in either trial; no participants in either trial had prior CVD. Median body mass index in POPADAD was 29.2 and was not reported in AAA.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle-brachial index; CVD = cardiovascular disease; DBP = diastolic blood pressure; HbAlc = glycated hemoglobin; HDL = high-density lipoprotein cholesterol; LDL = low-density lipoprotein cholesterol; N = number; NR = not reported; PAD = peripheral arterial disease; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; SBP = systolic blood pressure; TC = total cholesterol

#### Intervention Details

The intervention group in both trials received 100 mg daily of enteric (AAA) or nonenteric (POPADAD) coated aspirin orally. The control group in the AAA trial was placebo, and the 2x2 factorial-designed POPADAD trial also included an antioxidant tablet. The intervention groups received aspirin plus placebo or antioxidant plus placebo, compared with the control group which received two placebo tablets. Authors reported no evidence of an interaction between aspirin and antioxidants, so results below are presented for the group taking aspirin (intervention group) compared with the group not taking aspirin (control group).

#### Study Quality

Both trials had robust reporting, baseline comparability, adjustment for confounders, and outcome ascertainment using multiple data sources (clinic, hospital records, NHS records, death records, patient diary; outcomes adjudication committees). Additionally, both AAA and POPADAD used intent-to-treat (ITT) analyses and had minimal loss to followup (0.3% and 0.5%, respectively). AAA reported that adherence was 60 percent of patient years of followup and that the primary end point did not differ in those taking and not taking the medication at 5 years of followup. POPADAD reported that 14 percent of participants stopped taking trial drugs at 1 year and cumulatively 50 percent of participants withdrew from trial therapy at 5 years of followup.

Both AAA and POPADAD were powered for composite CVD outcomes. This was true despite the fact that the AAA event rate was 60 percent lower than expected, which was reflective of a national reduction in CVD events during the trial period.

#### Results

Both trials reported no difference between the aspirin and control groups in trial-defined composite cardiovascular outcomes. In the AAA trial, the adjusted hazard ratio (HR) was 1.00 (95% CI, 0.81 to 1.23) for the primary composite outcome of initial fatal or nonfatal coronary event, CVA, or revascularization. Similarly, in the POPADAD trial the HR was 0.98 (95% CI, 0.76 to 1.26) for the primary composite outcome of death from CHD or CVA, nonfatal MI or CVA, and above-the-ankle amputation for critical leg ischemia. There was no statistically significant difference in fatal CVD events [RR 1.17 (95% CI, 0.72 to 1.89) and HR 1.23 (95% CI, 0.79 to 1.93)] or all-cause mortality [HR 0.95 (95% CI, 0.77 to 1.16) and HR 0.93 (95% CI, 0.71 to 1.24)] (Table 7). Examining individual CVD outcomes (e.g., MI, CVA) likewise showed no statistically significant difference between the aspirin and control groups (Table 8). The development of intermittent claudication and need for peripheral arterial revascularization or above-the-ankle amputation procedures were similar between the aspirin and control groups (Table 9).

Table 7 Composite And Mortality Outcomes For Included Aspirin Studies For KQ4: Does Treatment Of Screen-Detected Or Generally Asymptomatic Adults With PAD Or An Abnormal ABI Lead To Improved Patient Health Outcomes?

Outcome | Trial name Author, Year | Mean F/U, years | IG N Analyzed | IG N Events (%) | CG N Analyzed | CG N Events (%) | IG vs. CG HR (95% CI)
Primary Composite CVD Outcome^*^ | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 181 (10.8%) | 1,675 | 176 (10.5%) | 1.00 (0.81 to 1.23)^†^
Primary Composite CVD Outcome^*^ | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 116 (18.2%) | 638 | 117 (18.3%) | 0.98 (0.76 to 1.26)
Composite Fatal Coronary Events + CVA + CVD Death | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 35 (2.1%)^§^ | 1,675 | 30 (1.8%)^§^ | 1.17 (0.72 to 1.89)^§^ǁ
Composite Fatal Coronary Events + CVA + CVD Death | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 43 (6.7%) | 638 | 35 (5.5%) | 1.23 (0.79 to 1.93)
Composite Nonfatal MI + CVA | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 99 (5.9%)^§^ | 1,675 | 106 (6.3%)^§^ | 0.93 (0.72 to 1.22)^§^ǁ
Composite Nonfatal MI + CVA | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 84 (13.2%)^§^ | 638 | 97 (15.2%)^§^ | 0.87 (0.66 to 1.14)^§^ǁ
All-Cause Mortality | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 176 (10.5%) | 1,675 | 186 (11.1%) | 0.95 (0.77 to 1.16)
All-Cause Mortality | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 94 (14.7%) | 638 | 101 (15.8%) | 0.93 (0.71 to 1.24)

* Defined in AAA as: initial fatal or nonfatal coronary event or CVA or revascularization; defined in POPADAD as death from CHD or CVA, nonfatal MI or CVA, above ankle amputation for critical limb ischemia

† HR adjusted for baseline age, ankle-brachial index, cholesterol, systolic blood pressure, smoking, and socioeconomic status; unadjusted HR 1.03 (95% CI, 0.84 to 1.27)

‡ Median

§ Calculated

ǁ RR

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; Adj = adjusted; CG = control group; CI = confidence interval; CVA = cerebrovascular accident; CVD = cardiovascular disease; HR = hazard ratio; IG = intervention group; MI = myocardial infarction; N = sample size; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk

Table 8 Myocardial Infarction And Cerebrovascular Accident Outcomes For Included Aspirin Studies For KQ4: Does Treatment Of Screen-Detected Or Generally Asymptomatic Adults With PAD Or An Abnormal ABI Lead To Improved Patient Health Outcomes?

Outcome | Trial name Author, Year | Mean F/U, yrs | IG N Analyzed | IG N Events (%) | CG N Analyzed | CG N Events (%) | IG vs. CG HR (95% CI)
Nonfatal MI + coronary death | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 90 (5.4%)^*^ | 1,675 | 86 (5.1%)^*^ | 1.05 (0.78 to 1.40)^*,†^
Nonfatal MI + coronary death | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 90 (14.1%)^*^ | 638 | 82 (12.9%)^*^ | 1.10 (0.83 to 1.45)^*,‡^
Fatal coronary event | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 28 (1.7%) | 1,675 | 18 (1.1%) | 1.56 (0.86 to 2.80)^*,†^
Fatal coronary event | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 35 (5.5%) | 638 | 26 (4.1%) | 1.35 (0.81 to 2.25)
Nonfatal MI | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 62 (3.7%) | 1,675 | 68 (4.1%) | 0.91 (0.65 to 1.28)^*,†^
Nonfatal MI | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 55 (8.6%) | 638 | 56 (8.8%) | 0.98 (0.68 to 1.43)
Total CVA | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 44 (2.6%)^*^ | 1,675 | 50 (3.0%)^*^ | 0.88 (0.59 to 1.31)^*,†^
Total CVA | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 37 (5.8%)^*^ | 638 | 50 (7.8%)^*^ | 0.74 (0.49 to 1.12)^*,†^
Fatal CVA | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 7 (0.4%) | 1,675 | 12 (0.7%) | 0.58 (0.23 to 1.48)^*,†^
Fatal CVA | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 8 (1.3%) | 638 | 9 (1.4%) | 0.89 (0.34 to 2.30)
Nonfatal CVA | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 37 (2.2%) | 1,675 | 38 (2.3%) | 0.97 (0.62 to 1.52)^*,†^
Nonfatal CVA | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 29 (4.6%) | 638 | 41 (6.4%) | 0.71 (0.44 to 1.14)
Total ischemic CVA | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 30 (1.8%)^*^ | 1,675 | 37 (2.2%)^*^ | 0.81 (0.50 to 1.31)^*,†^
Fatal ischemic CVA | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 2 (0.1%) | 1,675 | 7 (0.4%) | 0.29 (0.06 to 1.37)^*,†^
Fatal ischemic CVA | POPADAD Belch, 2008^98^ | 6.7^‡^ | 638 | 3 (0.5%) | 638 | 5 (0.8%) | 0.60 (0.14 to 2.50)^*,†^
Nonfatal ischemic CVA | AAA Fowkes, 2010^102^ | 8.2 | 1,675 | 28 (1.7%) | 1,675 | 30 (1.8%) | 0.93 (0.56 to 1.56)^*,†^

* Calculated.

† RR

‡ Median.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; CG = control group; CI = confidence interval; CVA = cerebrovascular accident; HR = hazard ratio; IG = intervention group; N = population; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk

Table 9 PAD-Specific Outcomes For Included Aspirin Studies For KQ4: Does Treatment Of Screen-Detected Or Generally Asymptomatic Adults With PAD Or An Abnormal Abi Lead To Improved Patient Health Outcomes?

Trial name Author, Year | Mean F/U, years | Outcome | IG N Analyzed | IG N Events (%) | CG N Analyzed | CG N Events (%) | IG vs. CG HR (95% CI)
AAA Fowkes, 2010^102^ | 8.2 | Development of IC | 1,675 | 53 (3.2%) | 1,675 | 53 (3.2%) | 1.00 (1.00 to 1.00)^*,†^
POPADAD Belch, 2008^98^ | 6.7^‡^ | Development of IC | 638 | 97 (15.2%) | 638 | 107 (16.8%) | 0.89 (0.68 to 1.18)
AAA Fowkes, 2010^102^ | 8.2 | Peripheral revascularization | 1,675 | 23 (1.4%) | 1,675 | 20 (1.2%) | 1.15 (0.63 to 2.09)^*,‡^
POPADAD Belch, 2008^98^ | 6.7^‡^ | Peripheral arterial bypass surgery | 638 | 7 (1.1%) | 638 | 5 (0.8%) | 1.41 (0.45 to 4.43)
POPADAD Belch, 2008^98^ | 6.7^‡^ | Peripheral arterial angioplasty | 638 | 11 (1.7%) | 638 | 13 (2.0%) | 0.85 (0.38 to 1.89)
POPADAD Belch, 2008^98^ | 6.7^‡^ | Above ankle amputation for critical limb ischemia | 638 | 11 (1.7%) | 638 | 9 (1.4%) | 1.23 (0.51 to 2.97)

* Calculated

† RR

‡ Median.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; CG = control group; CI = confidence interval; HR = hazard ratio; IC = intermittent claudication; IG = intervention group; N = population; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk.

In terms of subgroups, there was no compelling evidence to support a differential treatment effect by age or sex. Within-trial comparisons revealed overlapping confidence intervals, and the single trial (POPADAD) with heterogeneity testing for CVD outcomes by age and sex reported nonstatistically significant interaction testing (Tables 10 and 11).

Table 10 Age Subgroup Analyses For Reported Outcomes In Included Aspirin Studies For KQ4: Does Treatment Of Screen-Detected Or Generally Asymptomatic Adults With PAD Or An Abnormal ABI Lead To Improved Patient Health Outcomes?

Trial name Author, Year | Mean F/U, years | Type of analysis | Outcome | Age, years | IG N Analyzed | IG N Events (%) | CG N analyzed | CG N Events (%) | IG vs. CG HR (95% CI) | P-Value for interaction
AAA Fowkes, 2010^102^ | 8.2 | A priori | Primary composite: Initial fatal or nonfatal coronary event, CVA or revascularization | <62 | NR | 57 (NR)^*^ | NR | 70 (NR)^†^ | 0.85 (0.60 to 1.20) | NR
AAA Fowkes, 2010^102^ | 8.2 | A priori | Primary composite: Initial fatal or nonfatal coronary event, CVA or revascularization | ≥62 | NR | 124 (NR)^‡^ | NR | 106 (NR)^§^ | 1.13 (0.87 to 1.47) | NR
POPADAD Belch, 2008^98^ | 6T^ǁ^ | Specification unclear | Fatal Coronary Events + Fatal CVA | <60 | 297 | 10 (3.4%) | 315 | 10 (3.2%) | 1.07 (0.44 to 2.56) | 0.44
POPADAD Belch, 2008^98^ | 6T^ǁ^ | Specification unclear | Fatal Coronary Events + Fatal CVA | ≥60 | 341 | 33 (9.7%) | 323 | 25 (7.7%) | 1.24 (0.74 to 2.09) | 0.44
POPADAD Belch, 2008^98^ | 6.7^ǁ^ | Specification unclear | Primary composite: death from CHD or CVA, nonfatal MI or CVA, or above ankle amputation for critical limb ischemia | <60 | 297 | 38 (12.8%) | 315 | 36 (11.4%) | 1.11 (0.70 to 1.75) | 0.77
POPADAD Belch, 2008^98^ | 6.7^ǁ^ | Specification unclear | Primary composite: death from CHD or CVA, nonfatal MI or CVA, or above ankle amputation for critical limb ischemia | ≥60 | 341 | 78 (22.9%) | 323 | 81 (25.1%) | 0.89 (0.65 to 1.21) | 0.77

* 8.6 per 1,000 p-y (95% CI, 6.5 to 11.2)

† 10.2 per 1,000 p-y (95% CI, 8.0 to 12.9)

‡ 18.8 per 1,000 p-y (95% CI, 15.6 to 22.4)

§ 16.6 per 1,000 p-y (95% CI, 13.6 to 20.1)

ǁ Median.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; CG = control group; CI = confidence interval; CHD = coronary heart disease; CVA = cerebrovascular accident; HR = hazard ratio; IG = intervention group; MI = myocardial infarction; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; p-y: person-years

Table 11 Sex Subgroup Analyses for Reported Outcomes in Included Aspirin Studies for KQ4: Does Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI Lead to Improved Patient Health Outcomes?

Trial name Author, Year | Mean F/U, years | Type of analysis | Outcome | Sex | IG N Analyzed | IG N Events (%) | CG N Analyzed | CG N Events (%) | IG vs. CG HR (95% CI) | P-Value for interaction
AAA Fowkes, 2010^102^ | 8.2 | A priori | Primary composite: initial (earliest) fatal or nonfatal coronary event or CVA or revascularization | Men | 481 | 96 (20.0%) | 473 | 83 (17.5%) | 1.15 (0.86 to 1.54)^*,†^ | NR
AAA Fowkes, 2010^102^ | 8.2 | A priori | Primary composite: initial (earliest) fatal or nonfatal coronary event or CVA or revascularization | Women | 1,194 | 85 (7.1%) | 1,202 | 93 (7.7%) | 0.92 (0.68 to 1.23)^*,†^ | NR
POPADAD Belch, 2008^98^ | 6.7^‡^ | Specification unclear | Fatal coronary events + fatal CVA + CVD death | Men | 286 | 26 (9.1%) | 277 | 19 (6.9%) | 1.33 (0.73 to 2.40) | 0.68
POPADAD Belch, 2008^98^ | 6.7^‡^ | Specification unclear | Fatal coronary events + fatal CVA + CVD death | Women | 352 | 17 (4.8%) | 361 | 16 (4.4%) | 1.09 (0.55 to 2.16) | 0.68
POPADAD Belch, 2008^98^ | 6.7^‡^ | Specification unclear | Primary Composite: death from CHD or CVA, nonfatal MI or CVA, or above ankle amputation for critical limb ischemia | Men | 286 | 68 (23.8%) | 277 | 62 (22.4%) | 1.04 (0.74 to 1.47) | 0.54
POPADAD Belch, 2008^98^ | 6.7^‡^ | Specification unclear | Primary Composite: death from CHD or CVA, nonfatal MI or CVA, or above ankle amputation for critical limb ischemia | Women | 352 | 48 (13.6%) | 361 | 55 (15.2%) | 0.89 (0.60 to 1.31) | 0.54

* Calculated

† RR

‡ Median

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; CG = control group; CI = confidence interval; CHD = coronary heart disease; CVA = cerebrovascular accident; RR = Relative Risk; HR = hazard ratio; IG = intervention group; MI = myocardial infarction; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; p-y: person-years

### Exercise

#### Study Characteristics

The two exercise trials were new to this update because supervised exercise and physical therapy was not an included intervention type in the prior review. We identified one small, fair-quality U.S. trial by Collins and colleagues (n=50)^105^ and one good-quality Australian trial by Fowler and colleagues (n=882)^106^ examining the effectiveness of exercise in populations with a low ABI. The U.S. RCT included participants with a low ABI (<0.9) and no intermittent claudication who were referred to a vascular lab, while the Australian trial recruited participants from the population-based, Western Australian abdominal aortic aneurysm-screening trial; participants who screened positive for PAD using either the ECQ or ABI were then randomized to the intervention or control group. Primary outcomes were the change from baseline to followup in walking ability (WIQ walking distance score^105^ or ability to walk 100 to 400 yards before onset of intermittent claudication^106^). Secondary outcomes were WIQ-measured speed and stair climbing, the ABI, HgbA1c, lipid values, and PACE scores;^105^ HrQOL,^105,^ ^106^ physical activity,^106^ intermittent claudication based on the ECQ,^106^ and smoking.^106^ Outcomes were ascertained at 12^105^ and 52 weeks^106^ of followup.

#### Population Characteristics

The Collins trial recruited participants who were referred to a Veterans Administration vascular lab with an ABI of 0.5 to <0.9 and without intermittent claudication; participants were almost exclusively men (98%) (Table 12). The Fowler trial recruited exclusively men ages 65 to 79 years who screened positive for PAD using the ECQ and/or ABI. Mean age was 69.1 and 73.1 in the trials, respectively. The Collins trial included a majority of white participants (white 64%, black 26%, Hispanic 10%), while the Fowler trial did not report race or ethnicity. Most participants in the Collins trial had hypertension (86%); mean BP was 161/87 mm Hg in the Fowler trial. Mean total cholesterol was 189 mg/dL in the Collins trial, with approximately 60 percent of participants having an LDL greater than 100 mg/dL and HDL less than 40 mg/dL. Cholesterol levels were not reported in the Fowler trial. The Collins trial had more participants with diabetes (40%), compared with the Fowler trial (17.2%). More than half of the Collins participants were asymptomatic for PAD (56% were asymptomatic and 44% had atypical symptoms) which was intentional as the trial researchers selected participants for asymptomatic and atypical PAD using a telephone administered San Diego Claudication Questionnaire, while the Fowler screen-detected population recruited 27.4 percent asymptomatic participants; 44.6 percent had intermittent claudication and 9.2 percent had atypical symptoms. The mean ABI was 0.74 and 0.79 in the trials, respectively. Thirty percent and 18.7 percent of participants were smokers in the two trials. Nearly one-third of participants in the Fowler trial had angina and onequarter had history of MI.

Table 12 Participant Characteristics for Included Exercise Studies for KQ4: Does Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI Lead to Improved Patient Health Outcomes?^*^

Study name Author, Year | Quality | Country | N | Population description Recruitment method/setting | Mean Age, years (range) | % Female | Race/Ethnicity, % | % HTN (mean SBP/DBP) BP Meds | TC, mg/dL (mean | LDL-C, mg/dL (mean) | HDL-C, mg/dL (mean) | % DM | % Symptoms | ABI (mean) | % Smoking
Collins, 2007^105^ | Fair | U.S. | 50 | Patients with PAD based on an ABI of 0.50 to <0.9 and without symptoms of IC Patients referred to vascular lab | 69.1 (range NR) | 2 | White: 64 Black: 26 Hispanic: 10 | 86 (NR) Use of ACEI: 56 Use of BB: 34 | 188.6^†^ 10% >240 mg/d L | 117.6t^†^ 60% >100 mg/dL | 36.8^*^ 62% <40 mg/dL | 40 | None: 56 Atypical: 44 IC: 0 | 0.74 | 30
Western Australia Trial of Screening for Abdominal Aortic Aneurysms Fowler, 2002^106^ | Good | Australia | 882 | Men aged 65-79 who screened positive for PAD using the ECQ and ABI Population-based screening using the ECQ and ABI (the ABI conducted in 2 of 3 clinics) | 73.1 (65-79) | 0 | NR | NR (160.6/8 6.9) Meds NR | NR^†^ | NR^†^ | NR^*^ | 17.2 | None: 27.4 Atypical: 9.2 IC: 44.6 | 0.79 | 18.7

* Mean CVD risk score was not reported in either trial. In the Fowler trial, 32.4% of the population had a history of angina, 24.0% had a history of MI, and 12.8% had a history of CVA. Mean body mass index in the Fowler trial was 26.4 and was not reported in the Collins trial.

† Use of lipid-lowering treatment is not reported

Abbreviations: ABI = ankle-brachial index; ACE = angiotensin-converting enzyme inhibitor; BB = beta blocker; BMI=body mass index; BP = blood pressure; CVA = cerebrovascular accident; CVD = cardiovascular disease; ECQ = Edinburgh Claudication Questionnaire; HDL-C = high-density lipoprotein cholesterol; HTN = hypertension; IC = intermittent claudication; LDL-C = low-density lipoprotein cholesterol; mg/dL= milligrams per deciliter; MI = myocardial infarction; NR = not reported; PAD = peripheral artery disease; TC = total cholesterol

#### Intervention Details

The intervention in the Collins trial included two individual, nurse-delivered components: riskfactor modification and improvement in physical activity (Table 13). The risk-modification component included a “recognize, identify, and manage” approach whereby a nurse completed an initial 5-minute assessment of medication adherence followed by dietary advice and metabolic goals (HbA1c, LDL cholesterol). The physical activity component used the Patient-Centered Assessment and Counseling for Exercise (PACE) protocol,^111^ which included a readiness-forchange-stage assessment related to physical activity and a tailored handout identifying ways to increase physical activity; followup discussions encouraged regular physical activity. The intervention occurred during an initial, individual, face-to-face session followed by five phone visits lasting less than 30 minutes each which were conducted over 10 weeks. Control group participants were advised to continue routine care with their primary care physicians.

Table 13 Intervention Details for Included Exercise Studies for KQ4: Does Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI Lead to Improved Patient Health Outcomes?

Author, Year | IG Description | CG Description | Format | Delivered by | Duration, weeks | # Sessions | Session length, min
Collins, 2007^105^ | Advice to continue routine care with primary care physician, plus 2 intervention components: risk factor modification and improvement in physical activity (PA). Risk factor modification: “Recognize, identify, and manage” (RIM) approach used to assess risk factors. During initial 5-minute assessment, nurse used RIM to assess medication adherence. Nurse then assessed dietary needs specific to risk-factor profile, advised about HbA1c and LDL-C goals, and counseled on reading food labels, increasing fiber, and reducing calories. Participants were asked to share examples of appropriate behavior change related to their specific risk factors PA: PACE protocol, which included PA assessment of stage of readiness to change and handout tailored to help patient identify ways to increase PA based on stage of change, followed by “extensive discussion” with nurse to encourage regular PA | Usual care: patients advised to continue routine care with their primary care physician | Individual, in-person with phone F/U Unsupervised PA | Nurse | 12 | 6 (Initial session + 5 F/U phone visits) | Initial session: NR F/U sessions: <30
Fowler, 2002^106^ | “Stop smoking and keep walking” Intervention components included: 1) education, 2) letter to GP recommending smoking cessation, and 3) referral to a community PT intervention. Participants told that “your ABI or ECQ test showed a reduced blood flow to the muscles in your leg or legs caused by partial blockage of the arteries and this often results in pain on walking.” Participants provided with educational package including information on PAD, a brochure on the community PT service, information on smoking cessation (if applicable), and a copy of the letter from the clinic to their GP, and were advised to consult GP about management. GP sent a package of written materials about smoking cessation, notes on obtaining optimal results from nicotine replacement products, and a fact sheet on PAD. GP asked to discuss smoking and to refer each man with early PAD to community PT service. The community PT contacted each referred man within approximately three weeks of screening exam. The community PT intervention offered options to increase PA either independently or through an organized program. Participants could attend a weekly mixed-gender group session as part of the established program, a men-only session, or a home-based PA program devised specifically for him by the senior PT. Additionally, all men in IG advised by PT to walk for ≥30 minutes/day. In certain cases, men were referred to hydrotherapy classes or special exercise sessions for those with disabilities. | Usual care: patients told by nurse at screening clinic that “the blood flow to your feet and legs is lower than normal. This is not uncommon for men of your age but there is presently no evidence to suggest you should do anything about it at this time.” ABI and ECQ results were not mentioned in letters to the patient or GP regarding results of the AAA screening. | Individual initial session with print materials, PA was participants' choice of individual home-based PA or weekly group sessions | Nurse, GP, PT | 52 | For participants choosing group format: 51 (initial session with nurse, initial session with PT + 49 supervised PA sessions [52 weeks-3 week lead time])^*^ For participants choosing home-based PA: 2 (initial session with nurse, initial session with FT) | Initial session with nurse: NR Initial session with PT NR Group PA sessions: 45

* Based on Table 4, 16.5% of IG reported being in exercise group at 12 months

Abbreviations: AAA = abdominal aortic aneurysm; ECQ = Edinburgh Claudication Questionnaire; F/U = followup; GP = general practitioner; HbA1c = glycated hemoglobin; LDL-C = low-density lipoprotein cholesterol; NR = not reported; PA = physical activity; PACE = Physician-based Assessment and Counseling for Exercise; PAD = peripheral artery disease; PT = physical therapy/physical therapist

The intervention in the Fowler trial included a smoking cessation intervention and physical therapy (PT) referral. The initial, individual, face-to-face session included an explanation of the PAD screening test results and provision of an educational packet with information about PAD, a brochure about the community PT service, smoking-cessation information if applicable, and a copy of the letter sent to their general practitioner. Participants in the intervention group were advised to discuss PAD with their physician. General practitioners were advised to discuss smoking cessation and refer each participant to the community PT service, which then contacted each participant in the intervention group (the length of this initial session is not reported). The community PT service goal was to increase physical activity and included either weekly, 45-minute supervised sessions for 49 sessions or an individually designed, home-based physical activity program. In addition, all men were advised to walk for 30 minutes or more each day (or water therapy classes or special sessions for those with disabilities). The control group received usual care; nurses briefly disclosed results of diminished flow to lower extremities but stated there was no evidence for any intervention.

#### Study Quality

The Collins trial was conducted as a small, short-term feasibility study to calculate effect size and estimate power for subsequent trials, so it was not intended to be large enough to detect differences in the primary outcome (WIQ walking distance). There were large, statistically significant baseline differences in physical functioning scores as measured by the MOS SF-36, with the intervention group having greater (better) physical functioning scores, which may bias against finding a benefit from the intervention (IG 55.0, CG 39.4; p<0.009).

The Fowler trial was powered to detect differences in walking distance (e.g., 90% power to detect a 7.9% between-group difference in the proportion of men able to walk 100—400 yards before onset of intermittent claudication).

In both trials, ITT analyses were used and followup was good to excellent (greater than 80%). The Collins trial did not report whether outcome assessors were blinded. Adherence to the physical activity component differed widely in the two trials. The 12-week Collins trial reported high adherence to the physical activity recommendation of 30 minutes three times per week (40% at baseline and 82% by the fifth [final] phone call), while adherence over the longer Fowler trial was relatively low (only 16.5% of the intervention group attended classes at the 1year followup).

#### Results

##### QOL

Quality-of-life changes from baseline as measured by the MOS SF-36 and Rosser HrQOL instruments were similar between the intervention and control groups in both trials (Table 14). For example, in the Fowler trial, the MOS SF-36 component score mean differences between the exercise intervention and control groups ranged from -1.8 to 18.2 without any statistically significant differences between baseline and followup.^106^ In the Collins trial, the followup HrQOL scores were nearly identical in the exercise intervention and control groups.^105^

Table 14 Quality of Life Outcomes in Included Exercise Studies for KQ4: Does Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI Lead to Improved Patient Health Outcomes?

Author, Year Quality | F/U, Wks | Outcome/Instrument (except where noted, 0-100, where higher score indicates better function) | IG N^*^ | IG Mean (SD) baseline | IG Mean (SD) F/U^†^ | IG Mean change (95% CI)^‡^ | CG N^*^ | CG Mean (SD) baseline | CG Mean (SD) F/U^†^ | CG Mean change (95% CI)^‡^ | Between-group difference Mean (95% CI)^§^
Collins, 2007^105^ Fair | 12 | MOS SF-36: Physical functioning | 23 | 55.0 (18.5) | 64.1 (25.3) | 9.1 (-0.2 to 18.4) | 25 | 39.4 (22.4) | 45.4 (28.3) | 6.0 (-4.1 to 16.1) | 3.1 (-10.6 to 16.8); p>0.20
Collins, 2007^105^ Fair | 12 | MOS SF-36: Role-physical | 23 | 36.0 (36.1) | 52.2 (41.9) | 16.2 (0.1 to 32.3) | 25 | 35.0 (42.7) | 33.0 (38.7) | -2.0 (-18.0 to 14.0) | 18.2 (-4.5 to 40.9); p=0.11
Collins, 2007^105^ Fair | 12 | MOS SF-36: Bodily pain | 23 | 40.9 (19.1) | 49.0 (27.3) | 8.1 (-1.8 to 18.0) | 25 | 54.2 (28.2) | 61.4 (29.0) | 7.2 (-4.0 to 18.4) | 0.9 (-14.1 to 15.9); p>0.20
Collins, 2007^105^ Fair | 12 | MOS SF-36: General health | 23 | 55.4 (19.0) | 56.3 (22.5) | 0.9 (-7.7 to 9.5) | 25 | 55.7 (23.8) | 48.2 (19.1) | -7.5 (-16.1 to 1.1) | 8.4 (-3.7 to 20.5); p=0.15
Collins, 2007^105^ Fair | 12 | MOS SF-36: Vitality | 23 | 46.5 (18.9) | 51.1 (23.6) | 4.6 (-4.2 to 13.4) | 25 | 45.9 (22.2) | 41.8 (24.0) | -4.1 (-13.2 to 5.0) | 8.7 (-4.0 to 21.4); p=0.12
Collins, 2007^105^ Fair | 12 | MOS SF-36: Social functioning | 23 | 76.5 (24.3) | 77.7 (26.4) | 1.2 (-9.2 to 11.6) | 25 | 75.0 (23.4) | 78.0 (28.5) | 3.0 (-7.3 to 13.3) | -1.8 (-16.4 to 12.8); p>0.20
Collins, 2007^105^ Fair | 12 | MOS SF-36: Role-emotional | 23 | 45.3 (42.9) | 65.2 (44.4) | 19.9 (2.1 to 37.7) | 25 | 53.3 (44.1) | 70.7 (37.7) | 17.4 (1.2 to 33.6) | 2.5 (-21.6 to 26.6); p>0.20
Collins, 2007^105^ Fair | 12 | MOS SF-36: Mental health | 23 | 71.2 (17.4) | 76.5 (17.7) | 5.3 (-1.9 to 12.5) | 25 | 75.8 (17.1) | 76.7 (14.8) | 0.9 (-5.4 to 7.2) | 4.4 (-5.1 to 13.9); p>0.20
Fowler, 2002^106^ Good | 52 | Health-related quality of life; Rosser instrument (-1.2 to 1.0; higher indicates better) | 361∥ | NR | 0.83 (0.13) | NR | 336∥ | NR | 0.84 (0.14) | NR | p=0.13

* N analyzed at followup

† Adjusted for baseline values

‡ Calculated

§ Study reported p-values. Calculated between-group mean difference and 95% CI (see methods for more detail).

∥ N analyzed unclear from outcomes table; this is the number of participants returning a complete questionnaire

Abbreviations: CG = control group; CI = confidence interval; F/U = followup; IG = intervention group; MOS SF-36 = Medical Outcomes Study Short-Form Health Survey; NR = not reported; SD = standard deviation

##### WIQ

The Collins trial reported no difference in the primary outcome of mean walking distance score on the WIQ or walking speed but did report a statistically significantly larger improvement in the stair-climbing component of the WIQ in the intervention group compared with the control group (mean difference 15.1 [95% CI, 2.4 to 32.6]; p=0.02) (Table 15).

Table 15 Walking Impairment Questionnaire Outcomes in Included Exercise Studies for KQ4: Does Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI Lead to Improved Patient Health Outcomes?

Author, Year Quality | FU, Wks | Outcome (Range: 0. 100, where higher score indicates better function)^180^ | IG N^*^ | IG Mean (SD) baseline | IG Mean (SD) F/U^†^ | IG Mean change (95% CI) ‡ | CG N^*^ | CG Mean (SD) baseline | CG Mean (SD) F/U^†^ | CG Mean change (95% CI) ‡ | Between-group difference Mean (95% CI) §
Collins, 2007^105^ Fair | 12 | WIQ: Walking distance | 23 | 43.2 (28.2) | 62.3 (33.0) | 19.1 (6.5 to 31.7) | 25 | 30.9 (34.2) | 40.1 (35.7) | 9.2 (-4.5 to 22.9) | 9.9 (-8.7 to 28.5); p=0.18
Collins, 2007^105^ Fair | 12 | WIQ: Walking speed | 23 | 40.5 (24.9) | 41.4 (21.4) | 0.9 (-8.6 to 10.4) | 25 | 33.1 (31.4) | 28.3 (24.5) | -4.8 (-16.0 to 6.4) | 5.7 (-9.0 to 20.4); p=0.09
Collins, 2007^105^ Fair | 12 | WIQ: Stair climbing | 23 | 43.7 (30.7) | 61.2 (32.8) | 17.5 (4.5 to 30.5) | 25 | 37.8 (29.8) | 40.2 (30.2) | 2.4 (-9.4 to 14.2) | 15.1 (2.4 to 32.6); p=0.02

* N analyzed at followup

† Adjusted for baseline values

‡ Calculated

§ Study reported p-values. Calculated between group mean difference and 95% CI (see methods for more detail).

Abbreviations: CG = control group; CI = confidence interval; F/U = followup; IG = intervention group; MOS SF-36 = Medical Outcomes Study Short-Form Health Survey; NR = not reported; SD = standard deviation; WIQ = Walking Impairment Questionnaire

##### Symptoms

The Collins trial showed that neither the intervention nor control groups had statistically significant changes in the proportion of participants with symptoms (atypical symptoms or intermittent claudication) over the trial duration; there was no difference between the intervention and control groups (Table 16). The Fowler trial reported statistically significant improvements in symptoms in both the intervention and control groups but no difference in proportions of participants with symptoms when comparing the groups. For example, 45.6 and 43.5 percent of the intervention and control groups, respectively, had intermittent claudication at baseline; these proportions decreased to 28.5 and 30.9 percent at 52 weeks (between-group pvalue of 0.50). The proportion of participants with atypical symptoms showed a similar pattern, although it was experienced by fewer participants.

Table 16 Proportion of Participants With Symptoms at Baseline and Followup in Exercise Studies Included for KQ4: Does Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI Lead to Improved Patient Health Outcomes?

Outcome | Author, Year | FU, Wks | IG Baseline | IG F/U | IG Change p-value^*^ | CG Baseline | CG F/U | CG Change p-value^*^ | Calculated between-group difference, p-value^*^
N (%) with atypical symptoms | Collins, 2007^105^ | 12 | 12/25 (48.0) | 12/23 (52.2) | 0.69 | 10/25 (40.0) | 9/25 (36.0) | 0.68 | 0.26
N (%) with atypical symptoms | Fowler, 2002^106^ | 52 | 35/441 (7.9)f | 7/347 (2.0)f | <0.001 | 46/441 (10.4)^†^ | 13/327 (4.0)^†^ | <0.001 | 0.13
N (%) with IC | Collins, 2007^105^ | 12 | 0/25 (0.0) | 1/23 (4.3) | Not calculable | 0/25 (0.0) | 1/25 (4.0) | Not calculable | 0.95
N (%) with IC | Fowler, 2002^106^ | 52 | 201/441 (45.6)^‡^ | 99/347 (28.5)^‡^ | <0.001 | 192/441 (43.5)^‡^ | 101/327 (30.9)^‡^ | <0.001 | 0.50

* p-value calculated from test of proportions

† Edinburgh Claudication Questionnaire Atypical IC Grade 1 and Grade 2 combined

‡ Edinburgh Claudication Questionnaire Definite IC Grade 1 and Grade 2 combined

Abbreviations: CG = control group; CI = confidence interval; F/U = followup; IG = intervention group; NR = not reported

In terms of subgroups, there was no evidence to address whether a differential treatment effect exists in subpopulations at greater risk for PAD.

## KQ5 What Are the Harms of Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI? KQ5a. Do the Harms of Treatment Vary by Subpopulations at Greater Risk for PAD?

### Summary of Results

Limited evidence from one trial demonstrates a trend toward higher risk for major bleeding events with the use of aspirin. There was no effect on major GI bleeding in one trial. Two trials reported relative risks for total or fatal hemorrhagic CVA less than and greater than 1 with wide overlapping confidence intervals due to rare events. The two exercise trials did not report measuring harms.

### Results

The two trials, AAA and POPADAD, report bleeding harms associated with 100 mg daily aspirin use (enteric coated in AAA and nonenteric coated in POPADAD) (Table 17). Major GI bleeding, major hemorrhage, and total hemorrhagic CVA were outcomes reported in AAA (N=3,350). Major GI bleeding requiring hospital admission was similar in the aspirin and control groups (0.5% versus 0.5%; relative risk (RR) 1.13 [95% CI, 0.44 to 2.91]). Major hemorrhage (defined as nonfatal or fatal hemorrhagic CVA, fatal or nonfatal subarachnoid/subdural hemorrhage, GI bleed requiring admission, and other bleeding requiring hospital admission) did not reach statistical significance but was higher in the aspirin group (2.0% vs. 1.2%; HR 1.71 [95% CI, 0.99 to 2.97]). There was a trend for increased total hemorrhagic CVA associated with aspirin use; however, confidence intervals were wide due to the rare event rate and crossed one (0.3% vs. 0.2%; RR 1.25 [95% CI, 0.34 to 4.65]); five hemorrhagic CVAs occurred in the aspirin group and four occurred in the control group. POPADAD reported a nonsignificant reduction in fatal hemorrhagic CVA in the aspirin group, but again, confidence intervals were wide due to rare events (0.3% versus 0.5%; RR 0.67 [95% CI, 0.11 to 3.98]); two hemorrhagic CVAs occurred in the aspirin group and three occurred in the control group. POPADAD reported gastrointestinal bleeding without indication of severity, so these results were not included.

Table 17 Harms in Included Aspirin Studies for KQ5: What Are the Harms of Treatment of Screen-Detected or Generally Asymptomatic Adults With PAD or an Abnormal ABI?

Trial name Author, Year | Mean F/U, years | Outcome | IG N Analyzed | IG N Events (%) | CG N Analyzed | CG N Events (%) | IG vs. CG HR (95% CI)
AAA Fowkes, 2010^102^ | 8.2 | Major Hemorrhage^*^ | 1,675 | 34 (2.0%) | 1,675 | 20 (1.2%) | 1.71 (0.99 to 2.97)
AAA Fowkes, 2010^102^ | 8.2 | Major GI Bleeding^†^ | 1,675 | 9 (0.5%)^‡^ | 1,675 | 8 (0.5%)^‡^ | 1.13 (0.44 to 2.91)^‡,§^
AAA Fowkes, 2010^102^ | 8.2 | Total Hemorrhagic CVA | 1,675 | 5 (0.3%)t | 1,675 | 4 (0.2%)^‡^ | 1.25 (0.34 to 4.65)^‡,§^
AAA Fowkes, 2010^102^ | 8.2 | Fatal Hemorrhagic CVA | 1,675 | 3 (0.2%) | 1,675 | 3 (0.2%) | 1.00 (0.20 to 4.95)^‡,§^
AAA Fowkes, 2010^102^ | 8.2 | Nonfatal Hemorrhagic CVA | 1,675 | 2 (0.1%) | 1,675 | 1 (0.1%) | 2.00 (0.18 to 22.04)^‡,§^
AAA Fowkes, 2010^102^ | 8.2 | Intracranial Bleeding∥ | 1,675 | 6 (0.4%)^‡,§^ | 1,675 | 3 (0.2%)^‡,§^ | 2.00 (0.50 to 7.98)^‡,§^
POPADAD Belch, 2008^98^ | 6.7^¶^ | Fatal Hemorrhagic CVA | 638 | 2 (0.3%) | 638 | 3 (0.5%) | 0.67 (0.11 to 3.98)^‡,§^

* Defined as nonfatal or fatal hemorrhagic CVA, fatal or nonfatal subarachnoid/subdural hemorrhage, GI bleed requiring admission, and other bleeding requiring hospital admission

† Defined as requiring admission to hospital to control bleeding; admission only to investigate bleeding not included

‡ Calculated.

§ RR

∥ Edinburgh Claudication Questionnaire Definite IC Grade 1 and Grade 2 combined

¶ Median

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; CG = control group; CI = confidence interval; CVA = cerebrovascular accident; GI = gastrointestinal; IG = intervention group; n = population; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk; HR = Hazard Ratio

There are no subgroup analyses published from the two included trials reporting bleeding harms associated with aspirin in subpopulations at greater risk for PAD.