# 2 Methods

## Scope and Purpose

This report will be used by the USPSTF to update its 2013 recommendation on Screening for Peripheral Artery Disease and Cardiovascular Disease Risk Assessment with the Ankle-Brachial Index in Adults.^73^ A concurrent systematic review will be used to address questions pertaining to the ability of the ABI to improve risk prediction when added to traditional CVD risk assessment.^74^

## Key Questions and Analytic Framework

We developed an Analytic Framework (Figure 1) and five Key Questions (KQs) to guide the literature search, data abstraction, and data synthesis.

Figure 1 Analytic Framework

Abbreviations: ABI = ankle-brachial index; PAD = peripheral artery disease

Figure 1 is the analytic framework that depicts the five Key Questions (KQ) addressed in the systematic review. The figure illustrates how screening generally asymptomatic adults for PAD using the ABI may reduce mortality, cardiovascular morbidity, PAD morbidity, and quality of life (KQ1). The figure also depicts the diagnostic accuracy of the ABI as a screening test for PAD (KQ2) and the harms of screening (KQ3). KQ4 depicts whether treatment of screen-detected or generally asymptomatic adults with PAD or abnormal ABI improves the patient health outcomes evaluated in KQ1 and if there are harms associated with treatment (KQ5).

### KQs

1. Is screening for PAD in generally asymptomatic adults^*^ with the ABI effective in reducing CVD or PAD morbidity (e.g., impaired ambulation or amputation) or mortality?
  a. Does the effectiveness of screening for PAD vary by subpopulations at greater risk for PAD?
2. What is the diagnostic accuracy of the ABI as a screening test for PAD in generally asymptomatic adults^*^?
  a. Does the diagnostic accuracy of screening with the ABI vary by subpopulations at greater risk for PAD?
3. What are the harms of screening for PAD with the ABI?
  a. Do the harms of screening for PAD vary by subpopulations at greater risk for PAD?
4. Does treatment of screen-detected or generally asymptomatic adults^*^ with PAD or an abnormal ABI^†^ lead to improved patient health outcomes?
  a. Does the effectiveness of treatment vary by subpopulations at greater risk for PAD?
5. What are the harms of treatment of screen-detected or generally asymptomatic adults^*^ with PAD or an abnormal ABI^†^?
  a. Do the harms of treatment vary by subpopulations at greater risk for PAD?

* Adults without lower-extremity symptoms clinically considered suspicious for PAD

† Defined as ABI of ≤0.90 or >1.40.

## Review Terminology

For the purposes of this review, we will use the following terminology:

- PAD: Patients with confirmed PAD diagnosed by a confirmatory imaging study (e.g., DSA, CTA, MRA)
- Low ABI: Patients with a resting ABI ≤0.9^*^
- Abnormal ABI: Patients with a resting ABI ≤0.9 or >1.3^*^
- Atypical lower-extremity symptoms: Patients with lower-extremity symptoms associated with PAD other than classic intermittent claudication. Two common types of atypical symptoms are: 1) leg pain occurring with exertion and rest and 2) exertional leg pain that does not cause the patient to stop walking (“leg pain with carry on”)^33^
- Generally asymptomatic: Patients with no lower-extremity symptoms or without symptoms clinically considered suspicious for PAD

* Some studies may use a cutoff of low or abnormal ABI of <0.9 or ≥1.3 or 1.4.

## Data Sources and Searches

This review was designed as an update of the screening, diagnostic accuracy, treatment, and harms KQs of our prior systematic review.^75^ As such, we evaluated all of the previously included studies from this review for potential inclusion. We then searched for new, primary, published literature from January 2012 to May 2, 2017. We searched the following databases: CENTRAL, Ovid Medline, and PubMed (publisher-supplied records only). We worked with a research librarian to develop our search strategy (Appendix A). One ongoing screening trial was published after the search date and was formally evaluated for inclusion. Additionally, due to an expansion in the scope of the current review to include individuals with diabetes as well as exercise or physical therapy interventions aimed at improving lower limb function, we performed a targeted search of the bibliographic database for the previous review for these terms; this database included results of a comprehensive literature search from 1996 to September 2012, as well as outside sources (Appendix A).

We also examined the reference lists of recent systematic reviews to identify any potential studies for inclusion.^69,^ ^76-83^ We supplemented our searches with articles identified through news and table-of-content alerts such as those produced by the USPSTF Scientific Resource Center LitWatch activity.^84^ On January 24, 2017, we searched Clinicaltrials.gov for interventional studies on PAD restricted to adult and senior populations that accepted healthy volunteers. One reviewer scanned titles of the 66 records, and 10 were reviewed in more detail. When the trial description provisionally met criteria, we “matched” the record with the publication. We managed the literature search results using version X7 of EndNote® (Thomson Reuters, New York, NY), a bibliographic management software database.

## Study Selection

Our review focuses on the clinical utility of the resting ABI as the primary screening modality because it is the most commonly used screening modality in clinical practice, does not require advanced technical skills or expensive equipment, and is able to detect asymptomatic individuals. Therefore, our review excluded other methods of screening (e.g., questionnaires, the exercise ABI, toe-brachial measurement, pulse oximetry, duplex ultrasound, MRA). Consistent with the scope of the USPSTF, our review focuses on screen-detected and/or generally asymptomatic adults and thus we excluded studies whose subjects primarily had known intermittent claudication. However, PAD is frequently associated with atypical symptoms not consistent with classic intermittent claudication; two common presentations of atypical symptoms are leg pain on exertion and rest and leg pain with carry on.^33^ Even trials primarily recruiting patients with atypical PAD symptoms include a heterogeneous group of individuals in terms of symptom severity: some of these patients will fall in a minimally symptomatic category expected to be detected by screening unselected populations, and others will be on the more severe end of symptom spectrum, where they would clinically present for diagnosis (not screening). Thus, for the purposes of this review, while studies of screen-detected PAD were the ideal; it was not possible to operationalize the clinically relevant concept of “generally asymptomatic” (i.e., those with no lower-extremity symptoms or without high clinical suspicion for PAD). In order to be inclusive, this review included studies with both asymptomatic participants and those with atypical symptoms. We acknowledge that even the trials of patients with atypical symptoms may not entirely represent a screen-detected group, so we examined the mean baseline ABI and WIQ scores to include trials that would be closest to a screen-detected group. We excluded studies conducted exclusively in individuals with known CVD or severe chronic kidney disease (stages 4 and 5). We excluded studies conducted in hospital or specialty settings or that recruited from these settings (i.e., vascular clinics or laboratories), as these settings typically represented populations selected for known or highly suspected PAD.

Our primary outcomes of interest are: cardiovascular morbidity (i.e., MI and CVA), PAD morbidity (e.g., ambulation impairment, amputation), mortality, health-related quality of life, diagnostic accuracy of the resting ABI, adverse outcomes related to the ABI test, and serious adverse events related to treatment. For ambulation impairment, we accepted outcomes from the Walking Impairment Questionnaire (WIQ), a validated, disease-specific questionnaire for individuals with PAD.^85^ This questionnaire captures self-reported ambulatory ability for three domains: stair climbing, walking speed, and walking distance; each domain is scored from 0 to 100 where 0 represents an inability to perform the task and 100 indicates no difficulty performing the task. Research has suggested that lower WIQ stair-climbing scores are associated with higher all-cause and cardiovascular mortality among adults with PAD;^86^ WIQ distance and speed scores were not associated with mortality in this study. In included studies reporting WIQ outcomes (which were exclusively exercise trials), we also abstracted and present proportions of the population with symptoms at baseline and followup. Consistent with USPSTF methods of focusing on hard health outcomes, we excluded intermediate outcomes of ambulation (e.g., 6-minute walk test, time or distance to claudication, maximum walking distance).

Included treatments were pharmacologic or lifestyle interventions primarily aimed at CVD risk reduction, such as: interventions for smoking cessation, cholesterol-lowering therapy, diet and exercise (with or without weight loss), blood pressure control, and antiplatelet therapy. Newly included in this update were exercise and physical therapy interventions aimed at improving lower limb function. Interventions aimed only at symptomatic adults or adults with critical limb ischemia were excluded. These include pharmacologic symptom management (e.g., cilostazol, prostaglandins), nonpharmacologic symptom management, and revascularization (e.g., angioplasty, thrombolytics, stenting, bypass).

For KQ 1, we considered randomized controlled trials (RCTs), controlled clinical trial (CCTs), and systematic reviews that compared ABI screening to no screening and reported cardiovascular morbidity, PAD morbidity, mortality, or health-related quality of life. For KQ 2, we considered prospectively conducted diagnostic accuracy studies and well-conducted systematic reviews of diagnostic accuracy. We excluded case-control studies in which cases were selected based on individuals having known PAD. Distorted selection of subjects in recruitment or case-control designs has repeatedly been shown to overestimate sensitivity.^87-91^ A distorted selection of subjects directly affects the applicability of the study findings and threatens its validity (i.e., spectrum bias). Spectrum bias refers to the phenomenon that diagnostic test performance may change between clinical settings due to changes in the patient case-mix. For KQ 2, diagnostic accuracy studies had to compare the resting ABI with a reference standard. Because the gold standard, DSA, is an invasive test that presents known risks, it is not ethical to administer this test in asymptomatic individuals. Therefore, we considered any diagnostic test that could image the degree of atherosclerosis (e.g., MRA, CTA) or degree of impaired blood flow (e.g., duplex ultrasound) to be a reasonable diagnostic reference standard. We accepted all measures of diagnostic accuracy (e.g., sensitivity, specificity, positive or negative predictive values, positive or negative likelihood ratios). For KQ 4, we included any trial (RCT or CCT) and systematic review with at least 12 weeks of followup that compared treatment of PAD with no treatment, with placebo treatment, or with delayed treatment. Treatment trials needed to report one of the following outcomes: cardiovascular morbidity (i.e., MI or CVA), PAD morbidity (e.g., ambulation impairment, amputation), mortality, or health-related quality of life. While we included reviews, trials, cohort studies, and case-control studies for evaluation of harms (KQs 3 and 5), we excluded case series or case reports.

## Comparison of 2013 Review and This Review

While this review was designed as an update of the screening, diagnostic accuracy, treatment, and harms KQs of our prior systematic review,^75^ a few changes were made to the inclusion criteria used to guide study selection (Appendix A Table 1). One of these changes was an expansion of the eligible population to include individuals with diabetes, who are a subpopulation at higher risk for PAD. Additionally, the scope was expanded to include early treatment trials aimed at improving lower-extremity function in screen-detected or asymptomatic persons with PAD or an abnormal ABI. This type of trial was included based on feedback from experts who stated that there is some evidence of lower-extremity impairment and functional limitation in individuals who do not report classical symptoms of intermittent claudication. Finally, intermediate outcomes (e.g., blood pressure, lipid levels) were removed, and the review focused on hard patient-centered health outcomes; USPSTF methods give greater weight to evidence of an effect on health outcomes than intermediate outcomes.^84^

## Quality Assessment and Data Abstraction

Two reviewers applied USPSTF design-specific criteria to assess the methodological quality of all eligible trials (Appendix A Table 2),^84^ and QUADAS-2 was used to evaluate studies of diagnostic accuracy (Appendix A Table 2).^92^ Articles were rated as good, fair, or poor quality. In general, a good-quality study met all criteria well. A fair-quality study did not meet (or it was unclear whether it met) at least one criterion but also had no known important limitation that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. Flaws leading to a poor-quality rating in the one poor-quality diagnostic accuracy study were concern about the blinding of results between tests and the absence of information on personnel, training, or timing of index and reference standard tests.^93^ Treatment trials were rated poor if there were baseline differences between groups, high differential attrition, and no blinding of outcome assessors^94^ and for a post-hoc subgroup comparison with scant reported information on the PAD subgroup of interest.^95^ We excluded poor-quality studies from this review.

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms and a second reviewer checked the data for accuracy. For diagnostic accuracy studies, we abstracted general characteristics of the study (e.g., author, year, sample size), recruitment setting and method, clinical and demographic characteristics of the sample (e.g., age, cardiovascular risk factors), analytic methods, and results. We abstracted similar information for treatment trials and additionally captured intervention details (e.g., pharmacotherapy dose and duration where applicable; intervention format, provider, duration, and number of sessions where applicable).

## Data Synthesis and Analysis

We synthesized data separately for each KQ. The number of contributing studies was not sufficient for quantitative pooling for each one, so we summarized these data in tables and narratively.

For diagnostic accuracy studies (KQ 2), we calculated false positive rates (positive test given the absence of the disease [1 – specificity]) and false negative rates (negative test result given the presence of the disease [1 – sensitivity]) and calculated confidence intervals using the Agresti-Coull method.^96^ For the aspirin treatment trials in KQ 4, there was some heterogeneity of trial-defined primary outcome measures, so we used the approach from the 2015 systematic review of aspirin for the primary prevention of cardiovascular events commissioned by the USPSTF.^97^ We constructed our own fatal composite outcome (defined as fatal MI/coronary event + fatal CVA + CVD death) and nonfatal composite outcome (defined as nonfatal MI/coronary event + nonfatal CVA). When this outcome was not reported in primary studies, we combined individual component outcomes. When measures of association were not reported, we calculated these measures using the number of individuals and the numbers of events in each randomized group. For the multifactorial trial with additional randomization to antioxidants or placebo, we report results as aspirin versus no aspirin, as there was no evidence of interaction between interventions.^98^

For continuous outcomes reported in exercise trials (KQ 4), we converted standard deviations to 95% confidence intervals using the following standard calculation:

95% CI = mean difference ± (1.96 * SD_mean difference_ / sqrt(n))

We estimated the standard deviation for between-group differences using a conservative correlation coefficient (r) of 0.5.^99^ We selected a conservative default correlation coefficient in the absence of a trial with a similar population reporting mean and SD changes from baseline for SF-36 and WIQ outcomes. We calculated standard deviation between-group differences using the following formula:

SD_change_ = sqrt(SD^2^_baseline_ + SD^2^_followup_ − ( 2 * r * SD_baseline_ * SD_followup_ ))

For the proportion of participants with symptoms at baseline and followup in exercise trials, we calculated between-group p-values from the test of proportions (using the prtest command in version 13.1 of Stata [Stata Corp LP, College Station, TX]).

Stata was applied for all quantitative analyses.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^100^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^101^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body-of-evidence limitations field highlights important restrictions in answering the overall KQ).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft research plan was posted on the USPSTF Web site for public comment from March 24 to April 20, 2016. Based on the comments it received about the research plan, the USPSTF clarified that this review will address screening in unselected populations according to USPSTF methodology and will also review the evidence for subpopulations at greater risk for PAD based on age (particularly ≥65 years), sex, race/ethnicity, diabetes, smoking, and hypertension status. Eligibility criteria for this update were expanded to include studies in adults with diabetes. The draft version of this report was reviewed by three invited experts and one USPSTF Federal Partner. Experts were selected based on their expertise on fundamental content aspects of the review (i.e., cardiovascular epidemiology, the ABI, aspirin interventions, exercise interventions) and were selected to obtain diverse informed perspectives, including guideline developers, trialists, specialists, and practicing clinicians. All expert comments were considered, and selected comments from experts were used to clarify and extend the synthesis of evidence to ensure accuracy and address scientifically relevant concerns. All comments were shared with members of the USPSTF and AHRQ. Additionally, a draft of the full report was posted on the USPSTF Web site from January 16, 2018 to February 12, 2018. Based on the public comments received, additional descriptive text was added to the discussion of selected included and excluded studies and minor revisions were made to text distinguishing abnormal ABI and PAD.

## USPSTF Involvement

We worked with three USPSTF members at key points throughout this review, particularly when determining the scope and methods and developing the Analytic Framework and KQs. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.