# 1 Introduction

## Condition Definition

Peripheral artery disease (PAD) is atherosclerotic occlusive disease manifesting in the lower extremities.^1^ While the term PAD is also used more broadly to encompass a larger range of noncoronary arterial diseases,^2^ this review limits the definition of PAD to lower-extremity PAD. Currently, United States Preventive Services Task Force (USPSTF) recommendations and associated systematic reviews on other peripheral arterial diseases include carotid artery stenosis and abdominal aortic aneurysm.^3,4^

The resting ankle-brachial index (ABI) is the most commonly used screening and diagnostic test for PAD. It is defined as the ratio of systolic blood pressure at the ankle to the systolic blood pressure at the brachial artery.^5^ While the term “abnormal ABI” is often used interchangeably with “PAD” in clinical practice and research, this review will differentiate an abnormal ABI from PAD diagnosed by a confirmatory imaging study (i.e., digital subtraction angiography [DSA], computed tomography angiography [CTA], magnetic resonance angiography [MRA], and duplex ultrasound). Terminology definitions are discussed further in the methods section of this report.

## Prevalence

### PAD

Studies on the prevalence of PAD among general populations or unselected primary care populations use a low ABI as a surrogate for PAD. However, since the ABI does not have 100 percent sensitivity and specificity, the true prevalence of PAD in the general population is not known.

### Abnormal ABI

The definition of a low ABI varies across epidemiologic studies, with some studies using a cutoff of less than 0.9 and others using a cutoff of less than or equal to 0.9. The National Health and Nutrition Examination Survey (NHANES) identified the prevalence of a low ABI (≤0.9) from 1999 to 2004; 5.9 percent of the U.S population age 40 years or older had a low ABI, which amounts to 7.1 million people.^6^ Excluding individuals with known coronary artery or cerebrovascular disease, 4.7 percent of the adult U.S. population had a low ABI.^6^ NHANES population screening from 1999—2002 identified asymptomatic disease in two-thirds of U.S. adults age 40 or older with an ABI <0.9.^7^ Among a self-pay vascular screening cohort of over 3.5 million individuals with a mean age of 64 years, the prevalence of a low ABI (<0.9) was 4.1 percent; 54 percent of these individuals reported no intermittent claudication.^8^

The prevalence of a low ABI (<0.9) varies with age, cardiovascular disease (CVD) risk factors, and race/ethnicity. About 1.9 percent of individuals ages 40 to 59 years have a low ABI, 8.1 percent among those ages 60 to 74 years have a low ABI, and 17.5 percent among those ages 75 years or older have a low ABI.^9^ Prevalence increases dramatically with older age and increased cardiovascular risk factors. For example, the prevalence of a low ABI was 29 percent in a sample of 6,979 people who were age 70 years or older or ages 50 to 69 years with a history of smoking or diabetes for U.S. primary care practices.^10^ Prevalence of asymptomatic low ABI was nearly 18 percent in the PANDORA study, which recruited adults with one or more cardiovascular risk factors in addition to age (adults with diabetes were excluded from this study).^11^ Although women have a slightly lower ABI compared with men,^12,^ ^13^ the prevalence of a low ABI does not appear to vary significantly by sex after adjusting for age.^9,^ ^14-17^ PAD prevalence varies by race and ethnicity, with blacks having the highest age-adjusted prevalence of a low ABI.^9,^ ^14,^ ^16-19^ Further discussion of risk factors independently associated with a low ABI in multivariate analysis appears below (see risk factor section).

The prevalence of noncompressible arteries (ABI >1.30 or >1.40) is generally low. Among the NHANES cohort, 3.6 percent had an ABI greater than 1.30 and 1.5 percent had an ABI greater than 1.40.^6^ In other community-based cohorts, 3.9 to 5.5 percent had an ABI greater than 1.30 and 1.1 to 1.2 percent had an ABI greater than 1.4.^20-22^ The prevalence of noncompressible arteries also increases with age and CVD risk factors. For example, in the United States, 6.3 percent of clinic patients who were older than age 70 years, or those ages 50 to 69 years with CVD risk factors, had an ABI greater than 1.40.^22^ While the clinical implications of a high ABI (>1.30 or >1.40) are uncertain, persons with a high ABI are generally older and more likely to have CVD risk factors, particularly diabetes and hypertension.^21-23^ Persons with noncompressible arteries who are suspected of having PAD usually go on to additional diagnostic testing.

The most contemporary prevalence data available are baseline data from two Danish population-based screening trials.^24,^ ^25^ The Viborg Vascular (VIVA) screening trial of Danish men ages 65 to 74 years identified a PAD prevalence of 11 percent in the screening population, where PAD was defined as an ABI <0.9 or >1.4. Two-thirds of identified patients reported no intermittent claudication.^24^ The DANCAVAS screening trial of Danish men and women ages 65 to 74 years reported a PAD prevalence of 19 percent in men and 11 percent in women where PAD was defined as an ABI ≤0.9 or ≥1.4; the proportion reporting symptoms was not reported.^25^

## Burden and Natural History

### Burden

The global burden of PAD has been estimated to be high.^26^ Research has shown that PAD is associated with substantial and statistically significant decrements in health-related quality of life as well as work-related impairments such as absenteeism.^27^ While rates of PAD-related amputations have declined over time,^28^ major lower-extremity amputations are associated with extremely high mortality risk, with about half of patients dying within 1 year.^29^

### Clinical Presentation

PAD may be classified according to its clinical presentation using a Rutherford category or Fontaine staging ranging from asymptomatic PAD to severe disease with associated ulceration or gangrene.^30^ While intermittent claudication is the classically described PAD symptom of calf pain associated with walking and relieved by rest,^31^ other signs and symptoms of PAD include foot pain at rest; numbness, tingling, cyanosis, hair loss, nonhealing ulcers, or gangrene of the lower extremity; functional impairment (e.g., poor walking endurance, poor standing balance, difficulty rising from a seated position); and erectile dysfunction.^2,^ ^30,^ ^32^ It is now understood that the majority of patients with a low ABI may not have classical symptoms of intermittent claudication but may be either asymptomatic or have atypical symptoms.^33^ Atypical symptoms may include leg pain on exertion that sometimes starts at rest and exertional leg pain that does not cause the patient to stop walking (i.e., “leg pain/carry on”).

In studies of community-dwelling populations, of those identified with PAD or a low ABI, approximately 10 percent have symptoms of intermittent claudication, 60 percent are asymptomatic, and 30 percent have atypical symptoms (exertional leg symptoms other than intermittent claudication). In studies of primary care populations, approximately 10 percent have symptoms of intermittent claudication, 30 to 60 percent are asymptomatic, and 50 percent have atypical symptoms.^33^ Consistent with the large proportion of patients who are asymptomatic, an abnormal ABI is underdiagnosed; a community-based PAD detection program found that about half of people found to have an abnormal ABI in primary care were not previously diagnosed.^10^

### Lower-Extremity Outcomes

The extent of atherosclerosis, acuity of limb ischemia, and ability to restore arterial circulation determine the prognosis of the lower extremity in patients with PAD.^2^ For patients with chronic atherosclerosis and progression to symptoms of critical limb ischemia, for example, prognosis for viability of the affected limb is very poor unless it can be revascularized. For patients with acute occlusive events (i.e., thromboembolic occlusion with little underlying atherosclerosis), on the other hand, the prognosis for viability of the limb is related to the rapidity and completeness of revascularization before the onset of irreversible ischemic tissue damage.^2^ A 2016 systematic review found that over 5 years of followup, approximately 7 percent (95% CI, 4 to 11) of patients with asymptomatic PAD developed intermittent claudication and approximately 21 percent (95% CI, 12 to 29) of patients with intermittent claudication progressed to critical limb ischemia.^34^ Recent investigators have posited that patients with PAD may reduce activity levels as a means to manage symptoms, thus the perceived stability of leg symptoms in many patients may conceal objectively measured functional decline associated with PAD.^35^ One cohort study demonstrated that about half of those with asymptomatic low ABI remained asymptomatic over 2 years of followup; however, asymptomatic individuals with a low ABI experienced a dramatically greater annual decline in ambulatory function as measured by the 6-minute walk test compared with those with a normal ABI (-76.8 vs. -8.67 feet).^35^

### CVD Outcomes

Because PAD is a manifestation of systemic atherosclerosis, it is associated with the presence of other CVD (e.g., coronary artery disease [CAD], cerebrovascular disease) and CVD events such as myocardial infarction (MI), cerebrovascular accident (CVA), and death.^18^ Both CAD and cerebrovascular disease are significantly associated with a low ABI (<0.9).^36,^ ^37^ Analysis from the ABI Collaboration individual-patient data meta-analysis of 16 cohorts demonstrated that within each Framingham risk category, those with a low ABI (≤0.90) had about double the 10-year all-cause mortality, cardiovascular mortality, and major coronary event rate compared with the overall rate in a given Framingham risk category.^38^ In general, the risk of mortality due to CVD events in persons with a low ABI and/or claudication is similar to that of persons with a history of CAD or cerebrovascular disease.^5^ A 2016 systematic review found that the 5-year cumulative incidence of cardiovascular mortality in asymptomatic patients with a low ABI was 9 percent (95% CI, 7 to 12) and 13 percent for patients with symptomatic low ABI (95% CI, 9 to 17); this is compared with an incidence of 5 percent (95% CI, 4 to 6) among patients with a normal ABI.^34^

The presence of PAD confers a high risk for cardiovascular events even in the absence of symptoms.^39-42^ Analyses in several general population cohorts with 5 to 7 years of followup that define asymptomatic PAD by an ABI <0.9 or <0.95 suggest that risk for cardiovascular events may be reasonably similar between symptomatic and asymptomatic PAD. An analysis of 6,880 unselected adults age 65 years or older in Germany showed that among those with PAD, the risk of a composite of all-cause death, MI, and CVA was not statistically significantly different for those with and without symptoms (HR 1.18 [95% CI, 0.92 to 1.52]).^40^ However, risk of a composite outcome additionally including lower-extremity peripheral vascular events or any revascularization was statistically significantly higher in those with symptoms (HR 1.48 [95% CI, 1.21 to 1.80]). This composite outcome was driven by peripheral revascularizations, which may have been triggered by symptoms. The presence of PAD conferred high risk for cardiovascular events or all-cause mortality, regardless of symptoms, when compared with adults with no PAD (symptomatic adults HR 1.85 [95% CI, 1.57 to 2.17]; asymptomatic adults HR 1.72 [95% CI, 1.41 to 2.10]). Similarly, an analysis of a Dutch general population cohort of adults ages 40 to 78 years with over 7 years of followup suggests that compared with adults without PAD, asymptomatic PAD is associated with a much higher incidence of fatal cardiovascular disease (35.8 vs 2.3 per 1000 person-years).^41^ Additionally, the prognosis for fatal and nonfatal events was similar in those with symptomatic PAD and those with asymptomatic PAD. For example, compared with those with no PAD, the hazard ratio for fatal CVD was 1.6 (95% CI, 1.0 to 2.5) for those with asymptomatic PAD and 1.5 (95% CI, 1.1 to 2.2) for those with symptomatic PAD. The Edinburgh Artery Study, which is an older study consisting of a Scottish general practice cohort of adults ages 55 to 74 years with 5 years of followup, was generally confirmatory; the relative risk for cardiovascular events was highest among adults with intermittent claudication, but confidence intervals overlapped with individuals categorized as having both major and minor symptomatic PAD.^39^

### Risk Factors

In addition to increasing age, major risk factors for PAD include diabetes, smoking, hypertension, high cholesterol, obesity, and physical inactivity.^43,^ ^44^ ^45^ ^11,^ ^14,^ ^36,^ ^46-49^ Smoking and diabetes show the strongest association with a low ABI in most multivariable analyses; smoking has odds ratios (ORs) ranging from 1.55 (95% confidence interval [CI], 1.34 to 1.79)^11^ to 5.35 (95% CI, 1.77 to 16.22)^46^ and diabetes has ORs ranging from 1.59 (95% CI, 1.00 to 2.51)^49^ to 3.8 (95% CI, 1.6 to 9.0).^47^ Among the Lifeline self-pay vascular screening cohort of over 3.5 million individuals, hypertension (OR 2.26 [95% CI, 2.23 to 2.36]), hyperlipidemia (OR 1.35 [95% CI, 1.34 to 1.37]), and sedentary lifestyle (OR 1.38 [95% CI, 1.37 to 1.39]) were all associated with an increased risk of a low ABI (<0.9) in addition to smoking status and diabetes.^50^

## Rationale for Screening and Screening Strategies

There are two potential reasons to consider PAD screening. First, screening for PAD may lead to early detection and treatment of PAD before clinical presentation, which may slow the progression of atherosclerosis and resultant functional decline. Second, because PAD is considered an important manifestation of systemic atherosclerosis, screening for PAD in asymptomatic persons may lead to early CVD risk-factor modification in persons with undiagnosed atherosclerosis. In addition to its ability to detect PAD, an abnormal ABI may be useful for improving upon the calibration or discrimination of traditional risk-factor models to predict CVD and may appropriately reclassify risk in some individuals, leading to more aggressive medical management.

DSA demonstrating 50 percent or more stenosis is used as the gold standard for evaluating the accuracy of other tests to diagnose PAD.^51^ As an invasive procedure, DSA carries risks for nephrotoxic and hypersensitivity reactions to the contrast medium, as well as for complications from arterial catheter access.^52,^ ^53^ Because of these risks, less invasive angiography (i.e., MRA and CTA) is used in clinical practice for anatomic localization and estimation of degree of stenosis in patients who are candidates for revascularization^54,^ ^55^ The resting ABI is the most commonly used test to screen and detect PAD in clinical settings and is often considered synonymous with PAD.^56^

### Resting ABI

The resting ABI, the ratio of the systolic blood pressure measured over the ankle to the systolic blood pressure measured over the brachial artery,^57^ is the most commonly used screening test for PAD. The systolic blood pressure is measured after the patient has rested for 5 to 10 minutes and is in the supine position,^58^ using a manual sphygmomanometer and a handheld Doppler ultrasound probe,^59^ although specific techniques vary. This variation in measurement protocols (e.g., use of mean vs. highest recorded pressures; manual vs. automated devices) may lead to differences in ABI results.^60-62^ AHA guidance recommends using the highest of the two ankle pressures (dorsalis pedis vs. posterior tibial) in each leg divided by the highest of the brachial pressures (right versus left).^63^ Overall, the ABI is considered to have good reproducibility (variance of about 0.10).^2^

Traditionally, ABI values of 1.00 to 1.3 are considered normal. ABI values of 0.00 to 0.40 indicate severe PAD and 0.41 to 0.90 indicate mild to moderate PAD, values of 0.91 to 0.99 are considered borderline, and values greater than 1.30 indicates noncompressible arteries.^2^ More recent recommendations state that ABI values greater than 1.40 indicate noncompressible arteries and that 1.00 to 1.40 should be considered normal.^32^ While the ABI threshold of ≤0.90 has been widely accepted in clinical practice, the data supporting this single threshold are scant and have been based on different reference criteria in different populations.^63^

### Other Noninvasive Screening or Diagnostic Modalities

Other noninvasive tools used to diagnose or screen for PAD include the postexercise ABI, toe-brachial index, duplex ultrasound, exercise treadmill testing, segmental pressure measurements, pulse volume recordings, and pulse oximetry.^64^

### PAD Symptom Questionnaires

In many epidemiologic surveys, population-based diagnosis and classification have used standardized, symptom-based questionnaires, most commonly the World Health Organization Rose questionnaire or the Edinburgh Modification of the Rose questionnaire. The Walking Impairment Questionnaire and the San Diego claudication questionnaire are more recently developed questionnaires designed for PAD patients to measure their walking limitations.^2^

## Treatment Approaches

The primary aims of treating PAD as a lower extremity disease or treating PAD as a manifestation of systemic atherosclerosis, are to reduce overall CVD morbidity (e.g., MI, CVA), decrease PAD morbidity (e.g., increase walking distance and quality of life by improving symptoms of intermittent claudication and reducing walking impairment, prevent or reduce limb complications, preserve limb viability), and decrease mortality, while minimizing the harms of treatment.^56,^ ^65^ Treatment can be categorized into measures to reduce CVD risk or to improve lower-extremity dysfunction or symptoms. CVD risk reduction includes smoking cessation, cholesterol lowering, blood pressure control, and antiplatelet therapy. Medical treatment of symptoms includes pharmacologic (i.e., cilostazol) and nonpharmacologic (i.e., exercise therapy) interventions, but medications approved by the FDA for PAD are all based on trials of symptomatic patients. Revascularization by angioplasty, thrombolysis, stenting, or bypass surgery is reserved for persons with severe symptomatic PAD.^53,^ ^66^

## Current Clinical Practice in the United States

Administering the ABI takes about 15 minutes in primary care practices,^2^ although it is often performed in specialty settings (e.g., radiology, vascular labs). A survey of primary care practices across the United States found that nearly 70 percent of providers reported never using the ABI in their practice settings, 6 to 8 percent reported using the ABI annually, and 12 to 13 percent reported using the ABI weekly or monthly.^67^ A recent analysis of Medicare administrative data shows that noninvasive testing (the ABI, pulse volume recordings, segmental BP, bidirectional Doppler) and duplex ultrasound rates increased from 2001 to 2013 by 63 percent and 88 percent, respectively, with the greatest growth in specialty settings, although indication for testing was not specified.^68^

### Professional Organization Guidelines

Based on evidence from a 2015 systematic review,^69^ the Society for Vascular Surgery recommended against routine screening for lower-extremity PAD in the absence of risk factors, history, or signs or symptoms of PAD. However, the guidelines state that for asymptomatic individuals at elevated risk (i.e., those over age 70, smokers, diabetic patients, those with an abnormal pulse examination or other established CVD), screening for PAD may be reasonable if used to improve risk stratification, preventive care, and medical management.^56^ Similarly, joint recommendations from the American Heart Association and American College of Cardiology Foundation in 2016 recommended against PAD screening in adults who are not at increased risk and do not have a history or physical examination findings suggestive of PAD, but stated that such screening is reasonable in patients at increased risk of PAD (defined as those 65 years or older; those ages 50 to 64 years with risk factors for atherosclerosis, to include diabetes, history of smoking, hyperlipidemia, hypertension, or family history of PAD; those younger than 50 years old with diabetes and one other risk factor for atherosclerosis; or those with known atherosclerotic disease in another vascular bed)^65,^ ^70^ (Table 1).

Table 1 Recommendations Of Other Organizations For Screening For PAD With The ABI In Individuals Without History Or Physical Examination Findings Suggestive Of PAD

| | ESC 2017^154^ | AHA/ACC 2016^65^ | SVS 2015^56^ | USPSTF 2013^73^ | AAFP 2017^155^ | NICE 2012^156^ | ACPM 2011^157^
Asymptomatic adults with no risks | Population | NA | Adults not at increased risk of PAD and without history or physical examination findings suggestive of PAD | Adults with the absence of risk factors, history, signs, or symptoms of PAD | Adults with no known diagnosis of PAD, CVD, severe CKD, or DM | Endorses USPSTF 2013 | NA | Adults
Asymptomatic adults with no risks | Recommendation (Grade) | NA | No (Class III: No benefit; B-NR)^*^ | No (2;C)^†^ | No (I statement)^‡^ | No (I statement)^‡^ | NA | No (NA)
Asymptomatic adults with elevated risks | Population | Aged >65 y; Aged <65 y classified at high CVD risk according to ESC guidelines; aged >50 y with family history; known n atherosclerotic disease (CAD, any PAD), AAA, CKD, heart failure | Aged ≥65 y; Age 50-64 y with risk factors for atherosclerosis (e.g., DM, history of smoking, hyperlipidemia, hypertension) or family history of PAD; Age <50 y with DM and 1 other risk factor for atherosclerosis; know n atherosclerotic disease in another vascular bed (e.g., coronary, carotid, subclavian, renal, mesenteric artery stenosis, or AAA) | Aged >70 y, smokers, DM; abnormal pulse examination; or other established CVD | NA | Endorses USPSTF 2013 | Adults ≥ 18 y; symptoms suggestive of PAD or DM, nonhealing wounds on legs or feet or unexplained leg pain or considered for interventions to the leg or foot or need to use compression hosiery | >50 y, smokers, and DM and with clinical evidence of vascular disease
Asymptomatic adults with elevated risks | Recommendation (Grade) | NR | Yes, reasonable (Class IIa, B-NR)^§^ | Yes, reasonable (2; C)^†^ | NA | No (I statement)^‡^ | Yes, suspected PAD (NA) | NA

* Class of recommendation: Class III indicates no benefit where benefit=risk (moderate strength) and level B quality of evidence (nonrandomized designs)

† Defined as weak recommendation based on low-quality or very-low-quality evidence

‡ statement is insufficient to assess the balance of benefits and harms of service

§ Class of recommendation: Class IIa indicates moderate benefit where benefit >>risk (moderate strength) and level B quality of evidence (nonrandomized designs)

Abbreviations: AAA = abdominal aortic aneurysm; ABI = ankle-brachial index; ACMP = American College of Preventive Medicine; AHA/ACC = American Heart Association and American College of Cardiology; CKD = chronic kidney disease; CVD = cardiovascular disease; AAFP = American Academy of Family Physicians; DM = diabetes mellitus; ESC = European Society of Cardiology; NA = not applicable; NR = not reported; SVS = Society for Vascular Surgery; USPSTF = United States Preventive Services Task Force; y = year(s)

The 2013 joint AHA/ACC guideline on assessment of cardiovascular risk stated that the use of the ABI could be considered to inform decisionmaking if a risk-based treatment decision was uncertain after quantitative risk assessment. This recommendation was based on expert opinion.^71^ The American Academy of Family Physicians (AAFP) adopted the 2013 Task Force recommendation that current evidence was insufficient to assess the balance of benefits and harms of screening for PAD and CVD risk assessment with the ABI in adults.^72^

## Previous USPSTF Recommendation

In 2013, the USPSTF concluded that evidence was insufficient to assess the balance of benefits and harms of screening for PAD and CVD risk assessment with the ABI in asymptomatic adults. (I statement)^73^