# Appendix D Ongoing Studies

Study Reference Trial Identifier | Study Name | Location | Estimated N | Description | 2017 Status
ISRCTN12157806 (http://www.isrctn.com/ISRCTN12157806) | The Danish Cardiovascular Screening Trial (DANCAVAS) | Denmark | 45,000 (men) | Population-based, randomized trial to evaluate the health benefits and cost-effectiveness of using noncontrast computer tomography scans (to measure coronary artery calcification (CAC) and identify aortic/iliac aneurysms) and measurements of the ankle-brachial blood pressure index (ABI) as part of a multifocal screening and intervention program for CVD in men aged 65 to 74 years. | Ongoing: Est Interim Publication Date 2018; Completion Date Jan 2026
NCT03228459 (https://clinicaltrials.gov/show/NCT03228459) (Protocol (http://doi.org/10.1016/j.nefro.2016.02.008)) (Project page (http://www.elbusdelasalut.cat/inici)) | Randomized intervention study to assess the prevalence of subclinical vascular disease and hidden kidney disease and its impact on morbidity and mortality: The ILERVAS project | Spain | 14,600 | Adults 45 to 70 years without previous history of CVD and with ≥1 CVD risk factor will be randomly selected from the primary health care centers across the province of Lérida. The following baseline tests will be given to the intervention group in a mobile screening unit: artery ultrasound (carotid, femoral, transcranial and abdominal aorta); the ABI; spirometry; determination of advanced glycation end products; dried blood spot and urine spot tests. | Ongoing: Est Data Collection Completion Date 2017; Followup through 2027
ACTRN 12614000592640 (https://www.anzctr.org.au/Trial/Registration/TrialReview.aspx?id=366284&isReview=true) (Protocol (https://www.ncbi.nlm.nih.gov/pubmed/27829449)) | Effect of a brief behavioural counselling intervention on physical activity behaviour in people with peripheral artery disease. | Australia | 200 | Multicenter RCT in four cities across Australia; participants (N = 200) will be recruited from specialist vascular clinics, general practitioners and research databases. This trial will assess the efficacy of a brief behavioral counselling intervention delivered by allied health professionals to improve physical activity in persons with PAD. | Ongoing: Est Data Collection Completion Date NR
NCT01321086 (https://clinicaltrials.gov/ct2/show/NCT01321086) | Motivational Interviewing (MI) for African Americans With Peripheral Arterial Disease (PAD) | U.S. | 174 | Clinical research trial to determine the role of motivational interviewing on promoting home-based walking therapy to improve walking ability in African Americans with PAD (ABI <0.995). Quality of life, measured with the SF-12 and VascQOL questionnaires, is a prespecified secondary outcome. | Completed Nov 2016; not yet published
NCT00537225 (https://clinicaltrials.gov/ct2/show/NCT00537225) | Multifactor Risk Reduction for Optimal Management of PAD (VIGOR2) | U.S. | 300 | To examine effectiveness of a long-term multifactor CVD risk reduction program (HEAR2T) vs. enhanced standard care on walking and quality of life in patients with PAD. | Ongoing: Est Completion Date Jun 2018
NCT02622282 (https://clinicaltrials.gov/ct2/show/NCT02622282) | Text Messaging to Promote Walking Among Latino Adults at Risk for Peripheral Arterial Disease | U.S. | 69 | The purpose of this study is to learn about the impact of text messaging on physical activity in persons with risk factors for PAD. Quality of life is a prespecified secondary outcome. | Completed Dec 2016; not yet published

Abbreviations: Est = estimated; Jan = January; Jul = July; Jun = June, Nov=November, Dec=December; PAD = peripheral artery disease; RCT = randomized controlled trial; Sept = September; U.S. = United States