# Appendix C Excluded Studies

Reason for Exclusion
E1. | Aim
E2. | Population
E2a. | Patients with symptomatic PAD
E2b. | Exclusively persons with known CVD
E3. | Outcomes
E4. | Poor quality
*E4c. | Poor quality: Does not use reference standard
E5. | Setting (hospital, inpatient, long-term care, vascular clinics)
E6. | Not an included study design
*E6a. | Study design: case control (applies to KQ2 only)
†E6b. | Study design: followup from baseline < 3 months (12 weeks)
E7. | Intervention
*E7a. | Not a study of the ABI
†E7b. | Not an included treatment
†E7c. | Comparative effectiveness

* Screening-specific exclusion codes

† Treatment-specific exclusion codes

Abbreviations: ABI = ankle-brachial index; CVD = cardiovascular disease; PAD = peripheral artery disease

1 Aerden D, Massaad D, von KK, . The ankle-brachial index and the diabetic foot: a troublesome marriage. Ann Vasc Surg. 2011;25(6):770-7. PMID: 21514102. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.21514102
2 Alavi A, Sibbald RG, Nabavizadeh R, . Audible handheld Doppler ultrasound determines reliable and inexpensive exclusion of significant peripheral arterial disease. Vascular. 2015;23(6):622-9. PMID: 25628222. KQ1E1, KQ2E4c, KQ3E1, KQ4E1, KQ5E1.25628222
3 Allen J, Oates CP, Henderson J, . Comparison of lower limb arterial assessments using color-duplex ultrasound and ankle/brachial pressure index measurements. Angiology. 1996;47(3):225-32. PMID: 8638864. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.8638864
4 Alnaeb ME, Crabtree VP, Boutin A, . Prospective assessment of lower-extremity peripheral arterial disease in diabetic patients using a novel automated optical device. Angiology. 2007;58(5):579-85. PMID: 18024941. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.18024941
5 Aronow WS, Nayak D, Woodworth S, . Effect of simvastatin versus placebo on treadmill exercise time until the onset of intermittent claudication in older patients with peripheral arterial disease at six months and at one year after treatment. Am J Cardiol. 2003;92(6):711-2. PMID: 12972114. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.12972114
6 Aubert CE, Cluzel P, Kemel S, . Influence of peripheral vascular calcification on efficiency of screening tests for peripheral arterial occlusive disease in diabetes--a cross-sectional study. Diabet Med. 2014;31(2):192-9. PMID: 23952656. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.23952656
7 Auteri A, Angaroni A, Borgatti E, . Triflusal in the treatment of patients with chronic peripheral arteriopathy: multicentre double-blind clinical study vs placebo. Int J Clin Pharmacol Res. 1995;15(2):57-63. PMID: 8593974. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.8593974
8 Baltic A, Baljic R, Radjo I, . Health Effects of the Programmed Physical Activities on Lipid Profile in Peripheral Arterial Disease of the Lower Extremities. Med Arh. 2015;69(5):311-4. PMID: 26622083. KQ1E1, KQ2E1, KQ3E1, KQ4E5, KQ5E5.26622083
9 Barone Gibbs B, Dobrosielski DA, Althouse AD, . The effect of exercise training on ankle-brachial index in type 2 diabetes. Atherosclerosis. 2013;230(1):125-30. PMID: 23958264. KQ1E1, KQ2E1, KQ3E1, KQ4E3, KQ5E3.23958264
10 Burton NW, Ademi Z, Best S, . Efficacy of brief behavioral counselling by allied health professionals to promote physical activity in people with peripheral arterial disease (BIPP): study protocol for a multi-center randomized controlled trial. BMC Public Health. 2016;16(1):1148. PMID: 27829449. KQ1E1, KQ2E1, KQ3E1, KQ4E2, KQ5E2.27829449
11 Campens L, Backer T, Simoens S, . Accuracy of oscillometric determination of the anklebrachial index as screening method for peripheral artery disease. Acta cardiologica. 2012;67(1):136-7. PMID: None. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.
12 Catalano M, Born G, Peto R. Prevention of serious vascular events by aspirin amongst patients with peripheral arterial disease: randomized, double-blind trial. J Intern Med. 2007;261(3):276-84. PMID: 17305650. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.17305650
13 Clairotte C, Retout S, Potier L, . Automated ankle-brachial pressure index measurement by clinical staff for peripheral arterial disease diagnosis in nondiabetic and diabetic patients. Diabetes Care. 2009;32(7):1231-6. PMID: 19366974. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.19366974
14 Coe ER. Screening for peripheral arterial disease in a rural community health setting. J Vasc Nurs. 2014;32(4):137-8. PMID: 25455318. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.25455318
15 Collins EG, O'Connell S, McBurney C, . Comparison of walking with poles and traditional walking for peripheral arterial disease rehabilitation. J Cardiopulm Rehabil Prev. 2012;32(4):210-8. PMID: 22595894. KQ1E1, KQ2E1, KQ3E1, KQ4E7c, KQ5E7c.22595894
16 Collins T, editor. Home-based walking therapy improves walking ability and quality of life in patients with diabetes mellitus and peripheral arterial disease. 33rd Annual Meeting of the Society of General Internal Medicine; 2010 Apr 28-May 1; Minneapolis, MN (US). PREVDB Targeted Search: J Gen Intern Med; ABSTRACT ONLY. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.
17 Collins TC, Krueger PN, Kroll TL, . Faceto-face interaction compared with video watching on use of physical activity in peripheral arterial disease: a pilot trial. Angiology. 2009;60:21-30. PMID: 18586757. KQ1E1, KQ2E1, KQ3E1, KQ4E7c, KQ5E7c.18586757
18 Collins TC, Lunos S, Carlson T, . Effects of a home-based walking intervention on mobility and quality of life in people with diabetes and peripheral arterial disease: a randomized controlled trial. Diabetes Care. 2011;34(10):2174-9. PMID: 21873560. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.21873560
19 Dedes H, Figoni SF, Kalioundji G, . Prospective Trial of Calf Ergometry Training on Walking Ability in Peripheral Arterial Disease. Phys Med Rehab. 2010;2(9 (Suppl 1)):S26. PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.
20 Domanchuk K, Ferrucci L, Guralnik JM, . Progenitor cell release plus exercise to improve functional performance in peripheral artery disease: the PROPEL Study. Contemp Clin Trials. 2013;36(2):502-9. PMID: 24080099. KQ1E1, KQ2E1, KQ3E1, KQ4E3, KQ5E3.24080099
21 Elam MB, Hunninghake DB, Davis KB, . Effect of niacin on lipid and lipoprotein levels and glycemic control in patients with diabetes and peripheral arterial disease: the ADMIT study: A randomized trial. Arterial Disease Multiple Intervention Trial. JAMA. 2000;284(10):1263-70. PMID: 10979113. KQ1E1, KQ2E1, KQ3E1, KQ4E3, KQ5E2a.10979113
22 Esteghamati A, Aflatoonian M, Rad MV, . Association of osteoprotegerin with peripheral artery disease in patients with type 2 diabetes. Arch Cardiovasc Dis. 2015;108(8-9):412-9. PMID: 26184866. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.26184866
23 Feigelson HS, Criqui MH, Fronek A, . Screening for peripheral arterial disease: the sensitivity, specificity, and predictive value of noninvasive tests in a defined population. Am J Epidemiol. 1994;140(6):526-34. PMID: 8067346. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.8067346
24 Fowler B, Jamrozik K, Norman P, . Prevalence of peripheral arterial disease: persistence of excess risk in former smokers. Aust N Z J Public Health. 2002;26(3):219-24. PMID: 12141616. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.12141616
25 Franz RW, Garwick T, Haldeman K. Initial results of a 12-week, institution-based, supervised exercise rehabilitation program for the management of peripheral arterial disease. Vascular. 2010;18(6):325-35. PMID: 20979920. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.20979920
26 Girleanu I, Alexandrescu DM, Petris A, . Barriers of antiaggregant treatment. Rev Med Chir Soc Med Nat Iasi. 2014;118(2):333-8. PMID: 25076696. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E2.25076696
27 Gouveri E, Papanas N, Marakomichelakis G, . Post-exercise ankle-brachial index is not an indispensable tool for the detection of peripheral arterial disease in an epidemiological survey. A post-hoc analysis of the Athens Study. International angiology: a journal of the International Union of Angiology. 2013;32(5):518-25. PMID: 23903312. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.23903312
28 Guidon M, McGee H. One-year effect of a supervised exercise programme on functional capacity and quality of life in peripheral arterial disease. Disabil Rehabil. 2013;35(5):397-404. PMID: 22804715. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.22804715
29 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002;360(9326):7-22. PMID: 12114036. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.12114036
30 Heikkila A, Venermo M, Kautiainen H, . Physical Activity Improves Borderline AnkleBrachial Index Values in a Cardiovascular Risk Population. Ann Vasc Surg. 2016;32:50-6. PMID: 26806230. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26806230
31 Herraiz-Adillo A, Martinez-Vizcaino V, CaveroRedondo I, . Diagnostic Accuracy Study of an Oscillometric Ankle-Brachial Index in Peripheral Arterial Disease: The Influence of Oscillometric Errors and Calcified Legs. PLoS ONE. 2016;11(11):e0167408. PMID: 27898734. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.27898734
32 Hiatt WR, Rogers RK, Brass EP. The treadmill is a better functional test than the 6-minute walk test in therapeutic trials of patients with peripheral artery disease. Circulation. 2014;130(1):69-78. PMID: 24982118. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24982118
33 Hope Study I. The HOPE (Heart Outcomes Prevention Evaluation) Study: the design of a large, simple randomized trial of an angiotensinconverting enzyme inhibitor (ramipril) and vitamin E in patients at high risk of cardiovascular events. The HOPE study investigators. Can J Cardiol. 1996;12(2):127-37. PMID: 8605634. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.8605634
34 Ichihashi S, Hashimoto T, Iwakoshi S, . Validation study of automated oscillometric measurement of the ankle-brachial index for lower arterial occlusive disease by comparison with computed tomography angiography. Hypertens Res. 2014;37(6):591-4. PMID: 24599013. KQ1E1, KQ2E2a, KQ3E2a, KQ4E1, KQ5E1.24599013
35 Igari K, Kudo T, Uchiyama H, . Intraarterial injection of indocyanine green for evaluation of peripheral blood circulation in patients with peripheral arterial disease. Ann Vasc Surg. 2014;28(5):1280-5. PMID: 24583370. KQ1E1, KQ2E2a, KQ3E2a, KQ4E1, KQ5E1.24583370
36 Jahn J, Zimmermann W, Moysidis T, . Ankle brachial index and pneumoplethysmographic pulse-volume recordings for detection of peripheral arterial disease. Vasa. 2014;43(3):202-8. PMID: 24797052. KQ1E1, KQ2E2a, KQ3E2a, KQ4E1, KQ5E1.24797052
37 Jamrozik K, Norman PE, Spencer CA, . Screening for abdominal aortic aneurysm: lessons from a population-based study. Med J Aust. 2000;173(7):345-50. PMID: 11062788. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.11062788
38 Jeevanantham V, Chehab B, Austria E, . Comparison of accuracy of two different methods to determine ankle-brachial index to predict peripheral arterial disease severity confirmed by angiography. Am J Cardiol. 2014;114(7):1105-10. PMID: 25129876. KQ1E1, KQ2E2a, KQ3E2a, KQ4E1, KQ5E1.25129876
39 Jeon CH, Han SH, Chung NS, . The validity of ankle-brachial index for the differential diagnosis of peripheral arterial disease and lumbar spinal stenosis in patients with atypical claudication. Eur Spine J. 2012;21(6):1165-70. PMID: 22105308. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.22105308
40 Johnsen MC, Landow WJ, Sonnefeld J, . Evaluation of Legs For Life National Screening and Awareness Program for Peripheral Vascular Disease: results of a follow-up survey of screening participants. J Vasc Interv Radiol. 2002;13(1):25-35. PMID: 11788690. KQ1E3, KQ2E3, KQ3E3, KQ4E1, KQ5E1.11788690
41 Kumbhani DJ, Steg PG, Cannon CP, . Adherence to secondary prevention medications and four-year outcomes in outpatients with atherosclerosis. Am J Med. 2013;126(8):693-700.e1. PMID: 23800583. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E3.23800583
42 Kvist T, Lindholt J, Rasmussen L, . The DanCavas Pilot Study of Multifaceted Screening for Subclinical Cardiovascular Disease in Men and Women Aged 65-74 Years. Eur J Vasc Endovasc Surg. 2017;53(1):123-31. PMID: 27890524. KQ1E3, KQ2E1, KQ3E3, KQ4E1, KQ5E1.27890524
43 Kwon JN, Lee WB. Utility of digital pulse oximetry in the screening of lower extremity arterial disease. J Korean Surg Soc. 2012;82(2):94-100. PMID: 22347711. KQ1E1, KQ2E2a, KQ3E2a, KQ4E1, KQ5E1.22347711
44 Lewis JE, Owens DR. The pulse volume recorder as a measure of peripheral vascular status in people with diabetes mellitus. Diabetes Technol Ther. 2010;12(1):75-80. PMID: 20082588. KQ1E1, KQ2E4, KQ3E4, KQ4E1, KQ5E1.20082588
45 Lewis JE, Williams P, Davies JH. Non-invasive assessment of peripheral arterial disease: Automated ankle brachial index measurement and pulse volume analysis compared to duplex scan. SAGE Open Med. 2016;4:2050312116659088. PMID: 27493755. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.27493755
46 Lindholt JS, Søgaard R. Population screening and intervention for vascular disease in Danish men (VIVA): a randomised controlled trial. Lancet. 2017;[Epub ahead of print]. PMID: 28859943. KQ1E7, KQ2E1, KQ3E7, KQ4E1, KQ5E1.28859943
47 Londero LS, Lindholt JS, Thomsen MD, . Pulse palpation is an effective method for population-based screening to exclude peripheral arterial disease. J Vasc Surg. 2016;63(5):1305-10. PMID: 26947795. KQ1E3, KQ2E4c, KQ3E3, KQ4E1, KQ5E1.26947795
48 Lyu X, Li S, Peng S, . Intensive walking exercise for lower extremity peripheral arterial disease: A systematic review and meta-analysis. J Diabetes. 2016;8(3):363-77. PMID: 25940390. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.25940390
49 Mancera-Romero J, Rodriguez-Morata A, Angel Sanchez-Chaparro M, . Role of an intermittent claudication questionnaire for the diagnosis of PAD in ambulatory patients with type 2 diabetes. Int Angiol. 2013;32(5):512-7. PMID: 23903311. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.23903311
50 Mancini M, Di DO, Saldalamacchia G, . Contrast-enhanced ultrasound evaluation of peripheral microcirculation in diabetic patients: effects of cigarette smoking. Radiol Med. 2013;118(2):206-14. PMID: 22580811. KQ1E1, KQ2E2a, KQ3E2a, KQ4E1, KQ5E1.22580811
51 Mani V, Wong SK, Sawit ST, . Relationship between particulate matter exposure and atherogenic profile in “Ground Zero” workers as shown by dynamic contrast enhanced MR imaging. Int J Cardiovasc Imaging. 2013;29(4):827-33. PMID: 23179748. KQ1E2, KQ2E2, KQ3E2, KQ4E2, KQ5E2.23179748
52 Mannarino E, Pasqualini L, Menna M, . Effects of physical training on peripheral vascular disease: a controlled study. Angiology. 1989;40(1):5-10. PMID: 2642671. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.2642671
53 McDermott M, Criqui M, Domanchuk K, . A home-based exercise intervention significantly improves walking performance in peripheral arterial disease: One-year follow-up from a randomized controlled trial. Circulation. 2013;128(22 suppl. 1). PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.
54 McDermott M, Criqui M, Domanchuk K, . Home-based exercise improves walking speed and prevents mobility loss in peripheral artery disease: A randomized controlled trial. Circulation. 2014;130. PMID: None. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.
55 McDermott MM, Ades P, Guralnik JM, . Treadmill exercise and resistance training in patients with peripheral arterial disease with and without intermittent claudication: a randomized controlled trial. JAMA. 2009;301(2):165-74. PMID: 19141764. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.19141764
56 McDermott MM, Carroll TJ, Kibbe M, . Proximal superficial femoral artery occlusion, collateral vessels, and walking performance in peripheral artery disease. JACC Cardiovasc Imaging. 2013;6(6):687-94. PMID: 23647796. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.23647796
57 McDermott MM, Domanchuk K, Liu K, . The Group Oriented Arterial Leg Study (GOALS) to improve walking performance in patients with peripheral arterial disease. Contemp Clin Trials. 2012;33(6):1311-20. PMID: 23158112. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.23158112
58 McDermott MM, Guralnik JM, Criqui MH, . Unsupervised exercise and mobility loss in peripheral artery disease: a randomized controlled trial. J Am Heart Assoc. 2015;4(5). PMID: 25994445. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.25994445
59 McDermott MM, Guralnik JM, Criqui MH, . Home-based walking exercise in peripheral artery disease: 12-month follow-up of the GOALS randomized trial. J Am Heart Assoc. 2014;3(3):e000711. PMID: 24850615. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.24850615
60 McDermott MM, Guralnik JM, Greenland P, . Statin use and leg functioning in patients with and without lower-extremity peripheral arterial disease. Circulation. 2003;107(5):757-61. PMID: 12578881. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.12578881
61 McDermott MM, Liu K, Carroll TJ, . Superficial femoral artery plaque and functional performance in peripheral arterial disease: walking and leg circulation study (WALCS III). JACC Cardiovasc Imaging. 2011;4(7):730-9. PMID: 21757163. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.21757163
62 McDermott MM, Liu K, Guralnik JM, . Home-based walking exercise intervention in peripheral artery disease: a randomized clinical trial. JAMA. 2013;310(1):57-65. PMID: 23821089. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.23821089
63 McDermott MM, Mazor KM, Reed G, . Attitudes and behavior of peripheral arterial disease patients toward influencing their physician's prescription of cholesterol-lowering medication. Vasc Med. 2010;15(2):83-90. PMID: 20118170. KQ1E1, KQ2E1, KQ3E1, KQ4E3, KQ5E3.20118170
64 McDermott MM, Reed G, Greenland P, . Activating peripheral arterial disease patients to reduce cholesterol: a randomized trial. Am J Med. 2011;124(6):557-65. PMID: 21605733. KQ1E1, KQ2E1, KQ3E1, KQ4E3, KQ5E3.21605733
65 McDermott MM, Tiukinhoy S, Greenland P, . A pilot exercise intervention to improve lower extremity functioning in peripheral arterial disease unaccompanied by intermittent claudication. J Cardiopulm Rehabil. 2004;24:187-96. PMID: 15235301. KQ1E1, KQ2E1, KQ3E1, KQ4E4, KQ5E4.15235301
66 Meade T, For the British Medical Research Council General Practice Research Framework and participating vascular clinics. Design and intermediate results of the Lower Extremity Arterial Disease Event Reduction (LEADER)* trial of bezafibrate in men with lower extremity arterial disease. Curr Control Tials Cardiovasc Med. 2001;2(4):195-204. PMID: 11806795. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.11806795
67 Meade T, Zuhrie R, Cook C, . Bezafibrate in men with lower extremity arterial disease: randomised controlled trial. BMJ. 2002;325(7373):1139. PMID: 12433762. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.12433762
68 Mehler PS, Coll JR, Estacio R, . Intensive blood pressure control reduces the risk of cardiovascular events in patients with peripheral arterial disease and type 2 diabetes. Circulation. 2003;107(5):753-6. PMID: 12578880. KQ1E1, KQ2E1, KQ3E1, KQ4E4, KQ5E4.12578880
69 Mehlsen J, Wiinberg N, Bruce C. Oscillometric blood pressure measurement: a simple method in screening for peripheral arterial disease. Clin Physiol Funct Imaging. 2008;28(6):426-9. PMID: 18803641. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.18803641
70 Mohler ER, III, Bundens W, Denenberg J, . Progression of asymptomatic peripheral artery disease over 1 year. Vasc Med. 2012;17(1):10-6. PMID: 22363014. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.22363014
71 Mohler ER, 3rd, Hiatt WR, Gornik HL, . Sodium nitrite in patients with peripheral artery disease and diabetes mellitus: safety, walking distance and endothelial function. Vasc Med. 2014;19(1):9-17. PMID: 24363302. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.24363302
72 Muntendam P, McCall C, Sanz J, . The BioImage Study: novel approaches to risk assessment in the primary prevention of atherosclerotic cardiovascular disease--study design and objectives. Am Heart J. 2010;160(1):49-57.e1. PMID: 20598972. KQ1E3, KQ2E1, KQ3E1, KQ4E1, KQ5E1.20598972
73 Niazi K, Khan T, Easley K. Diagnostic utility of the two methods of ankle brachial index in the detection of peripheral arterial disease of lower extremities. Catheter Cardiovasc Interv. 2006;68(5):788-92. PMID: 17039537. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.17039537
74 Oesterling C, Kalia A, Chetcuti T, . Atypical leg symptoms: does routine measurement of the ankle brachial pressure index (ABPI) in primary care benefit patients? London J Prim Care (Abingdon). 2015;7(5):97-102. PMID: 26681981. KQ1E3, KQ2E3, KQ3E3, KQ4E1, KQ5E1.26681981
75 Oka RK, Conte MS, Owens CD, . Efficacy of optimal long-term management of multiple cardiovascular risk factors (CVD) on walking and quality of life in patients with peripheral artery disease (PAD): protocol for randomized controlled trial. Vasc Med. 2012;17(1):17-28. PMID: 22363015. KQ1E1, KQ2E1, KQ3E1, KQ4E3, KQ5E3.22363015
76 Patel M, Jones W. Peripheral Artery Disease Therapies May Perform Differently in Practice Than in Randomized Trials the Need for Learning Health Systems. JACC Cardiovascular interventions. 2016. PMID: 27056312. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.27056312
77 Patru S, Bighea AC, Popescu R. Remission of Walking Parameters in Peripheral Arterial Disease through Association of Galvanic Baths and Kinesytherapy. Curr Health Sci J. 2014;40(1):51-6. PMID: 24791206. KQ1E1, KQ2E1, KQ3E1, KQ4E5, KQ5E5.24791206
78 Premanath M, Raghunath M. Ankle-Brachial index by oscillometry: A very useful method to assess peripheral arterial disease in diabetes. Int J Diabetes Dev Ctries. 2010;30(2):97-101. PMID: 20535314. KQ1E1, KQ2E5, KQ3E5, KQ4E1, KQ5E1.20535314
79 Prevost A, Lafitte M, Pucheu Y, . Education and home based training for intermittent claudication: functional effects and quality of life. Eur J Prev Cardiol. 2015;22(3):373-9. PMID: 24177266. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.24177266
80 Quirk F, Dickinson C, Baune B, . Pilot trial of motivational interviewing in patients with peripheral artery disease. International angiology: a journal of the International Union of Angiology. 2012;31(5):468-73. PMID: 22990510. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.22990510
81 Ramos R, García-Gil M, Comas-Cufí M, . Statins for Prevention of Cardiovascular Events in a Low-Risk Population With Low Ankle Brachial Index. J Am Coll Cardiol. 2016;67(6):630-40. PMID: 26868687. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.26868687
82 Rejeski WJ, Spring B, Domanchuk K, . A group-mediated, home-based physical activity intervention for patients with peripheral artery disease: effects on social and psychological function. J Transl Med. 2014;12:29. PMID: 24467875. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.24467875
83 Ren S, Qian S, Wang W, . Prospective study of sarpogrelate hydrochloride on patients with arteriosclerosis obliterans. Ann Thorac Cardiovas Surg. 2013;19(1):30-4. PMID: 23364237. KQ1E1, KQ2E1, KQ3E1, KQ4E2, KQ5E2.23364237
84 Ro du H, Moon HJ, Kim JH, . Photoplethysmography and continuous-wave Doppler ultrasound as a complementary test to ankle-brachial index in detection of stenotic peripheral arterial disease. Angiology. 2013;64(4):314-20. PMID: 23162005. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.23162005
85 Roitman JL. Literature Update-Selected abstracts from recent publications in cardiopulmonary disease prevention and rehabilitation: Treadmill exercise and resistance training in patients with peripheral arterial disease with and without in intermittent claudication: A randomized controlled trial. J Cardiopulm Rehabil Prev. 2010;30:62. PMID: None. KQ1E6, KQ2E6, KQ3E6, KQ4E6, KQ5E6.
86 Ruiz-Canela M, Estruch R, Corella D, . Association of Mediterranean diet with peripheral artery disease: The PREDIMED randomized trial. JAMA. 2014;311(4):415-7. PMID: 24449321. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.24449321
87 Schroder F, Diehm N, Kareem S, . A modified calculation of ankle-brachial pressure index is far more sensitive in the detection of peripheral arterial disease. J Vasc Surg. 2006;44(3):531-6. PMID: 16950430. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.16950430
88 Shirasu T, Hoshina K, Akagi D, . Pulse volume recordings to identify falsely elevated ankle brachial index. Asian Cardiovasc Thorac Ann. 2016. PMID: 27230517. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.27230517
89 Soejima H, Morimoto T, Saito Y, . Aspirin for the primary prevention of cardiovascular events in patients with peripheral artery disease or diabetes mellitus. Analyses from the JPAD, POPADAD and AAA trials. Thromb Haemost. 2010;104(6):1085-8. PMID: 20941462. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.20941462
90 SoRelle R. Keeping the pressure down in patients with type 2 diabetes and peripheral artery disease. Circulation. 2003;107(5):E9008-E9. PMID: 12578895. KQ1E1, KQ2E1, KQ3E1, KQ4E6, KQ5E6.12578895
91 Span M, Gersak G, Millasseau SC, . Detection of peripheral arterial disease with an improved automated device: comparison of a new oscillometric device and the standard Doppler method. Vasc Health Risk Manag. 2016;12:305-11. PMID: 27536125. KQ1E1, KQ2E4c, KQ3E4c, KQ4E1, KQ5E1.27536125
92 Suzuki E, Egawa K, Nishio Y, . Prevalence and major risk factors of reduced flow volume in lower extremities with normal ankle-brachial index in Japanese patients with type 2 diabetes. Diabetes Care. 2003;26(6):1764-9. PMID: 12766107. KQ1E1, KQ2E1, KQ3E1, KQ4E1, KQ5E1.12766107
93 Tehan P, Bray A, Keech R, . Sensitivity and Specificity of the Toe-Brachial Index for Detecting Peripheral Arterial Disease: Initial Findings. J Ultrasound Med. 2015;34(10):1737-43. PMID: 26307119. KQ1E1, KQ2E5, KQ3E5, KQ4E1, KQ5E1.26307119
94 Tehan PE, Bray A, Chuter VH. Non-invasive vascular assessment in the foot with diabetes: sensitivity and specificity of the ankle brachial index, toe brachial index and continuous wave Doppler for detecting peripheral arterial disease. J Diabetes Complications. 2016;30(1):155-60. PMID: 26281971. KQ1E1, KQ2E5, KQ3E5, KQ4E1, KQ5E1.26281971
95 Tehan PE, Chuter VH. A targeted screening method for non-invasive vascular assessment of the lower limb. J Foot Ankle Res. 2016;9:48. PMID: 27980685. KQ1E1, KQ2E7, KQ3E7, KQ4E1, KQ5E1.27980685
96 Wang J, Zhou S, Bronks R, . Supervised exercise training combined with ginkgo biloba treatment for patients with peripheral arterial disease. Clin Rehabil. 2007;21:579-86. PMID: 17702699. KQ1E1, KQ2E1, KQ3E1, KQ4E2a, KQ5E2a.17702699
97 Williams DT, Harding KG, Price P. An evaluation of the efficacy of methods used in screening for lower-limb arterial disease in diabetes. Diabetes Care. 2005;28(9):2206-10. PMID: 16123491. KQ1E1, KQ2E2, KQ3E2, KQ4E1, KQ5E1.16123491
98 Wukich DK, Shen W, Raspovic KM, . Noninvasive Arterial Testing in Patients With Diabetes: A Guide for Foot and Ankle Surgeons. Foot Ankle Int. 2015;36(12):1391-9. PMID: 26194106. KQ1E1, KQ2E4c, KQ3E1, KQ4E1, KQ5E1.26194106
99 Zainuer A, Inoue Y, Kudo T, . Usefulness of the transfer function index for diagnosing peripheral arterial disease in patients with arterial calcification. J Med Dent Sci. 2016;63(1):29-35. PMID: 27181488. KQ1E1, KQ2E2a, KQ3E2a, KQ4E1, KQ5E1.27181488