# Appendix B Included Studies

Below is a list of included studies and their ancillary publications (indented below the main results publication):

1 Belch J, MacCuish A, Campbell I, . The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. PMID: 18927173. 10.1136/bmj.a1840 18927173
2 Collins TC, Johnson SL, Souchek J. Unsupervised walking therapy and atherosclerotic risk-factor management for patients with peripheral arterial disease: a pilot trial. Ann Behav Med. 2007;33(3):318-24. PMID: 17600459. 10.1080/08836610701360181 17600459
3 Fowkes FG, Price JF, Stewart MC, . Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303(9):841-8. PMID: 20197530. 10.1001/jama.2010.221 20197530
4 Fowler B, Jamrozik K, Norman P, . Improving maximum walking distance in early peripheral arterial disease: randomised controlled trial. Aust J Physiother. 2002;48(4):269-75. PMID: 12443521.12443521
5 Wikstrom J, Hansen T, Johansson L, . Ankle brachial index <0.9 underestimates the prevalence of peripheral artery occlusive disease assessed with whole-body magnetic resonance angiography in the elderly. Acta Radiol. 2008;49(2):143-9. PMID: 18300136. 10.1080/02841850701732957 18300136
Wikstrom J, Hansen T, Johansson L, . Lower extremity artery stenosis distribution in an unselected elderly population and its relation to a reduced ankle-brachial index. J Vasc Surg. 2009;50(2):330-4. PMID: 19446989. 10.1016/j.jvs.2009.03.008 19446989