# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Key:

/ = MeSH subject heading

$ = truncation

* = truncation

? = wildcard

ab = word in abstract

adj# = adjacent within x number of words

ae = adverse effects

kw = keyword

near/# = adjacent within x number of words

ti = word in title

### Central

#1 ((peripheral next arter*) near/2 disease*):ti,ab,kw
#2 (lower next (limb or extremity) near/2 disease*):ti,ab,kw
#3 (leg next artery next disease*):ti,ab,kw
#4 (ankle near/1 (brachial or arm) near/4 (index* or indices or ratio or gradient or pressure)):ti,ab,kw
#5 (ankle next (index* or indices)):ti,ab,kw
#6 ABPI:ti,ab,kw
#7 #1 or #2 or #3 or #4 or #5 or #6 Publication Year from 2012 to May 2, 2017, in Trials

### Medline (via Ovid)

#### Screening

Database: Ovid MEDLINE(R) Epub Ahead of Print <May 2, 2017>, Ovid MEDLINE(R) <1946 to May Week 1 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <May 2, 2017>, Ovid MEDLINE(R) Daily Update <May 2, 2017>

1. Peripheral Arterial Disease/
2. Arterial Occlusive Diseases/
3. Peripheral Vascular Diseases/
4. peripheral arter$ disease$.ti,ab.
5. peripheral arter$ occlusive disease$.ti,ab.
6. (lower adj (limb or extremity) adj2 disease$).ti,ab.
7. leg artery disease$.ti,ab.
8. or/1-7
9. Ankle Brachial Index/
10. (brachial adj1 ankle adj4 (ratio$ or index$ or indices or gradient$ or pressure)).ti,ab.
11. (arm adj1 ankle adj4 (ratio$ or index$ or indices or gradient$ or pressure)).ti,ab.
12. (ankle adj (index$ or indices)).ti,ab.
13. Ankle/bs [Blood Supply]
14. Brachial Artery/ph, pp, us [Physiology, Physiopathology, Ultrasonography]
15. Blood pressure/
16. Ankle/
17. 15 and 16
18. 9 or 10 or 11 or 12 or 13 or 14 or 17
19. Mass Screening/
20. screen$.ti,ab.
21. (detect$ or predict$ or diagnos$ or identif$).ti.
22. or/19-21
23. 8 and 18 and 22
24. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
25. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
26. Random$.ti,ab.
27. control groups/ or double-blind method/ or single-blind method/
28. clinical trial$.ti,ab.
29. controlled trial$.ti,ab.
30. meta analy$.ti,ab.
31. or/24-30
32. 23 and 31
33. “Sensitivity and Specificity”/
34. “Predictive Value of Tests”/
35. ROC Curve/
36. False Negative Reactions/
37. False Positive Reactions/
38. Diagnostic Errors/
39. “Reproducibility of Results”/
40. Reference Values/
41. Reference Standards/
42. Observer Variation/
43. Receiver operat$.ti,ab.
44. ROC curve$.ti,ab.
45. sensitivit$.ti,ab.
46. specificit$.ti,ab.
47. predictive value.ti,ab.
48. accuracy.ti,ab.
49. false positive$.ti,ab.
50. false negative$.ti,ab.
51. miss rate$.ti,ab.
52. error rate$.ti,ab.
53. 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52
54. 18 and 53
55. 32 or 54
56. limit 55 to (english language and yr=“2012 -Current”)
57. remove duplicates from 56

#### Treatment

Database: Ovid MEDLINE(R) Epub Ahead of Print <May 2, 2017>, Ovid MEDLINE(R) <1946 to May Week 1 2017>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <May 2, 2017>, Ovid MEDLINE(R) Daily Update <June 21, 2016>

1. Peripheral Arterial Disease/
2. Arterial Occlusive Diseases/
3. Peripheral Vascular Diseases/
4. peripheral arter$ disease$.ti,ab.
5. peripheral arter$ occlusive disease$.ti,ab.
6. (lower adj (limb or extremity) adj2 disease$).ti,ab.
7. leg artery disease$.ti,ab.
8. or/1-7
9. ((abnormal$ or low) adj4 (brachial adj1 ankle adj4 (ratio$ or index$ or indices or gradient$ or pressure))).ti,ab.
10. ((abnormal$ or low) adj4 (arm adj1 ankle adj4 (ratio$ or index$ or indices or gradient$ or pressure))).ti,ab.
11. ((abnormal$ or low) adj4 (ankle index$ or ankle indices)).ti,ab.
12. ((abnormal$ or low) adj ABI).ti,ab.
13. or/9-12
14. “tobacco use cessation”/ or smoking cessation/
15. smoking cessation.ti,ab.
16. Hypercholesterolemia/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy]
17. Hyperlipidemias/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy]
18. Anticholesteremic Agents/
19. (lower$ adj3 cholesterol).ti,ab.
20. (reduc$ adj3 cholesterol).ti,ab.
21. Diabetes Mellitus/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy]
22. Diabetes Mellitus, Type 2/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy]
23. Hypoglycemic Agents/
24. Hemoglobin A, Glycosylated/
25. Blood Glucose/an, me [Analysis, Metabolism]
26. Glycemic Index/
27. glycemic control$.ti,ab.
28. glycaemic control$.ti,ab.
29. glucose control$.ti,ab.
30. body weight changes/ or weight loss/
31. weight loss.ti,ab.
32. Hypertension/dh, dt, pc, rh, th [Diet Therapy, Drug Therapy, Prevention & Control, Rehabilitation, Therapy]
33. Antihypertensive Agents/
34. blood pressure control$.ti,ab.
35. (hypertension adj2 control$).ti,ab.
36. Platelet Aggregation Inhibitors/
37. Blood Platelets/de [Drug Effects]
38. ((anti platelet or antiplatelet) adj2 (therapy or treatment$)).ti,ab.
39. physical activit$.ti,ab.
40. Exercise/
41. exercis$.ti.
42. Physical Fitness/
43. Walking/
44. walking.ti.
45. treadmill.ti,ab.
46. Resistance Training/
47. Motor Activity/
48. Physical Therapy Modalities/
49. Exercise Therapy/
50. Exercise Movement Techniques/
51. physical therap$.ti,ab.
52. physiotherapy$.ti,ab.
53. or/14-52
54. (8 or 13) and 53
55. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
56. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
57. Random$.ti,ab.
58. control groups/ or double-blind method/ or single-blind method/
59. clinical trial$.ti,ab.
60. controlled trial$.ti,ab.
61. meta analy$.ti,ab.
62. or/55-61
63. 54 and 62
64. “Drug-Related Side Effects and Adverse Reactions”/
65. harm$.ti,ab.
66. toxicity.ti,ab.
67. complication$.ti,ab.
68. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab.
69. adverse effects.fs.
70. toxicity.fs.
71. mortality.fs.
72. Safety/
73. safety.ti,ab.
74. product surveillance, postmarketing/
75. side effect$.ti,ab.
76. Emergency Service, Hospital/
77. Hospitalization/
78. (unexpected$ adj3 (emergency or hospital$ or medical attention)).ti,ab.
79. or/64-78
80. 54 and 79
81. 63 or 80
82. limit 81 to (english language and yr=“2012 -Current”)
83. remove duplicates from 82

### PUBMED, publisher-supplied records

#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (((#6) AND publisher[sb]) AND English[Language]) AND (“2012/01/01”[Date - Publication]: “3000”[Date - Publication])
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #1 OR #4 OR #5
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (ankle[tiab] AND (brachial[tiab] OR arm[tiab]) AND (index*[tiab] OR indices[tiab] OR ratio*[tiab] OR gradient*[tiab] OR pressure[tiab]) OR ankle index*[tiab])
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #2 AND #3
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search ((control[tiab] OR controls[tiab] OR controlled[tiab] OR controled[tiab]) AND (trial[tiab] OR trials[tiab])) OR clinical trial[tiab] OR clinical trials[tiab] OR random*[tiab] OR systematic review[sb] OR metaanaly*[tiab] OR meta analysis[tiab]
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (peripheral artery disease [tiab] OR peripheral arterial disease [tiab] OR lower extremity disease[tiab] OR leg artery disease[tiab] OR abnormal ABI[tiab] OR low ABI[tiab]) AND (cholesterol[tiab] OR smoking[tiab] OR glycemic[tiab] OR glycaemic[tiab] OR glucose[tiab] OR weight loss[tiab] OR blood pressure[tiab] OR hypertension[tiab] OR anti hypertensive[tiab] OR antihypertensive[tiab] anti platelet[tiab] OR antiplatelet[tiab] OR physical activit*[tiab] OR exercis*[tiab] OR walking[tiab] OR treadmill[tiab] OR physical therap*[tiab])
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (peripheral artery disease[tiab] OR peripheral arterial disease[tiab] OR lower extremity disease[tiab] OR leg artery disease[tiab]) AND screen*[tiab]

Terms used in targeted search of previous Reference Manager bibliographic database for diabetes and exercise or physical therapy

Connector | Field | Parameter | Results
| All Non-Indexed Fields | diab | 1020
OR | Keywords | diab* | 1066
OR | All Non-Indexed Fields | abnormal glucose | 1069
OR | All Non-Indexed Fields | impaired glucose | 1072
OR | All Non-Indexed Fields | uncontrolled glucose | 1072
OR | All Non-Indexed Fields | insulin resistance | 1112
OR | All Non-Indexed Fields | prediab | 1112
OR | All Non-Indexed Fields | exercise | 1527
OR | All Non-Indexed Fields | walking | 1753
OR | All Non-Indexed Fields | physical activity | 1775
OR | All Non-Indexed Fields | physical therap | 1781
OR | All Non-Indexed Fields | motor activity | 1781
OR | Keywords | Exercise Therapy | 1784
OR | Keywords | Physical Activity | 1784
OR | Keywords | Physical Therapy Modalities | 1785

Appendix A Figure 1 Literature Flow Diagram

Appendix A Figure 1 displays the literature search results and article flow for the review. A total of 1,679 articles were identified through a targeted search of the previous review's bibliographic database for diabetes and exercise therapy; 2,392 articles were identified through new database searches; and 123 articles were identified from other sources. 4,194 articles were screened and 105 full-text articles were assessed for eligibility. 6 publications (5 trials) were included for KQs 1-5.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Population | KQs 1-3: Unselected or community-dwelling, generally asymptomatic adults^*^ KQs 4,5: Screen-detected or generally asymptomatic adults with PAD or an abnormal ABI^†^ A priori subpopulations at greater risk for PAD will be examined based on the following factors: age (particularly ≥65 years), sex, race/ethnicity, diabetes, smoking, and hypertension status | Symptomatic adults; study populations consisting exclusively of adults with known CVD or severe chronic kidney disease (stages 4 and 5)
Setting | Primary care and outpatient settings (i.e., ambulatory care) | Vascular surgery clinics (KQs 1,2); hospital/inpatient settings
Disease/Condition | Lower-extremity PAD secondary to atherosclerosis^‡^ | Other anatomic locations for vascular disease (e.g., coronary artery stenosis, abdominal aortic aneurysm)
Screening | Resting ABI | History taking, physical examination, questionnaires, digital subtraction arteriography (DSA), duplex ultrasonography, magnetic resonance angiography (MRA), computed tomographic angiography (CTA), toe pressure measurement, treadmill testing (exercise ABI), pulse oximetry, near-infrared spectroscopy, and all invasive diagnostic testing
Treatment or management interventions | Pharmacologic or lifestyle interventions primarily aimed at CVD reduction: interventions for smoking cessation, cholesterol-lowering therapy, diet and exercise (with or without weight loss), blood pressure control, and antiplatelet therapy Exercise or physical therapy interventions aimed at improving lower limb function | Vitamins or nutritional or herbal supplements Interventions aimed only at symptomatic adults or adults with critical limb ischemia: pharmacologic symptom management (pentoxyfylline, cilostazol, prostaglandins), nonpharmacologic symptom management, and revascularization (angioplasty, thrombolytics, stenting, bypass)
Comparisons | KQ 1: No screening KQ 2: Reference standard (DSA, diagnostic imaging of atherosclerosis [e.g., MRA, CTA]) or degree of impaired blood flow (e.g., duplex ultrasonography) KQ 4: True control group (receives placebo, no intervention, or usual care); intervention/treatment at later or symptomatic stage of disease (vs. earlier or asymptomatic stage)
Outcomes | KQ 1: Cardiovascular morbidity (myocardial infarction, cerebrovascular accident), PAD morbidity (ambulation impairment, amputation) or mortality (all-cause, PAD-related, or CVD-related), and health-related quality of life KQ 2: Sensitivity, specificity, positive and negative predictive value for PAD, and incidence or prevalence KQ 4: Patient health outcomes (listed above for KQ 1) | Surrogate markers for atherosclerosis, including imaging (e.g., carotid intima-media thickness) or biochemical markers (e.g., high-sensitivity C-reactive protein) Patient satisfaction Cost-related outcomes (for screening and treatment) Intermediate cardiovascular outcomes (e.g., blood pressure, cholesterol); behavior changes (e.g., smoking cessation, physical activity level); and intermediate measures of lower limb function (e.g., 6-minute walking test, lower-extremity strength) Change in ABI
Harms | KQ 3: Adverse outcomes related to ABI test (diagnostic inaccuracy) or harms of subsequent testing KQ 5: Serious adverse events (e.g., death, serious adverse drug reactions) and unexpected medical attention (e.g., emergency department visits, hospitalizations) | Patient satisfaction
Study designs | KQs 1, 4: Good-quality systematic reviews and randomized or clinically controlled trials KQ 2: Good-quality systematic reviews and diagnostic accuracy studies KQs 3, 5: Good-quality systematic reviews, randomized or clinically controlled trials, and cohort or case-control studies | Poor-quality studies based on established design-specific quality criteria KQ 2: Case-control studies of diagnostic accuracy KQ 4: Studies with less than 3 months of followup
Countries | Economically developed countries, defined as member countries of the Organisation for Economic Co-operation and Development (2015): Australia, Austria, Belgium, Canada, Chile, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Luxembourg, Mexico, Netherlands, New Zealand, Norway, Poland, Portugal, Slovak Republic, Slovenia, Spain, Sweden, Switzerland, Turkey, United Kingdom, and United States | Studies performed in countries with populations not similar to the United States Countries that are not a member of the Organisation for Economic Co-operation and Development
Language | English only | Non-English languages

* Adults without lower extremity symptoms or with vague symptoms not attributed to PAD.

† Defined as an ABI of ≤0.90 or >1.40.

‡ The condition definition for PAD would ideally be confirmed by diagnostic imaging (MRA, CTA, or DSA); however, the review will include trials that recruit participants with an abnormal ABI.

Abbreviations: ABI = ankle-brachial index; CTA = computed tomographic angiography; CVD = cardiovascular disease; DSA = digital subtraction arteriography; MRA = magnetic resonance angiography; PAD = peripheral artery disease

Appendix A Table 2 USPSTF and QUADAS-2 Quality Rating Criteria

USPSTF quality rating criteria for trials^84^
- Initial assembly of comparable groups; - Employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered; - Intention-to-treat analysis
Quality criteria from QUADAS-2^92^
- Were tests clearly described (or referenced)?; - Domain 1: Patient Selection (Could the selection of patients have introduced bias?)^*^; ○ Was the spectrum of patients representative of the patients who will receive the test in primary care?; ○ Was the selection process clearly defined?; ○ Are there concerns that the included patients and setting do not match the review question?; - Domain 2: Index Test (Could the conduct or interpretation of the index test have introduced bias?); ○ Was the index test interpreted without knowledge of the reference standard results?; ○ If a threshold was used, was it prespecified?; ○ Are there concerns that the index test, its conduct, or its interpretation differ from the review question?; - Domain 3: Reference Standard (Could the conduct or interpretation of the reference standard have introduced bias?); ○ Is the reference standard acceptable for correctly classifying the target condition?; ○ Was the reference standard interpreted without knowledge of the index test results?; ○ Are there concerns that the target condition as defined by the reference standard does not match the review question?; ○ Did the whole or partial selection of patients receive the reference standard?; - Domain 4: Flow and Timing (Could the patient flow have introduced bias?); ○ Was there an appropriate interval between the index test and reference standard?; ○ Did all patients receive the same reference standard?; ○ Were all patients included in the analysis?

* Domain 1 questions minimally adapted