# References

1 January CT, Wann LS, Alpert JS, . 2014 AHA/ACC/HRS guideline for the management of patients with atrial fibrillation: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Heart Rhythm Society. J Am Coll Cardiol. 2014 Dec 02;64(21):e1–76. doi: 10.1016/j.jacc.2014.03.022. PMID: 24685669.24685669
2 Cheng A, Kumar K. Overview of atrial fibrillation. 2015. http://www.uptodate.com/contents/overview-of-atrial-fibrillation.
3 Burstein B, Nattel S. Atrial fibrosis: mechanisms and clinical relevance in atrial fibrillation. J Am Coll Cardiol. 2008 Feb 26;51(8):802–9. doi: 10.1016/j.jacc.2007.09.064. PMID: 18294563.18294563
4 Kistler PM, Sanders P, Fynn SP, . Electrophysiologic and electroanatomic changes in the human atrium associated with age. J Am Coll Cardiol. 2004 Jul 7;44(1):109–16. doi: 10.1016/j.jacc.2004.03.044. PMID: 15234418.15234418
5 Allessie M, Ausma J, Schotten U. Electrical, contractile and structural remodeling during atrial fibrillation. Cardiovasc Res. 2002 May;54(2):230–46. PMID: 12062329.12062329
6 Nattel S, Burstein B, Dobrev D. Atrial remodeling and atrial fibrillation: mechanisms and implications. Circ Arrhythm Electrophysiol. 2008 Apr;1(1):62–73. doi: 10.1161/CIRCEP.107.754564. PMID: 19808395.19808395
7 Ikeda T, Murai H, Kaneko S, . Augmented single-unit muscle sympathetic nerve activity in heart failure with chronic atrial fibrillation. J Physiol. 2012 Feb 1;590(Pt 3):509–18. doi: 10.1113/jphysiol.2011.223842. PMID: 22144576.22144576
8 Segerson NM, Sharma N, Smith ML, . The effects of rate and irregularity on sympathetic nerve activity in human subjects. Heart Rhythm. 2007 Jan;4(1):20–6. doi: 10.1016/j.hrthm.2006.09.017. PMID: 17198984.17198984
9 Nabauer M, Gerth A, Limbourg T, . The Registry of the German Competence NETwork on Atrial Fibrillation: patient characteristics and initial management. Europace. 2009 Apr;11(4):423–34. doi: 10.1093/europace/eun369. PMID: 19153087.19153087
10 Savelieva I, Camm AJ. Clinical relevance of silent atrial fibrillation: prevalence, prognosis, quality of life, and management. J Interv Card Electrophysiol. 2000 Jun;4(2):369–82. PMID: 10936003.10936003
11 Wolf PA, Abbott RD, Kannel WB. Atrial fibrillation as an independent risk factor for stroke: the Framingham Study. Stroke. 1991 Aug;22(8):983–8. PMID: 1866765.1866765
12 Watson T, Shantsila E, Lip GY. Mechanisms of thrombogenesis in atrial fibrillation: Virchow’s triad revisited. Lancet. 2009 Jan 10;373(9658):155–66. doi: 10.1016/S0140-6736(09)60040-4. PMID: 19135613.19135613
13 Banerjee A, Taillandier S, Olesen JB, . Pattern of atrial fibrillation and risk of outcomes: the Loire Valley Atrial Fibrillation Project. Int J Cardiol. 2013 Sep 10;167(6):2682–7. doi: 10.1016/j.ijcard.2012.06.118. PMID: 22795403.22795403
14 Friberg L, Hammar N, Rosenqvist M. Stroke in paroxysmal atrial fibrillation: report from the Stockholm Cohort of Atrial Fibrillation. Eur Heart J. 2010 Apr;31(8):967–75. doi: 10.1093/eurheartj/ehn599. PMID: 19176537.19176537
15 Hart RG, Pearce LA, Rothbart RM, . Stroke with intermittent atrial fibrillation: incidence and predictors during aspirin therapy. Stroke Prevention in Atrial Fibrillation Investigators. J Am Coll Cardiol. 2000 Jan;35(1):183–7. PMID: 10636278.10636278
16 Hohnloser SH, Pajitnev D, Pogue J, . Incidence of stroke in paroxysmal versus sustained atrial fibrillation in patients taking oral anticoagulation or combined antiplatelet therapy: an ACTIVE W Substudy. J Am Coll Cardiol. 2007 Nov 27;50(22):2156–61. doi: 10.1016/j.jacc.2007.07.076. PMID: 18036454.18036454
17 Link MS, Giugliano RP, Ruff CT, . Stroke and mortality risk in patients with various patterns of atrial fibrillation: results from the ENGAGE AF-TIMI 48 Trial (Effective Anticoagulation With Factor Xa Next Generation in Atrial Fibrillation-Thrombolysis in Myocardial Infarction 48). Circ Arrhythm Electrophysiol. 2017 Jan;10(1)doi: 10.1161/circep.116.004267. PMID: 28077507.28077507
18 Giugliano RP, Ruff CT, Braunwald E, . Edoxaban versus warfarin in patients with atrial fibrillation. N Engl J Med. 2013 Nov 28;369(22):2093–104. doi: 10.1056/NEJMoa1310907. PMID: 24251359.24251359
19 Al-Khatib SM, Thomas L, Wallentin L, . Outcomes of apixaban vs. warfarin by type and duration of atrial fibrillation: results from the ARISTOTLE trial. Eur Heart J. 2013 Aug;34(31):2464–71. doi: 10.1093/eurheartj/eht135. PMID: 23594592.23594592
20 Steinberg BA, Hellkamp AS, Lokhnygina Y, . Higher risk of death and stroke in patients with persistent vs. paroxysmal atrial fibrillation: results from the ROCKET-AF Trial. Eur Heart J. 2015 Feb 1;36(5):288–96. doi: 10.1093/eurheartj/ehu359. PMID: 25209598.25209598
21 Lip GY, Frison L, Grind M. Stroke event rates in anticoagulated patients with paroxysmal atrial fibrillation. J Intern Med. 2008 Jul;264(1):50–61. doi: 10.1111/j.1365-2796.2007.01909.x. PMID: 18266660.18266660
22 Takabayashi K, Hamatani Y, Yamashita Y, . Incidence of Stroke or Systemic Embolism in Paroxysmal Versus Sustained Atrial Fibrillation: The Fushimi Atrial Fibrillation Registry. Stroke. 2015 Dec;46(12):3354–61. doi: 10.1161/strokeaha.115.010947. PMID: 26514188.26514188
23 Vanassche T, Lauw MN, Eikelboom JW, . Risk of ischaemic stroke according to pattern of atrial fibrillation: analysis of 6563 aspirin-treated patients in ACTIVE-A and AVERROES. Eur Heart J. 2015 Feb 1;36(5):281–7a. doi: 10.1093/eurheartj/ehu307. PMID: 25187524.25187524
24 Stroke Risk in Atrial Fibrillation Working G. Independent predictors of stroke in patients with atrial fibrillation: a systematic review. Neurology. 2007 Aug 7;69(6):546–54. doi: 10.1212/01.wnl.0000267275.68538.8d. PMID: 17679673.17679673
25 Dulli DA, Stanko H, Levine RL. Atrial fibrillation is associated with severe acute ischemic stroke. Neuroepidemiology. 2003 Mar–Apr;22(2):118–23. . PMID: 12629277.12629277
26 Lamassa M, Di Carlo A, Pracucci G, . Characteristics, outcome, and care of stroke associated with atrial fibrillation in Europe: data from a multicenter multinational hospital-based registry (The European Community Stroke Project). Stroke. 2001 Feb;32(2):392–8. PMID: 11157172.11157172
27 Lin HJ, Wolf PA, Kelly-Hayes M, . Stroke severity in atrial fibrillation. The Framingham Study. Stroke. 1996 Oct;27(10):1760–4. PMID: 8841325.8841325
28 Menke J, Luthje L, Kastrup A, . Thromboembolism in atrial fibrillation. Am J Cardiol. 2010 Feb 15;105(4):502–10. doi: 10.1016/j.amjcard.2009.10.018. PMID: 20152245.20152245
29 Mozaffarian D, Benjamin EJ, Go AS, . Heart Disease and Stroke Statistics-2016 Update: A Report From the American Heart Association. Circulation. 2016 Jan 26;133(4):e38–e360. doi: 10.1161/CIR.0000000000000350. PMID: 26673558.26673558
30 Schnabel RB, Sullivan LM, Levy D, . Development of a risk score for atrial fibrillation (Framingham Heart Study): a community-based cohort study. Lancet. 2009 Feb 28;373(9665):739–45. doi: 10.1016/S0140-6736(09)60443-8. PMID: 19249635.19249635
31 Chamberlain AM, Agarwal SK, Folsom AR, . A clinical risk score for atrial fibrillation in a biracial prospective cohort (from the Atherosclerosis Risk in Communities [ARIC] study). Am J Cardiol. 2011 Jan;107(1):85–91. doi: 10.1016/j.amjcard.2010.08.049. PMID: 21146692.21146692
32 Alonso A, Krijthe BP, Aspelund T, . Simple risk model predicts incidence of atrial fibrillation in a racially and geographically diverse population: the CHARGE-AF consortium. J Am Heart Assoc. 2013 Apr;2(2):e000102. doi: 10.1161/JAHA.112.000102. PMID: 23537808.23537808
33 Go AS, Hylek EM, Phillips KA, . Prevalence of diagnosed atrial fibrillation in adults: national implications for rhythm management and stroke prevention: the AnTicoagulation and Risk Factors in Atrial Fibrillation (ATRIA) Study. JAMA. 2001 May 9;285(18):2370–5. PMID: 11343485.11343485
34 Centers for Medicare & Medicaid Services. Medicare Beneficiary Prevalence for Chronic Conditions for 2004 Through 2013. 2015. https://www.ccwdata.org/web/guest/medicare-charts/medicare-chronic-condition-charts/#b2_cardio_2004_2013.
35 Harris K, Edwards D, Mant J. How can we best detect atrial fibrillation? J R Coll Physicians Edinb. 2012;42 Suppl 18:5–22. doi: 10.4997/JRCPE.2012.S02. PMID: 22518390.22518390
36 Moran PS, Flattery MJ, Teljeur C, . Effectiveness of systematic screening for the detection of atrial fibrillation. Cochrane Database Syst Rev. 2013(4):Cd009586. doi: 10.1002/14651858.CD009586.pub2. PMID: 23633374.23633374
37 Mozaffarian D, Benjamin EJ, Go AS, . Heart disease and stroke statistics-2015 update: a report from the American Heart Association. Circulation. 2015 Jan 27;131(4):e29–322. doi: 10.1161/CIR.0000000000000152. PMID: 25520374.25520374
38 Wolf PA, Kannel WB, McGee DL, . Duration of atrial fibrillation and imminence of stroke: the Framingham study. Stroke. 1983 Sep–Oct;14(5):664–7. PMID: 6658948.6658948
39 Lin HJ, Wolf PA, Benjamin EJ, . Newly diagnosed atrial fibrillation and acute stroke. The Framingham Study. Stroke. 1995 Sep;26(9):1527–30. PMID: 7660392.7660392
40 Hannon N, Sheehan O, Kelly L, . Stroke associated with atrial fibrillation-incidence and early outcomes in the north Dublin population stroke study. Cerebrovasc Dis. 2010;29(1):43–9. doi: 10.1159/000255973. PMID: 19893311.19893311
41 Lowres N, Neubeck L, Redfern J, . Screening to identify unknown atrial fibrillation. A systematic review. Thromb Haemost. 2013 Aug;110(2):213–22. doi: 10.1160/th13-02-0165. PMID: 23595785.23595785
42 Taggar JS, Coleman T, Lewis S, . Accuracy of methods for detecting an irregular pulse and suspected atrial fibrillation: A systematic review and meta-analysis. Eur J Prev Cardiol. 2016 Aug;23(12):1330–8. doi: 10.1177/2047487315611347. PMID: 26464292.26464292
43 Bogun F, Anh D, Kalahasty G, . Misdiagnosis of atrial fibrillation and its clinical consequences. Am J Med. 2004 Nov 1;117(9):636–42. doi: 10.1016/j.amjmed.2004.06.024. PMID: 15501200.15501200
44 Hart RG, Pearce LA, Aguilar MI. Meta-analysis: antithrombotic therapy to prevent stroke in patients who have nonvalvular atrial fibrillation. Ann Intern Med. 2007 Jun 19;146(12):857–67. PMID: 17577005.17577005
45 Ogilvie IM, Newton N, Welner SA, . Underuse of oral anticoagulants in atrial fibrillation: a systematic review. Am J Med. 2010 Jul;123(7):638–45 e4. doi: 10.1016/j.amjmed.2009.11.025. PMID: 20609686.20609686
46 Ogilvie IM, Welner SA, Cowell W, . Characterization of the proportion of untreated and antiplatelet therapy treated patients with atrial fibrillation. Am J Cardiol. 2011 Jul 1;108(1):151–61. doi: 10.1016/j.amjcard.2011.02.353. PMID: 21545990.21545990
47 Cameron C, Coyle D, Richter T, . Systematic review and network meta-analysis comparing antithrombotic agents for the prevention of stroke and major bleeding in patients with atrial fibrillation (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):e004301. PMID: DARE-12014036609.
48 Dogliotti A, Paolasso E, Giugliano RP. Current and new oral antithrombotics in non-valvular atrial fibrillation: a network meta-analysis of 79 808 patients. Heart. 2014 Mar;100(5):396–405. doi: 10.1136/heartjnl-2013-304347. PMID: 24009224.24009224
49 U.S. Food and Drug Administration. WATCHMAN LAA Closure Technology approval letter. 2015. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfTopic/pma/pma.cfm?num=p130013. Accessed February 8, 2016.
50 Olshansky B, Rosenfeld LE, Warner AL, . The Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study: approaches to control rate in atrial fibrillation. J Am Coll Cardiol. 2004 Apr 7;43(7):1201–8. doi: 10.1016/j.jacc.2003.11.032. PMID: 15063430.15063430
51 Van Gelder IC, Hagens VE, Bosker HA, . A comparison of rate control and rhythm control in patients with recurrent persistent atrial fibrillation. N Engl J Med. 2002 Dec 5;347(23):1834–40. doi: 10.1056/NEJMoa021375. PMID: 12466507.12466507
52 Meschia JF, Bushnell C, Boden-Albala B, . Guidelines for the primary prevention of stroke: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2014 Dec;45(12):3754–832. doi: 10.1161/STR.0000000000000046. PMID: 25355838.25355838
53 Bushnell C, McCullough LD, Awad IA, . Guidelines for the prevention of stroke in women: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2014 May;45(5):1545–88. doi: 10.1161/01.str.0000442009.06663.48. PMID: 24503673.24503673
54 Camm AJ, Lip GY, De Caterina R, . 2012 focused update of the ESC Guidelines for the management of atrial fibrillation: an update of the 2010 ESC Guidelines for the management of atrial fibrillation. Developed with the special contribution of the European Heart Rhythm Association. Eur Heart J. 2012 Nov;33(21):2719–47. doi: 10.1093/eurheartj/ehs253. PMID: 22922413.22922413
55 Stott DJ, Dewar RI, Garratt CJ, . RCPE UK Consensus Conference on ‘Approaching the comprehensive management of atrial fibrillation: evolution or revolution?’. J R Coll Physicians Edinb. 2012;42(Suppl 18):3–4. doi: 10.4997/JRCPE.2012.S01. PMID: 22518389.22518389
56 Murphy A, Banerjee A, Breithardt G, . The World Heart Federation Roadmap for Nonvalvular Atrial Fibrillation. Glob Heart. 2017 Dec;12(4):273–84. doi: 10.1016/j.gheart.2017.01.015. PMID: 28336387.28336387
57 Kirchhof P, Breithardt G, Bax J, . A roadmap to improve the quality of atrial fibrillation management: proceedings from the fifth Atrial Fibrillation Network/European Heart Rhythm Association consensus conference. Europace. 2016 Jan;18(1):37–50. doi: 10.1093/europace/euv304. PMID: 26481149.26481149
58 Mairesse GH, Moran P, Van Gelder IC, . Screening for atrial fibrillation: a European Heart Rhythm Association (EHRA) consensus document endorsed by the Heart Rhythm Society (HRS), Asia Pacific Heart Rhythm Society (APHRS), and Sociedad Latinoamericana de Estimulacion Cardiaca y Electrofisiologia (SOLAECE). Europace. 2017 Oct 1;19(10):1589–623. doi: 10.1093/europace/eux177. PMID: 29048522.29048522
59 Hobbs FR, Taylor CJ, Jan Geersing G, . European Primary Care Cardiovascular Society (EPCCS) consensus guidance on stroke prevention in atrial fibrillation (SPAF) in primary care. Eur J Prev Cardiol. 2016 Mar;23(5):460–73. doi: 10.1177/2047487315571890. PMID: 25701017.25701017
60 Kirchhof P, Benussi S, Kotecha D, . 2016 ESC Guidelines for the management of atrial fibrillation developed in collaboration with EACTS. Eur Heart J. 2016 Oct 7;37(38):2893–962. doi: 10.1093/eurheartj/ehw210. PMID: 27567408.27567408
61 Culebras A, Messe SR, Chaturvedi S, . Summary of evidence-based guideline update: prevention of stroke in nonvalvular atrial fibrillation: report of the Guideline Development Subcommittee of the American Academy of Neurology. Neurology. 2014 Feb 25;82(8):716–24.24566225
62 Scottish Intercollegiate Guidelines Network (SIGN). SIGN 129: Antithrombotics: Indications and Management. Edinburgh: Healthcare Improvement Scotland; 2013.
63 Lip GY, Ramsay SG. Consensus conference on approaching the comprehensive management of atrial fibrillation. Expert Rev Cardiovasc Ther. 2012;10(6):697–700.22894625
64 National Institute for Health and Care Excellence. Atrial Fibrillation: The Management of Atrial Fibrillation National Institute for Health and Care Excellence (UK). London: 2014.
65 Antithrombotic Agents for the Prevention of Stroke and Systemic Embolism in Patients With Atrial Fibrillation Canadian Agency for Drugs and Technologies in Health. Ottawa (ON): 2013.
66 You JJ, Singer DE, Howard PA, . Antithrombotic therapy for atrial fibrillation: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012;141(2 Suppl):e513S–75S.
67 Verma A, Cairns JA, Mitchell LB, . 2014 focused update of the Canadian Cardiovascular Society Guidelines for the management of atrial fibrillation. Can J Cardiol. 2014;30(10):1114–30.25262857
68 Lindsay MP, Gubitz G, Bayley M, . Canadian Best Practice Recommendations for Stroke Care (Update 2010). On behalf of the Canadian Stroke Strategy Best Practices and Standards Writing Group Canadian Stroke Network. Ottawa (ON): 2010.
69 West SL, Gartlehner G, Mansfield AJ, . Comparative Effectiveness Review Methods: Clinical Heterogeneity. Report No.: 10-EHC070-EF. Rockville, MD: Agency for Healthcare Research and Quality; Sep 2010.
70 Nyaga VN, Arbyn M, Aerts M. Metaprop: a Stata command to perform meta-analysis of binomial data. Arch Public Health. 2014;72(1):39. doi: 10.1186/2049-3258-72-39. PMID: 25810908.25810908
71 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
72 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 06;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
73 Higgins JPT, Green S. Cochrane Handbook for Systematic Reviews of Interventions: The Cochrane Collaboration. London: The Cochrane Collaboration; March 2011.
74 Posada IS, Barriales V. Alternate-day dosing of aspirin in atrial fibrillation. LASAF Pilot Study Group. Am Heart J. 1999 Jul;138(1 Pt 1):137–43. PMID: 10385777.10385777
75 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes Accessed May 17, 2017.
76 Halcox JPJ, Wareham K, Cardew A, . Assessment of Remote Heart Rhythm Sampling Using the AliveCor Heart Monitor to Screen for Atrial Fibrillation: The REHEARSE-AF Study. Circulation. 2017 Nov 7;136(19):1784–94. doi: 10.1161/circulationaha.117.030583. PMID: 28851729.28851729
77 Svennberg E, Engdahl J, Al-Khalili F, . Mass screening for untreated atrial fibrillation: the STROKESTOP Study. Circulation. 2015 Jun 23;131(25):2176–84. doi: 10.1161/circulationaha.114.014343. PMID: 25910800.25910800
78 Friberg L, Engdahl J, Frykman V, . Population screening of 75- and 76-year-old men and women for silent atrial fibrillation (STROKESTOP). Europace. 2013 Jan;15(1):135–40. doi: 10.1093/europace/eus217. PMID: 22791299.22791299
79 Karolinska University Hospital. Systematic ECG Screening for Atrial Fibrillation Among 75 Year Old Subjects in the Region of Stockholm and Halland, Sweden. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine (US). [cited 2017]. https://ClinicalTrials.gov/show/NCT01593553. NLM Identifier: NCT01593553.
80 Fitzmaurice DA, Hobbs FD, Jowett S, . Screening versus routine practice in detection of atrial fibrillation in patients aged 65 or over: cluster randomised controlled trial. BMJ. 2007 Aug 25;335(7616):383. doi: 10.1136/bmj.39280.660567.55. PMID: 17673732.17673732
81 Fitzmaurice DA, McCahon D, Baker J, . Is screening for AF worthwhile? Stroke risk in a screened population from the SAFE study. Fam Pract. 2014 Jun;31(3):298–302. doi: 10.1093/fampra/cmu011. PMID: 24728774.24728774
82 Mant J, Fitzmaurice DA, Hobbs FD, . Accuracy of diagnosing atrial fibrillation on electrocardiogram by primary care practitioners and interpretative diagnostic software: analysis of data from screening for atrial fibrillation in the elderly (SAFE) trial. BMJ. 2007 Aug 25;335(7616):380. doi: 10.1136/bmj.39227.551713.AE. PMID: 17604299.17604299
83 Hobbs FD, Fitzmaurice DA, Mant J, . A randomised controlled trial and cost-effectiveness study of systematic screening (targeted and total population screening) versus routine practice for the detection of atrial fibrillation in people aged 65 and over. The SAFE study. Health Technol Assess. 2005 Oct;9(40):iii–iv, ix–x, 1–74. PMID: 16202350.16202350
84 Swancutt D, Hobbs R, Fitzmaurice D, . A randomised controlled trial and cost effectiveness study of systematic screening (targeted and total population screening) versus routine practice for the detection of atrial fibrillation in the over 65s: (SAFE) [ISRCTN19633732]. BMC Cardiovasc Disord. 2004 Jul 29;4:12. doi: 10.1186/1471-2261-4-12. PMID: 15283871.15283871
85 Morgan S, Mant D. Randomised trial of two approaches to screening for atrial fibrillation in UK general practice. Br J Gen Pract. 2002 May;52(478):373–4, 7–80. PMID: 12014534.12014534
86 Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators. The effect of low-dose warfarin on the risk of stroke in patients with nonrheumatic atrial fibrillation. N Engl J Med. 1990 Nov 29;323(22):1505–11. doi: 10.1056/nejm199011293232201. PMID: 2233931.2233931
87 Connolly SJ, Laupacis A, Gent M, . Canadian Atrial Fibrillation Anticoagulation (CAFA) Study. J Am Coll Cardiol. 1991 Aug;18(2):349–55. PMID: 1856403.1856403
88 Ezekowitz MD, Bridgers SL, James KE, . Warfarin in the prevention of stroke associated with nonrheumatic atrial fibrillation. Veterans Affairs Stroke Prevention in Nonrheumatic Atrial Fibrillation Investigators. N Engl J Med. 1992 Nov 12;327(20):1406–12. doi: 10.1056/nejm199211123272002. PMID: 1406859.1406859
89 Sato H, Ishikawa K, Kitabatake A, . Low-dose aspirin for prevention of stroke in low-risk patients with atrial fibrillation: Japan Atrial Fibrillation Stroke Trial. Stroke. 2006 Feb;37(2):447–51. doi: 10.1161/01.STR.0000198839.61112.ee. PMID: 16385088.16385088
90 Petersen P, Boysen G, Godtfredsen J, . Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Lancet. 1989 Jan 28;1(8631):175–9. PMID: 2563096.2563096
91 Stroke Prevention in Atrial Fibrillation Study Group Investigators. Preliminary report of the Stroke Prevention in Atrial Fibrillation Study. N Engl J Med. 1990 Mar 22;322(12):863–8. doi: 10.1056/nejm199003223221232. PMID: 2407959.2407959
92 Stroke Prevention in Atrial Fibrillation Study. Final results. Circulation. 1991 Aug;84(2):527–39. PMID: 1860198.1860198
93 Aguilar Maria I, Hart R. Oral anticoagulants for preventing stroke in patients with non-valvular atrial fibrillation and no previous history of stroke or transient ischemic attacks. Cochrane Database of Systematic Reviews. 2005(3)doi: 10.1002/14651858.CD001927.pub2. PMID: CD001927.
94 Aguilar M, Hart R. Antiplatelet therapy for preventing stroke in patients with non-valvular atrial fibrillation and no previous history of stroke or transient ischemic attacks. Cochrane Database Syst Rev. 2005 Oct 19(4):CD001925. doi: 10.1002/14651858.CD001925.pub2. PMID: 16235290.16235290
95 Risk factors for stroke and efficacy of antithrombotic therapy in atrial fibrillation. Analysis of pooled data from five randomized controlled trials. Arch Intern Med. 1994 Jul 11;154(13):1449–57. PMID: 8018000.8018000
96 Atrial Fibrillation Investigators. The efficacy of aspirin in patients with atrial fibrillation. Analysis of pooled data from 3 randomized trials. Arch Intern Med. 1997 Jun 9;157(11):1237–40. PMID: 9183235.9183235
97 van Walraven C, Hart RG, Connolly S, . Effect of age on stroke prevention therapy in patients with atrial fibrillation: the atrial fibrillation investigators. Stroke. 2009 Apr;40(4):1410–6. doi: 10.1161/strokeaha.108.526988. PMID: 19182090.19182090
98 Tereshchenko LG, Henrikson CA, Cigarroa J, . Comparative Effectiveness of Interventions for Stroke Prevention in Atrial Fibrillation: A Network Meta-Analysis. J Am Heart Assoc. 2016 May;5(5)doi: 10.1161/jaha.116.003206. PMID: 27207998.27207998
99 EAFT Study Group (European Atrial Fibrillation Trial). Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. Lancet. 1993;342:1255.7901582
100 Coleman CI, Sobieraj DM, Winkler S, . Effect of pharmacological therapies for stroke prevention on major gastrointestinal bleeding in patients with atrial fibrillation (Structured abstract). Int J Clin Pract. 2012;66(1):53–63. PMID: DARE-12012000802.22093613
101 Mather M. Fact Sheet: Aging in the United States. Washington, DC: Population Reference Bureau; 2016. Accessed May 16, 2017.
102 Engdahl J, Andersson L, Mirskaya M, . Stepwise screening of atrial fibrillation in a 75-year-old population: implications for stroke prevention. Circulation. 2013 Feb 26;127(8):930–7. doi: 10.1161/circulationaha.112.126656. PMID: 23343564.23343564
103 Turakhia MP, Ullal AJ, Hoang DD, . Feasibility of extended ambulatory electrocardiogram monitoring to identify silent atrial fibrillation in high-risk patients: the Screening Study for Undiagnosed Atrial Fibrillation (STUDY-AF). Clin Cardiol. 2015 May;38(5):285–92. doi: 10.1002/clc.22387. PMID: 25873476.25873476
104 Welton NJ, McAleenan A, Thom HH, . Screening strategies for atrial fibrillation: a systematic review and cost-effectiveness analysis. Health Technol Assess. 2017 May;21(29):1–236. doi: 10.3310/hta21290. PMID: 28629510.28629510
105 Go AS, Hylek EM, Chang Y, . Anticoagulation therapy for stroke prevention in atrial fibrillation: how well do randomized trials translate into clinical practice? JAMA. 2003 Nov 26;290(20):2685–92. doi: 10.1001/jama.290.20.2685. PMID: 14645310.14645310
106 Uittenbogaart SB, Verbiest-van Gurp N, Erkens PM, . Detecting and Diagnosing Atrial Fibrillation (D2AF): study protocol for a cluster randomised controlled trial. Trials. 2015;16:478. doi: 10.1186/s13063-015-1006-5. PMID: 26499449.26499449
107 Steinhubl SR, Mehta RR, Ebner GS, . Rationale and design of a home-based trial using wearable sensors to detect asymptomatic atrial fibrillation in a targeted population: The mHealth Screening to Prevent Strokes (mSToPS) trial. Am Heart J. 2016;175:77–85. doi: 10.1016/j.ahj.2016.02.011. PMID: CN-01142287.27179726