# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Elisabeth Kato, MD, MRP, and Howard Tracer, MD, AHRQ Medical Officers; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers David A Fitzmaurice, MBChB, MRCGP, MD, Richard Hobbs, MA, Stephen Morgan, MA, MB, BChir, MSc, MRCG, and Larisa G. Tereshchenko, MD, PhD; Federal partner reviewers at the Centers for Disease Control and Prevention; and RTI International–University of North Carolina EPC staff Carol Woodell, BSPH; Josh Green, BA; Christiane Voisin, MSLS; Claire Korzen, BA; Sharon Barrell, and Loraine Monroe.