# Chapter 4 Discussion

## Summary of Evidence

Table 6 provides a summary of findings in this evidence review. This table is organized by KQ and provides a summary of the main findings along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability.

Table 6 Summary of Evidence for Screening for Atrial Fibrillation With ECG

Key Question and Topic | No. of Studies Study Design | No. of Participants | Summary of Main Findings (Including Consistency and Precision) | Quality | Limitations (Including Reporting Bias) | Strength of Evidence | Applicability
1: Benefits of screening | 1 RCT | 1,001 | Study was not designed or powered to evaluate health outcomes (it was designed for KQ 2). Composite of stroke, TIA, or systemic embolism: 6 vs. 10 events; HR, 0.61; 95% CI, 0.22 to 1.69; consistency unknown; imprecise. | Fair | Moderate risk of measurement bias; lack of masking; reporting bias not detected. | Insufficient | NA
2: Identifying new cases of atrial fibrillation | 3 RCTs | 18,804 | No significant difference between systematic screening with ECG and opportunistic screening approaches focused on pulse palpation; RDs were ‑0.02% (95% CI, -0.5% to 0.5%) and 0.3% (-0.2% to 0.9%); consistent, imprecise. Systematic screening with 12-lead ECG identified more new cases than no screening (absolute increase over 12 months, 0.6% [95% CI, 0.1% to 0.98%]) as does twice-weekly screening with single-lead ECG (absolute increase over 12 months, 2.8% [95% CI, 0.9% to 4.7%]); consistent^a^; imprecise. | Fair | Allocation concealment was inadequate or not reported; limited reporting of baseline characteristics to allow assessment for baseline differences in 2 studies (studies reported only age and sex);^80–85^ potential ascertainment bias for previous atrial fibrillation diagnoses in 1 study (done by 1 person and masking to allocation was NR);^85^ moderate risk of ascertainment bias with lack of masking and uncertain workup to confirm AF in 1 study;^76^ reporting bias not detected. | Low | Adults age 65 or older without a known history of atrial fibrillation Questionable applicability to women
3: Harms of screening | 1 RCT | False positives: 2,595 Anxiety: 1,940^b^ (of the 14,802 participants in the SAFE study) | General practitioners misinterpreted 8% of sinus rhythm cases as AF compared with reference standard cardiologists (sensitivity 79.8 [95% CI, 70.5 to 87.2]; specificity 91.6 [90.1 to 93.1]). Mean anxiety (S6AQ) scores were not significantly different for systematic and opportunistic screening arms postscreening (28.8 [95% CI, 28.3 to 29.3] vs. 28.3 [26.8 to 29.7], p=0.73) or after 17 months (35.9 [34.3 to 37.6] vs. 37.5 [35.8 to 39.2], p=0.84 adjusted for baseline scores). Mean scores were higher for screen-positive vs. screen-negative respondents at 17 months (38.1 [35.9 to 40.4] vs. (34.6 [32.4 to 36.8], p=0.03); consistency unknown (single study); precise. | Fair | Relatively few participants were included in the analysis of screen-positive vs. screen-negative respondents (270 participants). Screening vs no screening: no anxiety data collected from no-screening group to allow comparison between screening and no-screening arms. Reporting bias not detected. | Low for false positives; low for anxiety for systematic vs. opportunistic and screen-positive vs. negative Insufficient for other harms and screening vs. no screening for all harms | Adults age 65 or older who were screened with an ECG
4: Benefits of treatment | 6 RCTs and 7 SRs | 4,531 in the RCTs and 108,942 in the SRs | Warfarin treatment (mean 1.5 years) was associated with reduced all-cause mortality (pooled RR, 0.68 [0.50 to 0.93]) and ischemic stroke (pooled RR, 0.32 [0.20 to 0.51]) compared with controls (5 trials; 2,415 participants). Findings were consistent and precise. Aspirin was associated with reduced all-cause mortality and ischemic stroke compared with controls, but differences were not statistically significant.^c^ Network meta-analysis (previously published^98^) found that all treatments (aspirin, VKAs, and all four NOACs)^d^ reduced the risk of a primary outcome (composite of any stroke and systemic embolism) and all-cause mortality. For NOACs, it found statistically significant associations with reduction in the primary outcome compared with placebo/control (unadjusted ORs from 0.27 to 0.38; adjusted ORs from 0.32 to 0.44).^e^ | Fair | All warfarin trials were stopped early; 3 of the 5 warfarin trials were open label; 4 of the 5 warfarin trials had inadequate or unclear methods of allocation concealment. Reporting bias not detected. Limitations of the network meta-analysis include (1) the lack of sensitivity analyses removing the studies with greater focus on secondary prevention, (2) limited ability to adjust for population characteristics (because some included studies were older and did not report CHADS_2_ scores, and they were estimated from baseline characteristics), and (3) heterogeneity of doses in intervention and control groups. | Moderate | Adults with nonvalvular atrial fibrillation and no history of stroke or TIA; uncertain whether the results are applicable to asymptomatic screen-detected people with AF. Most participants had AF for more than a year and few had paroxysmal AF. Warfarin trials were mean 1.5 years; estimates for lifelong benefits are not available.
5: Harms of treatment | 6 RCTs and 7 SRs | 4,531 in the RCTs and 116,496 in the SRs | Warfarin treatment for an average of 1.5 to 1.6 years was associated with increased risk of major bleeding (pooled RR, 1.8 [0.85 to 3.7]) and intracranial hemorrhage (pooled RR, 1.9 [0.56 to 6.7]) compared with controls, but confidence intervals were wide and differences between groups were not statistically significant (5 trials; 2,415 participants). Findings were consistent and imprecise. Aspirin was associated with increased risk of bleeding compared with controls; confidence intervals were wide, and differences were not statistically significant.^f^ Network meta-analysis (previously published^98^) found that the four NOACs were associated with increased risk of bleeding compared with placebo/controls (adjusted ORs from 1.38 to 2.21); confidence intervals were wide and differences between groups were not statistically significant).^h^ | Fair | All warfarin trials were stopped early; 3 of the 5 warfarin trials were open label; 4 of the 5 warfarin trials had inadequate or unclear methods of allocation concealment; reporting bias not detected. Limitations of the network meta-analysis include 1) the lack of sensitivity analyses removing the studies with greater focus on secondary prevention, 2) limited ability to adjust for population characteristics (because some included studies were older and did not report CHADS_2_ scores, and they were estimated from baseline characteristics), and 3) heterogeneity of doses in intervention and control groups. | Moderate^g^ | Adults with nonvalvular AF and no history of stroke or TIA

a Consistent when considering the studies described in Appendix A for Contextual Question 1 and considering that the results were consistent for systematic screening versus no screening when compared with those for opportunistic screening versus no screening.

b This was a subset of the 14,802 participants in the SAFE study. The number of participants may be slightly greater than 1,940 because the study did not report the total number of unique individuals who completed the Spielberger 6-item Anxiety Questionnaire (S6AQ) and it is unclear whether everyone in the baseline and end-of-study samples were also in the post-ECG screening sample. The study reported that 493 participants completed the baseline S6AQ, 1,940 completed the postscreening S6AQ, and 535 returned the end-of-study S6AQ. REHEARSE-AF also reported some information about anxiety, but it was not included because those outcomes were rated poor quality because of high risk of measurement bias (for not using a valid and reliable measure and lack of masking).

c Aspirin treatment for an average of 1.5 years was associated with a reduction in all-cause mortality (pooled RR, 0.84 [0.62 to 1.14]) and ischemic stroke (pooled RR, 0.76 [95% CI, 0.52 to 1.1]) compared with controls, but the differences were not statistically significant; 3 trials; 2,663 participants. Findings were consistent and imprecise.

d The four NOACs are apixaban, dabigatran, edoxaban, and rivaroxaban.

e The network meta-analysis also found no statistically significant differences for the four NOACs in comparison to one another. In adjusted analyses, the NOACs were not statistically different from VKAs for the primary outcome or for all-cause mortality. VKAs and the NOACs showed greater reduction in risk of the primary outcome compared with aspirin.

f Aspirin treatment for an average of 1.5 years was associated with an increased risk of major bleeding compared with controls, but the confidence interval was wide and the difference between groups was not statistically significant (pooled RR, 1.5 [95% CI, 0.44 to 5.0]; 3 trials; 2,663 participants).

g Although findings were imprecise and quality was fair, we graded the strength of evidence as Moderate considering evidence on dose response (with higher INRs increasing bleeding risk) and evidence on treatment of other conditions showing consistent evidence of bleeding risk.

h The network meta-analysis also found no statistically significant differences for the four NOACs in comparison to one another. Compared with VKAs, three of the NOACs (apixaban, dabigatran, and edoxaban) were associated with a lower risk of bleeding (range of ORs [95% CIs] from 0.64 [0.46 to 0.90] to 0.85 [0.65 to 1.11]), but the difference was only statistically significant for edoxaban (0.64 [0.46 to 0.90]). For rivaroxaban compared with VKAs, the odds of major bleeding was 1.03 (95% CI, 0.68, 1.57).

Abbreviations: CHADS_2_=Congestive heart failure, Hypertension, Age≥75 years, Diabetes mellitus, prior Stroke or TIA or thromboembolism; CI=confidence intervals; ECG=electrocardiogram; HR=hazard ratio; INR=international normalized ratio; NA=not applicable; No.=number; NOAC=novel oral anticoagulant; NR=not reported; OR=odds ratio; RCT=randomized control trial; RD=risk difference; REHEARSE-AF=Assessment of REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation; RR=relative risk; S6AQ=Spielberger 6-item Anxiety Questionnaire; SR=systematic review; TIA=transient ischemic attack; VKA=vitamin K antagonist.

### Evidence for Benefit and Harms of Screening

We did not identify any eligible studies evaluating screening for AF with ECG compared with no screening that focused on health outcomes (i.e., no eligible studies focused on the overarching question, KQ 1). We identified one ongoing RCT, the STROKESTOP study, that aims to do so and is estimated to be completed by March 2019.^77,^ ^79^ It randomized 28,768 older adults to screening program invitations for AF or to no invitations. The screening program involves an initial 12-lead ECG and then a handheld 1-lead ECG for intermittent recordings over 2 weeks. The primary outcome is incidence of stroke.

For harms of screening, no eligible studies provided information that allowed comparison between screening and no screening. The SAFE study provided limited evidence showing that anxiety may be increased among people who undergo ECG and screen positive compared with those who undergo ECG and screen negative; relatively few participants were included in the analysis (270 of the 14,802 participants in the trial). Although the difference was statistically significant, it is unclear whether the difference between groups was clinically meaningful (mean S6AQ score at 17 months: 38.1 [35.9 to 40.4] vs. 34.6 [32.4 to 36.8], p=0.028). Though it may be expected that anxiety would be slightly higher after a positive screen (than after a negative screen) because it is associated with a new diagnosis of AF.

Potential harms of screening with ECG include overdiagnosis, misdiagnosis (e.g., from misinterpretation of ECGs), and overtreatment (e.g., with anticoagulation for someone without AF, with rate or rhythm control agents when not indicated) for asymptomatic persons who either do not have AF or who would never have had symptoms of or problems from AF. Some evidence suggests that many primary care providers cannot accurately detect AF on ECG.^82^ For example, an analysis of 2,595 participants from 49 general practices in central England participating in the SAFE study assessed the accuracy of general practitioners and interpretive software for diagnosing AF.^82^ General practitioners missed 20 percent of AF cases on 12-lead ECG and misinterpreted 8 percent of sinus rhythm cases (as AF) compared with reference standard cardiologists (sensitivity 79.8 [95% CI, 70.5 to 87.2]; specificity 91.6 [90.1 to 93.1]; 79 out of 99 AF cases detected; misinterpreted sinus rhythm as AF for 114 out of 1,355). False-positive rates varied from 0 to 44 percent for individual general practitioners (standard deviation, 13%). Combining general practitioners’ interpretations with those of interpretive software increased the sensitivity (91.9 [86.6 to 97.3]), but specificity was about the same (91.1 [89.6 to 92.6]). Use of single-lead or limb-lead ECGs resulted in slightly lower specificity. The analysis did not evaluate the accuracy of primary care providers for other ECG findings (e.g., findings that may suggest ischemia and could lead to subsequent testing). Another study using a database from a U.S. hospital that evaluated 2,298 ECGs (from 1,085 patients) with a computerized interpretation of AF found that 442 (19%) ECGs from 382 (35%) patients had been misinterpreted.^43^ For 92 patients, physicians did not correct the computerized misinterpretation and initiated inappropriate and potentially harmful treatments, and they pursued unnecessary additional testing. Potential harms could also result from additional testing (e.g., unnecessary stress tests or angiographies that were done because of ECG findings suggestive of ischemia, which turned out to be false positives and resulted in complications).

### Detection of Previously Undiagnosed AF

Our review found that both one-time systematic screening with 12-lead ECG and twice-weekly screening with a single-lead ECG identified more new cases of AF than no screening (absolute increase over 12 months, 0.6% [95% CI, 0.1% to 0.9%] and 2.8% [95% CI, 0.9% to 4.7%], respectively), but screening with ECG did not detect more cases than an opportunistic screening approach using pulse palpation. The opportunistic screening approaches used in trials included reminder flags to encourage pulse recording and are therefore not necessarily reflective of routine clinical practice. Extrapolating to the U.S. population of adults age 65 or older (estimated as 46 million in 2016^101^) suggests that 276,000 additional new cases would be identified if ECG screening programs using one-time screening with 12-lead ECG were implemented in the United States. Studies without control groups (summarized in Appendix A, Contextual Question 1) estimated more new cases, although they do not account for differences in detection of undiagnosed AF between screening programs and usual care (i.e., the new cases detected that would be attributable to screening). REHEARSE-AF, STROKESTOP, and some uncontrolled studies^77,^ ^102,^ ^103^ suggest that the number of new AF cases detected is greater with intermittent ECG recordings or continuous ECG recordings over the course of 2 weeks than with one-time ECG.

Most asymptomatic older adults with previously unrecognized or undiagnosed AF have a stroke risk (based on CHADS_2_ scores or CHA_2_DS_2_-VASc scores) above the threshold for initiating anticoagulation (Appendix A Table 2; Appendix A, Contextual Question 2). Seven studies that described CHA_2_DS_2_-VASc scores reported a range of mean scores from 3.1 to 3.8, scores that would typically be associated with initiation of anticoagulation (in the absence of contraindications). In STROKESTOP, over 90 percent of new cases of AF were offered and accepted initiation of oral anticoagulant therapy.^77^ The SAFE study reported that 78 percent of new cases identified with systematic screening had CHADS_2_ scores of 1 or more and that 43 percent had scores of 2 or more.^81^ Of note, if screening programs were implemented, they could be limited to people age 65 or older who have CHA_2_DS_2_-VASc scores of 2 or higher (to avoid screening people for whom anticoagulation would not be indicated).

### Benefits and Harms of Anticoagulation and Antiplatelet Treatment for Nonvalvular AF

Our review found consistent evidence that anticoagulation reduces the risk of stroke and all-cause mortality and increases the risk of bleeding for people with nonvalvular AF who do not have a history of stroke or TIA (i.e., for primary prevention). Warfarin treatment (mean 1.5 years) was associated with a 68 percent reduction in ischemic stroke (pooled RR, 0.32 [95% CI, 0.20 to 0.51]) and 32 percent reduction in all-cause mortality (pooled RR, 0.68 [95% CI, 0.50 to 0.93]) compared with controls. For a population with baseline annual stroke risk of 4 percent (e.g., such as those with CHADS_2_ scores of 2), warfarin was associated with a corresponding NNT of 24 (95% CI, 17 to 36) to prevent one ischemic stroke over an average of 1.5 years of followup. For a population of 1,000 adults age 65 or older with an annual stroke risk of 4 percent, the results translate to an absolute reduction of approximately 28 ischemic strokes per year, an absolute reduction of 16 deaths per year, and an absolute increase of five major bleeding events per year. Aspirin was associated with reduction in mortality and ischemic stroke, but differences between aspirin and controls were not statistically significant. Of note, aspirin for the treatment of AF is either not recommended or is only recommended if the stroke risk is low (CHA_2_DS_2_-VASc score=1) (Appendix A Table 2). A previously published network meta-analysis^98^ included in our review found that NOACs (apixaban, dabigatran, edoxaban, and rivaroxaban) were not statistically different from VKAs for a composite outcome (any stroke and systemic embolism) or for all-cause mortality. VKAs and the NOACs showed greater reduction in risk of the composite outcome compared with aspirin.

Although we aimed to determine the benefits of treatment for asymptomatic, screen-detected older adults with nonvalvular AF, we found no trials or systematic reviews that focused on this population, and it is uncertain whether benefits of medications vary for symptomatic people and those who have never had symptoms (asymptomatic screen-detected people).

## Limitations

This review is limited in the ability to describe the direct evidence on the effectiveness or harms of screening for AF because we identified no eligible studies designed to address the overarching question (KQ 1). Therefore, we attempted to review literature that might establish an indirect chain of evidence from multiple questions that link screening to health outcomes (KQs 2 through 5). Table 6 provides a summary of key limitations of the evidence for each KQ.

We did not systematically review the evidence regarding the diagnostic accuracy of screening tests for AF or the accuracy of a 12-lead ECG conducted and interpreted within primary care settings. A 2017 health technology assessment synthesized studies conducted in a variety of settings (e.g., primary care, preoperative clinics, cardiology practices) that were related to diagnostic accuracy for AF.^104^ Based on data from seven studies, a 12-lead ECG interpreted by a nurse, general practitioner, or the ECG machine’s automated algorithm had a sensitivity of 92.7 percent (95% CI, 85.9% to 96.8%) and a specificity of 97.4% (95% CI, 95.0% to 98.9%) when compared with a reference standard of cardiologist interpretation. The authors derived these estimates from a hierarchical summary receiver operating characteristics curve. Across individual studies, sensitivity ranged from 68 percent to 100 percent and specificity ranged from 76 percent to 100 percent.

We did not systematically review all the evidence on rate control or rhythm control for AF; however, we summarized the recommendations on rate and rhythm control and the main evidence cited by those recommendations in Appendix A (Contextual Question 3a). Briefly, rhythm control is not recommended for asymptomatic adults with AF. Some guidelines, including those of the American Heart Association/American College of Cardiology/Heart Rhythm Society, recommend rate control to achieve a resting heart rate under 110 beats per minute for asymptomatic patients with AF based on the results from one trial (Rate Control Efficacy in Permanent Atrial Fibrillation: a Comparison between Lenient versus Strict Rate Control II [RACE II]) that concluded noninferiority of a lenient (<110 bpm) versus a strict (<80 bpm resting HR) rate control strategy in patients with permanent AF (for up to 12 months prior to enrollment).^51^ RACE II compared strict (<80 bpm resting HR) versus lenient (<110 bpm) rate control strategies in patients with permanent AF (for up to 12 months prior to enrollment). Forty-three percent of the study population was asymptomatic at baseline (defined as no palpitations, dyspnea, or fatigue), although it is not clear how many were never symptomatic (i.e., how many did not have symptoms around the time of their AF diagnosis or prior to it).

We did not include head-to-head trials of treatments for AF because our intention was to provide evidence on benefits of treatments compared with placebo/no treatment for the USPSTF rather than to assess the comparative effectiveness of treatments. Nevertheless, we did include and summarize a previously published network meta-analysis that provides comparative effectiveness estimates.

For KQs 4 and 5, all five included trials that evaluated warfarin began in the 1980s and were completed by 1992. Baseline population rates of stroke may have decreased since then with the increased use of statins and antihypertensive medications. Therefore, the absolute benefits of anticoagulation compared with placebo/control might be less in current clinical practice than in the RCTs, although the relative benefits would not be expected to have changed. Also, the current clinical approach to anticoagulation has evolved since the trials were conducted. Target INR ranges in current practice are typically 2 to 3 for patients with nonvalvular AF. The INR target ranges in the included trials were 2.8 to 4.2 (AFASAK I), 1.5 to 2.7 (BAATAF), 2 to 3 (CAFA), 2 to 4.5 (SPAF I), and 1.4 to 2.8 (SPINAF). In three of the trials (BAATAF, SPAF I, and SPINAF), PT was used to adjust warfarin doses, and the corresponding INR target ranges and mean INRs achieved were estimated. There is some uncertainty about the INR target ranges of these three trials because they used PT targets and conversion of PT to INR cannot be done precisely because of uncertain sensitivity of thromboplastin agents. In addition, trials enrolled somewhat selected participants and followed protocols (e.g., for warfarin dosing); routine clinical practice may not be as rigorous, and whether the results apply to routine clinical practice might be questioned. However, observational studies of anticoagulation suggest that the results are applicable to routine clinical practice.^105^ Finally, the trials included in KQs 4 and 5 that evaluated warfarin had a mean duration of followup from 1.2 to 2.2 years (on average, 1.5 years of followup) and were stopped early. It is possible that estimates for reduction in strokes and all-cause mortality are not accurate for lifelong anticoagulation.

The aspirin evidence may be somewhat limited by heterogeneity of doses used. Just one (SPAF I) of the trials evaluating aspirin used a full-dose aspirin (325 mg daily), and it found benefit for stroke reduction, unlike the pooled data.

## Future Research Needs

To better understand the potential benefits and harms of screening for AF with ECG, randomized trials of asymptomatic persons that directly compare screening with usual care and assess health outcomes are needed (i.e., trials that address KQ 1, the overarching question, and KQ 3 on harms). The ongoing STROKESTOP study may help fill this evidence gap. Other relevant ongoing RCTs are focused on detecting AF (KQ 2) as the primary outcome; these include SCREEN-AF (NCT02392754), IDEAL-MD (NCT02270151), D_2_AF,^106^ and mSToPS.^107^ SCREEN-AF plans to randomize 822 Canadians age 75 or older with hypertension to screening with Zio XT Patch (2-week continuous ECG monitoring) plus home blood pressure monitoring or to no screening. The primary outcome is new diagnosis of AF or atrial flutter within 6 months. Secondary outcomes include stroke, TIA, and major bleeding. IDEAL-MD is a cluster randomized trial in the Netherlands aiming to enroll 16,000 participants (from 42 general practices randomized to screening vs. usual care) age 65 or older. In the screening arm, a single lead handheld ECG recorder (for up to 1 minute) will be used at every visit to the practice for 1 year. The primary outcome is new diagnosis of AF over 1 year. Secondary outcomes include major cardiovascular events and all-cause mortality over 1 year. Finally, the Detecting and Diagnosing Atrial Fibrillation (D_2_AF) trial (listed in The Netherlands Trial Register, NTR4914) is a multicenter cluster randomized trial that will compare different approaches to case finding among adults 65 or older.^106^ The case finding protocol includes pulse palpation, sphygmomanometer with automated AF detection, and handheld single-lead ECG. Participants with a positive test and a random sample of those with negative tests will undergo 12-lead ECG. Participants without AF on 12-lead ECG will undergo additional continuous Holter monitoring and use the handheld single-lead ECG at home for 2 weeks. The primary outcome is the difference in detection rate of new AF over 1 year (compared with usual care).

## Conclusion

There is uncertainty about the benefits and harms of screening for AF with ECG, and screening can potentially lead to harms that have not been well studied. Although screening can detect previously unknown cases of AF, it has not been shown to detect more cases than opportunistic screening that is focused on pulse palpation. Most older adults with previously unknown AF have a stroke risk above the threshold for anticoagulation. Multiple treatments for AF reduce the risk of stroke and all-cause mortality, and increase the risk of bleeding, but trials have not assessed whether treatment of screen-detected asymptomatic older adults results in better health outcomes than treatment after detection by usual care or after symptoms develop.