# Chapter 3 Results

## Literature Search

We identified 4,121 unique records and assessed 389 full-text articles for eligibility (Figure 2). We excluded 367 studies for various reasons, detailed in Appendix C and included 17 unique studies (described in 22 publications) of good or fair quality. Of the included studies, one RCT reported some eligible outcomes for KQ 1 (although the study was focused on KQ 2 outcomes), three RCTs (described in 7 publications) addressed detection of previously undiagnosed AF (KQ 2), and one of those two (described in 5 publications) was also included for KQ 3 (harms of ECG screening). Six RCTs (described in 7 publications) and eight systematic reviews addressed the benefits (KQ 4) and/or harms (KQ 5) of anticoagulation or antiplatelet therapy. Details of quality assessments of included studies and studies excluded because of poor quality are in Appendix D Tables 1–6.

Figure 2 Summary of Evidence Search and Selection

^a^ We also used one study rated poor quality in sensitivity analyses.^74^

Abbreviations: SR=systematic review; WHO ICTRP=World Health Organization International Clinical Trials Registry Platform.

Figure 2 is a flow chart that summarizes the search and selection of articles. 2742 records were identified by searching PubMed and 1324 records by searching the Cochrane Library. Additional records were identified through other sources, including 415 from ClinicalTrials.gov, 101 from WHO ICTRP, 71 by hand searching, 3 by suggestions from reviewer, and 1 identified through study author contact. After removal of duplicates, 4121 titles and abstracts were screened for potential inclusion. Of these, 389 were deemed appropriate for full-text review to determine eligibility. After full-text review, 367 were excluded: 5 for wrong language/non-English, 25 for wrong population, 34 for wrong screening/intervention, 171 for wrong or no comparator, 27 for wrong or no outcome, 8 for wrong setting, 83 for wrong study design, 1 for wrong country, 1 for only having an abstract available, 1 for being outdated (more recent data was available), 5 for not meeting the current review’s relevance criteria, and 6 for poor quality. 22 articles representing 17 studies were included in the qualitative synthesis of the systematic review. 1 article representing 1 trial was included for KQ1. 7 articles representing 3 studies were included for KQ2. 5 articles representing 1 trial were included for KQ3. 7 articles representing 6 trials and 7 systematic reviews were included for KQ4. 7 articles representing 6 trials and 7 systematic reviews were included for KQ5. In the quantitative synthesis, 7 articles representing 6 trials were included for KQs 4 and 5.

## Results by KQ

### KQ1 Does Screening for AF With ECG Improve Health Outcomes in Asymptomatic Older Adults?

We found no eligible studies that focused on this question and have reported results. One fair-quality RCT of 1,001 participants and a primary outcome of time to diagnosis of AF (a KQ 2 outcome), Assessment of REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation (REHEARSE-AF), reported limited information on health outcomes but was not designed or powered to evaluate them.^76^ The trial is described in more detail in KQ 2. For all-cause mortality, the authors reported three deaths in the screening group and five in the no screening group (p=0.51). For a composite of stroke, TIA, or systemic embolism, there were 6 versus 10 events, respectively (hazard ratio [HR] 0.6 [95% CI, 0.2 to 1.7]; p=0.34).

We identified another RCT, the STROKESTOP Study, that is currently ongoing and has not yet reported results for the outcomes and comparisons eligible for our review.^77–79^ The primary outcome listed in clinicaltrials.gov is reduced incidence of stroke among 75-year-old subjects, with a planned time frame of 5 years (and interim analysis after 3 years). The estimated study completion date is March 2019.^79^ The STROKESTOP study randomized 28,768 persons ages 75 to 76 years in two regions in Sweden to screening program invitations for AF or to no invitations. More than half of those invited (53.8%) participated in the screening. The screening program used an initial ECG and then a handheld one-lead ECG recorder for intermittent recordings over 2 weeks (average of 26 completed recordings per participant). The handheld recorder uses an integrated mobile transmitter to send 30-second ECG strips to a database. Participants were instructed to place their thumbs on the device twice daily and whenever they noticed palpitations. The detection rate for previously unknown AF was 3 percent (95% CI, 2.7 to 3.5; 218/7,173 participants) in the intervention group; incidence data for AF in the control group has not yet been reported. Of the new cases detected in the intervention group, few of them were identified on the initial ECG (37/218=17%). More than 90 percent of the new cases of AF accepted initiation of oral anticoagulant therapy.

### KQ2 Does Systematic Screening for AF With ECG Identify Older Adults With Previously Undiagnosed AF More Effectively Than Usual Care?

#### Characteristics of Included Trials

We included three fair-quality RCTs (described in 7 articles).^76,^ ^80–85^ The characteristics of the included studies are summarized in Table 2, and the results are summarized in Table 3. Two trials compared systematic screening with opportunistic screening;^80–85^ one of those also compared systematic screening with no screening.^80–84^ The third trial compared systematic, twice-weekly screening using a handheld ECG versus no screening.^76^

Table 2 Characteristics of Included Randomized, Controlled Trials Evaluating Detection of Previously Undiagnosed Atrial Fibrillation (KQ 2)

First Author, Year Trial Name | G1 (N) G2 (N) G3 (N) | Screening Approaches | Source of Patients | Country | Duration of Study, Months | Mean Age | % F | Quality
Fitzmaurice, 2014^81^; Fitzmaurice, 2007^80^; Mant, 2007^82^; Hobbs, 2005^83^; Swancutt, 2004^84^ SAFE | Opportunistic screening (4,933) Systematic screening (4,933) No screening (4,936) | Opportunistic screening: Nurses and physicians encouraged to record pulse during routine visits; patients with irregular pulses invited to attend a nurse-led screening clinic and have 12-lead ECG Systematic screening: Patients invited by letter to attend a nurse-led screening clinic where their radial pulse was palpated, and a 12-lead ECG was performed | 50 primary care practices; cluster RCT with randomiz-ation at the practice level | United Kingdom | 12 | 75.3 | 57.4 | Fair
Halcox, 2017^76^ REHEARSE-AF | Systematic screening (500) No screening (501) | Systematic screening: Twice-weekly 30-second, single-lead ECG using a handheld device, plus additional recordings if symptomatic No screening: followed up as normal by their general practitioner | General practices | United Kingdom | 12 | 72.6 | 53.4 | Fair
Morgan, 2002 ^85^ | Opportunistic screening (1,502) Systematic screening (1,499) | Opportunistic screening: Nurses and physicians were encouraged to record pulse during routine visits; if pulse was suspicious for atrial fibrillation, they decided whether to request ECG depending on the history and clinical context Systematic screening: Patients invited by letter to attend a nurse-led screening clinic where their radial pulse was palpated, and a lead II rhythm strip was performed | 4 general practices | United Kingdom | 6 | 75.5 | 58.8 | Fair

Abbreviations: ECG=electrocardiogram; F=Female; G=group; N=sample size; SAFE=Screening for Atrial Fibrillation in the Elderly.

Table 3 Results of Included Randomized, Controlled Trials for KQs 2 and 3

First Author, Year Trial Name | G1 (N) G2 (N) G3 (N) | Atrial Fibrillation G1 N (%) G2 N (%) G3 N (%) Between-Group Difference or OR (95% CI) | Anxiety G1 N (%) G2 N (%) Mean State Anxiety (95% CI), p-Value (Unadjusted Except Where Indicated), Response Rate (Questionnaires Completed/Sent)
Fitzmaurice, 2014^81^; Fitzmaurice, 2007^80^; Mant, 2007^82^; Hobbs, 2005^83^; Swancutt, 2004^84^ SAFE | Opportunistic screening (4,933) Systematic screening (4,933) No screening (4,936) | New cases identified (percentage of those randomized; percentage if excluding those with a history of atrial fibrillation and those with missing notes from the denominator): 75 (1.5; 1.64) 74 (1.5; 1.62) 47 (0.95; 1.04) Screening (either approach) vs. no screening Between-group difference: 0.59% (0.20% to 0.98%); the difference was similar and statistically significant for both opportunistic vs. no screening and systematic vs. no screening (p≤0.02 for both) OR: 1.58 (1.12 to 2.22), p=0.01 without accounting for baseline prevalence OR: 1.61 (1.14 to 2.29), p=0.0085 accounting for baseline prevalence Opportunistic screening vs. systematic screening Between-group difference: 0.02% (-0.5% to 0.5%) OR: 0.99 (0.72 to 1.37), p=0.95 | Systematic vs. opportunistic Baseline: 35.78 (33.80 to 37.76) vs. 36.44 (34.35 to 38.53), p=0.695, 66% (493/750) Postscreening: 28.77 (28.27 to 29.26) vs. 28.25 (26.78 to 29.73), p=0.732, 75% (1940/2595) After 17 months: 35.92 (34.29 to 37.55) vs. 37.50 (35.82 to 39.18), p=0.089, p=0.844 (adjusted), 69% (535/777) Screen positive (n=142) vs. screen negative (n=128) (after 17 months): 38.12 (35.89 to 40.35) vs. 34.61 (32.41 to 36.81), p=0.028
Halcox, 2017^76^ REHEARSE-AF | Systematic screening (500) No screening (501) | New cases identified 19 5 Hazard ratio, 3.9; 95% CI, 1.4 to 10.4, p=0.007 | Study was rated as poor quality for anxiety outcomes
Morgan, 2002 ^85^ | Opportunistic screening (1,502) Systematic screening (1,499) | New cases identified 7 (0.5) 12 (0.8) OR: 1.7 (0.68 to 4.4), p=0.25 All cases identified (most of these had a prior diagnosis of atrial fibrillation) 19 (1.3) 67 (4.5) Between-group difference: 3.2% (2.0% to 4.4%), p<0.001 | NR

Abbreviations: CI=confidence interval; G=group; n=number (of patients); N=sample size; NR=not reported; OR=odds ratio; SAFE=Screening for Atrial Fibrillation in the Elderly.

The Screening for Atrial Fibrillation in the Elderly (SAFE) study was a multicenter cluster randomized trial (14,802 participants) that randomized 50 primary care practices to screening versus no screening.^80–84^ Within the 25 practices randomized to screening, individual participants were randomized to systematic screening or opportunistic screening. Those in the systematic screening arm were invited by mail to attend a nurse-led screening clinic where their radial pulse was palpated, and a 12-lead ECG was performed. For those in the opportunistic arm, paper or computer flags were placed in their notes to encourage pulse recording; those with an irregular pulse were invited to attend a screening clinic and have a 12-lead ECG. For the screening practices, primary care physicians and other members of the health care team attended educational days covering the importance of detecting AF and available treatment options. The second trial randomized 3,001 participants from four primary care practices to systematic screening or opportunistic screening.^85^ Those in the systematic screening arm were invited by mail to attend a nurse-led screening clinic where their radial pulse was palpated and a lead II rhythm strip was performed. Those unable to attend the clinic were offered screening at home. For those in the opportunistic arm, a reminder flag was placed in their notes. Nurses or physicians who assessed the pulse during routine care of the patient were asked to indicate on the flag whether the pulse was suspicious of AF and whether they wished to investigate further with an ECG. Nurses conducting screenings received 2 hours of training in the clinical assessment of the pulse rhythm. The third trial, REHEARSE-AF, randomized 1,001 participants with a CHA_2_DS_2_-VASc score of 2 or more to a twice-weekly screening with a single-lead ECG using a handheld device or to no screening.

All three trials were conducted in the United Kingdom. Followup lasted 12 months for the SAFE study and for REHEARSE-AF and 6 months for the other trial. All trials enrolled patients age 65 years or older; the mean age of participants was 72 to 75 years. More than half of participants were women in all three trials (53% to 59%). None of the trials reported information about the race or ethnicity of participants. Only REHEARSE-AF reported the baseline prevalence of hypertension (54%), diabetes (27%), heart failure (1.4%), or the proportion of participants with a history of TIA or stroke (6.5%). Only REHEARSE-AF reported baseline stroke risk scores for participants; the mean (SD) CHA_2_DS_2_-VASc score was 3 (1). The SAFE study reported the CHADS_2_ scores for the 149 newly identified cases of AF.^81^ More cases in the systematic screening arm had scores of 2 or more than in the opportunistic arm, but the difference was not statistically significant (43.2% [95% CI, 32.6% to 54.6%] vs. 29.3% [20.2% to 40.4%], p=0.077).

#### Results of Included Trials

All three trials focused on detection of AF. In the SAFE study, two cardiologists masked to allocation assessed whether ECGs showed AF; a third arbitrated any disagreements. The trial that randomized 3,001 participants reported AF ascertainment by a single observer (masking not reported) who reviewed medical records. In REHEARSE-AF, an unmasked study cardiologist confirmed all AF diagnoses. The trials did not find a significant difference between systematic and opportunistic screening for detection of new cases of AF (Figure 3 and Table 3). The SAFE study reported about a 60 percent increase in the odds of detecting new cases with either screening approach compared with no screening (Figure 3 and Table 3). REHEARSE-AF also reported that more new cases of AF were detected in those undergoing screening compared with no screening (19 vs 5; HR, 3.9 [95% CI, 1.4 to 10.4]; risk difference, 2.8% [95% CI, 0.9% to 4.7%]; odds ratio [OR], 3.9 [95% CI, 1.5 to 10.6]).

Figure 3 Odds of Detecting New Cases of Atrial Fibrillation and Absolute Difference in New Cases Detected, by Comparison

Analyses for this figure used the full study denominators. If using smaller denominators that exclude persons determined to have a prior history of AF, the results were almost identical.

Abbreviations: CI=confidence interval; G=group; ICU=intensive care unit; IG=intervention group; INR=international normalized ratio; No.=number; OR=odds ratio; RD=risk difference; SAFE=Screening for Atrial Fibrillation in the Elderly.

Figure 3 displays a forest plot reporting the risk difference and odds ratio of detecting new cases of atrial fibrillation for 3 trials. Two trials (SAFE, 2007 and Morgan, 2002) compared systematic screening with opportunistic screening, 2 trials (SAFE, 2007 and REHEARSE-AF, 2007) compared systematic screening with no screening, 1 trial (SAFE, 2007) compared opportunistic screening with no screening, and 1 trial (SAFE, 2007) compared any screening with no screening. The trials did not find a significant difference between systematic and opportunistic screening for detection of new cases of AF.

The SAFE study reported that more new cases of AF were detected in those undergoing screening (systematic or opportunistic) than in the no screening group (149 vs. 47; 1.63% vs. 1.04%; OR, 1.58 [95% CI, 1.12 to 2.22]). There was no difference in detection of new cases between opportunistic and systematic screening groups (75 vs. 74; 1.64% vs. 1.62%; OR, 0.99 [95% CI, 0.7 to 1.4]). The trial that used lead II rhythm strips found no statistically significant difference between systematic and opportunistic screening groups, although there were few new cases and the CI was wide (12 vs. 7; 0.8% vs. 0.5%; OR, 1.7 [95% CI, 0.7 to 4.4]).

The SAFE study reported subgroup analyses by sex and age for systematic or opportunistic screening compared with no screening. The subgroup analyses show that screening may not increase detection of new cases among women. Men in the systematic (44 vs. 16; OR, 2.68 [95% CI, 1.52 to 4.73]) and opportunistic screening groups (38 vs. 16; OR, 2.33 [95% CI, 1.30 to 4.15]) had greater odds of having AF diagnosed than men in the no screening group. The odds were not significantly increased for women in either screening group compared with no screening (30 vs. 31; OR, 0.98 [95% CI, 0.59 to 1.61] and 37 vs. 31; OR, 1.20 [95% CI, 0.74 to 1.92], respectively). Patients ages 65 to 74 years and those older than 75 had similar odds of having AF diagnosed in both the systematic screening (30 vs. 18; OR 1.62 [95% CI, 0.91 to 2.88] and 44 vs. 29; OR, 1.56 [95% CI, 0.98 to 2.49], respectively) and opportunistic screening arms (31 vs. 18; OR, 1.63 [95% CI, 0.92 to 2.89] and 44 vs. 29; OR, 1.60 [95% CI, 1.00 to 2.56], respectively), compared with no screening.

### KQ3 What Are the Harms of Screening for AF With ECG in Older Adults?

#### KQ3a Do the Harms of Screening Vary for Subgroups Defined by Stroke Risk, Age, Sex, or Race/Ethnicity?

We identified no eligible studies assessing labeling or harms of subsequent procedures or interventions initiated because of screening with ECG (e.g., subsequent ablation with complications). One of the trials included for KQ 2, the SAFE study, assessed anxiety associated with screening. It did not, however, collect anxiety data from patients within the no screening arm of the study, which would have allowed for a comparison between screening and no screening. As a result, we cannot make conclusions about whether screening causes more or less anxiety than usual care.

The SAFE study used the Spielberger Six-Item Anxiety Questionnaire (S6AQ) to evaluate anxiety in the opportunistic and systematic screening arms at three different time points.^80^ To allow for baseline score adjustment later in the study, 750 patients (out of more than 9,000 in the screening groups) were sent the S6AQ before randomization into either the opportunistic or screening arm. Patients who underwent ECGs in both screening arms were sent the S6AQ immediately after ECG screening. Seventeen months after baseline, investigators sent the S6AQ to all patients who screened positive and all 750 patients who had received the questionnaire before randomization.^51,^ ^83^ Of the 750 questionnaires sent to patients before randomization, 620 (84%) were returned and 493 were completed (66%). Investigators provided S6AQs to all 2,595 patients who underwent ECG screening immediately after ECG screening, and 1,940 were returned (response rate 75%). Of the 777 questionnaires sent to patients 17 months after baseline, 535 were returned (response rate 69%).^83^

Anxiety levels were not significantly different between the opportunistic and systematic screening arms at baseline (Mean Spielberger State Anxiety inventory 35.78 [95% CI, 33.80 to 37.76] vs. 36.44 [95% CI, 34.35 to 38.53], p=0.695). The two arms had similar results on the questionnaires administered immediately after screening (28.77 [95% CI, 28.27 to 29.26] vs. 28.25 [95% CI, 26.78 to 29.73], unadjusted p=0.732). Mean scores for the systematic and opportunistic screening arms were also similar at 17 months (35.92 [95% CI, 34.29 to 37.55] vs. 37.50 [95% CI, 35.82 to 39.18], p=0.844 adjusted for baseline scores). When comparing screen-positive and screen-negative respondents, anxiety scores collected 17 months after initial chart review were significantly different (p=0.028), with screen-positive participants having higher mean anxiety scores (38.12 [95% CI, 35.89 to 40.35]) than screen-negative participants (34.61, 95% CI, 32.41 to 36.81) (unadjusted p=0.028), although relatively few participants were included in that analysis (142 screen-positive and 128 screen-negative participants).^83^

Potential harms of screening include overdiagnosis (e.g., from misinterpretation of ECGs) and overtreatment (e.g., warfarin for someone without AF). An analysis of 2,595 participants in the SAFE study from 49 general practices assessed the accuracy of general practitioners and interpretive software for diagnosing AF.^82^ General practitioners missed 20 percent of AF cases on 12-lead ECG and misinterpreted 8 percent of sinus rhythm cases (as AF) compared with reference standard cardiologists (sensitivity 79.8 [95% CI, 70.5 to 87.2]; specificity 91.6 [90.1 to 93.1]; 79 out of 99 AF cases detected; misinterpreted sinus rhythm as AF for 114 out of 1,355). False-positive rates varied from 0 to 44 percent for individual general practitioners (standard deviation, 13%). Combining general practitioners’ interpretations with those of interpretive software increased the sensitivity (91.9 [86.6 to 97.3]), but specificity was about the same (91.1 [89.6 to 92.6]). Use of single-lead or limb-lead ECGs resulted in slightly lower specificity.

### KQ4 What Are the Benefits of Anticoagulation or Antiplatelet Therapy on Health Outcomes in Asymptomatic, Screen-Detected Older Adults With AF?

Although we aimed to determine the benefits of treatment for asymptomatic, screen-detected older adults with AF, we found no trials or systematic reviews that focused on asymptomatic, screen-detected participants. We included six RCTs of people who were not screen-detected; most had long-standing persistent nonvalvular AF; few had a history of TIA or stroke (<8%); prevalence of baseline or past symptoms (e.g., palpitations, dyspnea) was generally not reported. Three evaluated warfarin,^86–88^ one evaluated aspirin,^89^ and two (described in 3 articles) evaluated both warfarin and aspirin.^90–92^ The characteristics of the included RCTs are summarized in Table 4 and Table 5, and the results are summarized in Appendix E Tables 1 and 2. One trial evaluating aspirin was excluded for poor quality but was used in sensitivity analyses.^74^ We included seven systematic reviews (Appendix E Table 3): three were traditional systematic reviews with meta-analyses,^44,^ ^93,^ ^94^ three were meta-analyses of individual patient data,^95–97^ and one was a network meta-analysis.^98^ The systematic reviews included a total of 38 unique studies (including the 6 RCTs in our review). Many of the unique studies included in other systematic reviews were not eligible for this review because they evaluated secondary prevention (i.e., some of the eligible systematic reviews evaluated treatments for people with a history of TIA or stroke in addition to addressing primary prevention) or because they were head-to-head studies (most of the 21 studies included in the network meta-analysis were head-to-head studies).

Table 4 Characteristics of Included Randomized, Controlled Trials for KQs 4 and 5: Part 1

First Author, Year Trial Name | G1 (N) G2 (N) G3 (N) | Source of Patients | Country | Mean Followup, yr | Mean Age | % F | % Non-white
Petersen, 1989^90^ AFASAK | Warfarin, adjusted dose (335) Aspirin 75 mg daily (336) Placebo (336) | Those with chronic AF from 2 outpatient ECG laboratories | Denmark | 1.2 | 74 (median) | 46 | NR
The Boston Area Trial for Atrial Fibrillation Investigators, 1990^86^ BAATAF | Warfarin, adjusted dose (212) Control^a^ (208) | 32 centers and 3 private medical offices | United States | 2.2 | 68 | 28 | NR
Stroke Prevention in Atrial Fibrillation Investigators, 1990 & 1991^91,^ ^92^ SPAF I | [underlined: Group 1 (anti-coagulation candidates)] Warfarin, adjusted dose (210) Aspirin 325 mg/day (206) Placebo (211) [underlined: Group 2 (non-anticoagulation candidates)] Aspirin 325 mg/day (346) Placebo (357) | 15 centers | United States | 1.3 | 67 | 29 | 16
Connolly, 1991^87^ CAFA | Warfarin, dose adjusted per subject (187) Placebo (191) | 11 centers (hospitals, outpatient laboratories, and direct physician referrals) | Canada | 1.3 | 68 | 25 | NR
Ezekowitz et al, 1992^88^ SPINAF | Warfarin, adjusted dose (4-mg/day and adjusted to meet PT ratios) (260) Placebo (265)^b^ | 16 Department of Veterans Affairs medical centers | United States | 1.7 | 67 | 0 | NR
Sato et al, 2006^89^ JAST | Aspirin 150-200 mg/day (426) Control (445) | 13 centers and 76 affiliated hospitals | Japan | 2.1 | 65 | 30 | NR

Table 5 Characteristics of Included Randomized, Controlled Trials for KQs 4 and 5: Part 2

First Author, Year Trial Name | % TIA % Stroke | % HF % Heart Valve dz % CAD % HTN % DM | Target INR (PT) | TTR%
Petersen, 1989^90^ AFASAK | 2 4 | 52 NR 8 prior MI 32 12 | 2.8 to 4.2 (NR) | 73
The Boston Area Trial for Atrial Fibrillation Investigators, 1990^86^ BAATAF | NR 3 | 26 23 MR>1+ 52 51 15 | 1.5 to 2.7 (1.2 to 1.5) | 83
Stroke Prevention in Atrial Fibrillation Investigators, 1990 & 1991^91,^ ^92^ SPAF I | 7 Stroke or TIA | 19 6 MVP 8 with prior MI 52 16 | G1: 2 to 4.5 (1.3 to 1.8) | 71 within target PT
Connolly, 1991^87^ CAFA | 4 Stroke or TIA | 22 NR 13 prior MI 39 12 | 2 to 3 (NR) | 44
Ezekowitz et al, 1992^88^ SPINAF | NR 8 | 30 15 MR>1+ 19 prior MI 58 18 | 1.4 to 2.8 (1.2 to 1.5) | 56
Sato et al, 2006^89^ JAST | 2.5 | 9 NR 0 38 14 | NA | NA

a Control group was allowed to take aspirin.

b Study reported findings separately for patients with and without previous cerebral infarctions. Patients with previous cerebral infarction: warfarin (21) vs. control (25).

Abbreviations: AF=atrial fibrillation; AFASAK=Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulation study; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAD=coronary artery disease; CAFA=Canadian Atrial Fibrillation Anticoagulation study; DM=diabetes mellitus; dz=disease; ECG=electrocardiogram; F=female; G=group; HF=heart failure; HTN=hypertension; INR=international normalized ratio; JAST=Japan Atrial Fibrillation Stroke Trial; mg=milligrams; MI=myocardial infarction; MR=mitral regurgitation; N=sample size; MR=mitral regurgitation; MVP=mitral valve prolapse; NA=not applicable; NR=not reported; OR=odds ratio; PT=prothrombin time; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study; TIA=transient ischemic attack; TTR=time in therapeutic range; yr=year.

#### Warfarin: Characteristics of RCTs

Five trials (described in 6 articles) evaluated warfarin.^86–88,^ ^90–92^ Four of the five trials compared warfarin with a placebo (Atrial Fibrillation, ASpirin, and AntiKoagulation study [AFASAK I],^90^ Canadian Atrial Fibrillation Anticoagulation [CAFA],^87^ Stroke Prevention in Atrial Fibrillation [SPAF I],^91,^ ^92^ Stroke Prevention in Nonrheumatic Atrial Fibrillation [SPINAF]^88^) and one (Boston Area Anticoagulation Trial for Atrial Fibrillation [BAATAF])^86^ compared warfarin with no treatment. BAATAF allowed participants in the no treatment group to take aspirin (and 46% of all patient years in the control group were contributed by participants taking aspirin), but use of aspirin or other antithrombotic medications was not permitted in the four placebo-controlled trials. Two trials (AFASAK I and SPAF I) were three-arm studies that included aspirin arms (in addition to warfarin and placebo or no treatment). Two trials were double-blind (CAFA, SPINAF), and three were open label (AFASAK I, BAATAF, SPAF I). Three trials were conducted in the United States (BAATAF, SPAF I, and SPINAF), one in Canada (CAFA), and one in Denmark (AFASAK I). Mean duration of followup ranged from 1.2 to 2.2 years. All five trials began in the 1980s and were completed by 1992. All five trials were stopped early, primarily because of evidence favoring warfarin for stroke reduction.

None of the trials focused on participants who were detected by screening in primary care or the general population. The mean age of participants ranged from 67 to 74 years. Most participants were men, with four out of five trials enrolling fewer than 30 percent women. Just one trial reported any information about the race or ethnicity of participants (16% were nonwhite in SPAF I). Few participants had a history of TIA or stroke (range 3% to 8%). The baseline prevalence of hypertension and diabetes ranged from 32 to 58 percent and 12 to 18 percent, respectively. AFASAK I and SPINAF did not include participants with paroxysmal AF; the other three trials reported that 7 percent to 34 percent had paroxysmal AF. Most participants in the trials had AF for more than a year. Three trials (CAFA, SPAF I, and BAATAF) reported that between 19 percent and 32 percent had AF for less than a year; SPINAF I reported that 12 percent had AF less than 6 months (and a mean duration of AF of 8 years); and AFASAK I did not report information about the duration of AF prior to enrollment. Baseline stroke risk (e.g., CHADS_2_) was not reported by any of the trials because stroke risk scores used in current practice were not yet developed; some future publications have used the baseline characteristics of subjects to estimate that the mean CHADS_2_ scores of participants in these trials ranged from 1 to 1.6.^98^

All trials titrated doses of warfarin on the basis of either prothrombin time (PT) or international normalized ratio (INR). The INR target ranges spanned from 1.4 to 4.5. The mean INRs achieved ranged from 2 to 2.6. The reported time in therapeutic range (TTR) spanned from 44 percent (CAFA) to 83 percent (BAATAF), and three trials reported TTR over 70 percent (SPAF I, AFASAK I, and BAATAF).

#### Warfarin: Results of Meta-Analyses

##### All-Cause Mortality

Across included trials, the mean annual mortality rate in control groups was 5 percent. Warfarin treatment over an average of 1.5 years was associated with a 32 percent reduction in all-cause mortality compared with controls (pooled RR, 0.68 [95% CI, 0.50 to 0.93]; I^2^=0%; 5 trials; 2,415 participants) (Figure 4).

Figure 4 Relative Risk of All-Cause Mortality, Cardiovascular-Related Mortality, All Ischemic Stroke, Moderately to Severely Disabling Stroke, Major Bleeding, Major Extracranial Bleeding, Intracranial Hemorrhage, and All Ischemic Stroke or Intracranial Hemorrhage for Warfarin Compared With Controls

All-cause mortality: SPINAF includes only those without a history of stroke. AFASAK includes data from a previously published meta-analysis that they obtained data from the original study authors.

Major bleeding: AFASAK did not specify bleeding severity of most bleeding events; it reported 1 fatal intracerebral hemorrhage in the warfarin group and only reported bleeding events leading to withdrawal from study, 21 for warfarin and 0 for placebo. BAATAF defines major bleeding as intracranial bleeding, fatal bleeding, or bleeding that led to a blood transfusion (four or more units of blood within 48 hours). SPAF I defines major bleeding as bleeding that involved the central nervous system, management requiring hospitalization with transfusion and/or surgery, or permanent residual impairment. CAFA defines major bleeding as life-threatening bleeding. SPINAF defines major bleeding as bleeding that required a blood transfusion, an emergency procedure, or removal of a hematoma or bleeding that led to ICU admission.

Intracranial Hemorrhage: SPAF I events included one fatal intracerebral hemorrhage and one subdural hematoma with full recovery in the warfarin group, and two subdural hematomas with full recovery in the placebo group.

Abbreviations: AFASAK=Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulation study; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; CG=control group; CI=confidence interval; ICU=intensive care unit; IG=intervention group; INR=international normalized ratio; No.=number; RR=risk ratio; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study; yr=year.

Figure 4 displays a forest plot reporting the relative risks of all-cause mortality, cardiovascular-related mortality, all ischemic stroke, moderately to severely disabling stroke, major bleeding, major extracranial bleeding, intracranial hemorrhage, and all ischemic stroke or intracranial hemorrhage for trials comparing treatment with warfarin vs. controls.

##### Cardiovascular-Related Mortality

Across included trials, the mean annual cardiovascular-related mortality rate in control groups was 2.8 percent. Warfarin treatment over an average of 1.5 years was associated with a reduction in cardiovascular-related mortality, but the difference between warfarin and controls was not statistically significant (pooled RR, 0.66 [95% CI, 0.33 to 1.29]; I^2^=53.3%; 5 trials; 2,415 participants) (Figure 4).

##### All Ischemic Stroke

Across included trials, the mean annual ischemic stroke rate in control groups was 4 percent. Four of the five trials reported a statistically significant reduction in ischemic strokes. Warfarin treatment over an average of 1.5 years was associated with a 68 percent reduction in ischemic strokes compared with controls (pooled RR, 0.32 [95% CI, 0.20 to 0.51]; I^2^=0%; 5 trials; 2,415 participants) (Figure 4).

##### Moderately to Severely Disabling Stroke

Across included trials, the mean annual event rate in control groups was 1.5 percent. Warfarin treatment over an average of 1.5 years was associated with a 62 percent reduction in moderately to severely disabling stroke compared with controls (pooled RR, 0.38 [95% CI, 0.19 to 0.78]; I^2^=0%; 5 trials; 2,415 participants) (Figure 4).

##### TIA

Across included trials, the mean annual event rate in control groups was 0.8 percent. Warfarin was associated with a reduction in TIAs, but the difference between warfarin and controls was not statistically significant (pooled RR, 0.66 [95% CI, 0.26 to 1.68]; I^2^=0%; 4 trials; 1,890 participants) (Appendix E Figure 1).

##### All Ischemic Stroke or Intracranial Hemorrhage

Across included trials, the mean annual event rate in control groups was 4.1 percent. Warfarin treatment over an average of 1.5 years was associated with a 62 percent reduction in all ischemic stroke or intracranial hemorrhage compared with controls (pooled RR, 0.38 [95% CI, 0.25 to 0.59]; I^2^=0%; 5 trials; 2,415 participants) (Figure 4).

#### Aspirin: Characteristics of RCTs

Our review included three RCTs (described in 4 articles) that evaluated aspirin.^89–92^ One trial, which was conducted in Spain and evaluated aspirin 125 mg daily versus 125 mg every other day versus control (Low-dose Aspirin, Stroke, Atrial Fibrillation [LASAF] pilot study), was excluded for poor quality but was used in sensitivity analyses.^74^ Two of the three included trials compared aspirin with placebo (AFASAK I^90^ and SPAF I^91,^ ^92^), and one (Japanese Atrial fibrillation Stroke Trial [JAST])^89^ compared aspirin with a control group taking no antiplatelet or anticoagulant therapy. The doses of aspirin used in the included trials were 75 mg daily (AFASAK I), 325 mg daily (SPAF I), and 150–200 mg daily (JAST). AFASAK I was a three-arm trial that also included a warfarin arm. SPAF I divided participants into two groups based on their eligibility for warfarin (i.e., willingness to take it, bleeding risk, and risk of embolism): those eligible for warfarin were randomized to warfarin, aspirin, or placebo, and those not eligible for warfarin were randomized to aspirin or placebo. Participants from both groups were combined in analyses comparing aspirin with placebo. AFASAK I and SPAF I were double-blind, and JAST was open label. SPAF I was conducted in the United States, AFASAK was conducted in Denmark, and JAST was conducted in Japan. On average, followup lasted 1.2 to 2.1 years. AFASAK I and SPAF I began in the 1980s and were concluded by 1991, and JAST began in 1998 and was stopped in 2002.

None of the trials focused on asymptomatic participants who were screen-detected. AFASAK I did not include participants with paroxysmal AF, but 33 percent of those in SPAF I and 45 percent of those in JAST had paroxysmal AF. The mean age of participants ranged from 65 to 74 years. Most participants in all trials were men; 29 to 46 percent of participants were women. SPAF I reported that 16 percent were nonwhite, and neither JAST nor AFASAK I reported on the race or ethnicity of their participants. Few participants had a history of TIA or stroke (range 2.5% to 7%). The baseline prevalence of hypertension and diabetes ranged from 32 to 52 percent and 12 to 15 percent, respectively.

#### Aspirin: Results of Meta-Analyses

##### All-Cause Mortality

Across included studies, the mean annual mortality rate in control groups was 4.2 percent. Aspirin treatment over an average of 1.5 years was associated with a lower risk of death than controls, but the difference between aspirin and controls was not statistically significant (pooled RR, 0.84 [95% CI, 0.62 to 1.14]; I^2^=0%; 3 trials; 2,663 participants) (Figure 5).

Figure 5 Relative Risk of All-Cause Mortality, Cardiovascular-Related Mortality, All Ischemic Stroke, Major Bleeding, Major Extracranial Bleeding, and All Ischemic Stroke or Intracranial Hemorrhage for Aspirin Compared With Controls

All-cause mortality: AFASAK includes data from a previously published meta-analysis that they obtained from the original study authors.

Major bleeding: AFASAK did not specify the severity of most bleeding events; it only reported that there were two aspirin bleeding episodes that required a blood transfusion and zero bleeding episodes in the placebo group. SPAF I defined major bleeding as bleeding that involved the central nervous system, management requiring hospitalization with transfusion and/or surgery, or permanent residual impairment. JAST defined major bleeding as fatal bleeding, bleeding that required hospital admission for treatment, bleeding that required a blood transfusion, or a decrease of hemoglobin concentration by more than 4g/dL.

Abbreviations: AFASAK=Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulation study; CG=control group; CI=confidence interval; g/dL=grams per deciliter; JAST=Japan Atrial Fibrillation Stroke Trial; IG=intervention group; INR=international normalized ratio; No.=number; RR=risk ratio; SPAF=Stroke Prevention in Atrial Fibrillation Study; yr=year.

Figure 5 displays a forest plot reporting the relative risks of all-cause mortality, cardiovascular-related mortality, all ischemic stroke, major bleeding, major extracranial bleeding, and all ischemic stroke or intracranial hemorrhage for trials comparing treatment with aspirin vs. controls.

##### Cardiovascular-Related Mortality

Across included trials, the mean annual cardiovascular-related mortality rate in control groups was 2.2 percent. Aspirin treatment over an average of 1.5 years was associated with a reduction in cardiovascular-related mortality, but the difference between aspirin and controls was not statistically significant (pooled RR, 0.86 [95% CI, 0.56 to 1.32]; I^2^=0%; 3 trials; 2,663 participants) (Figure 5).

##### All Ischemic Stroke

Across included trials, the mean annual ischemic stroke rate in control groups was 3.7 percent. Aspirin treatment over an average of 1.5 years was associated with a reduction in ischemic strokes, but the difference between aspirin and controls was not statistically significant (pooled RR, 0.76 [95% CI, 0.52 to 1.1]; I^2^=15.7%; 3 trials; 2,663 participants) (Figure 5).

##### Moderately to Severely Disabling Stroke

Two of the three included trials reported on disabling strokes (AFASAK I and SPAF I). Both reported nonstatistically significant reductions in events for those treated with aspirin (RR 0.57 [95% CI, 0.17 to 1.9] in AFASAK I over an average followup of 1.2 years, with 672 participants; RR 0.64 [95% CI, 0.29 to 1.4] in SPAF I over an average followup of 1.3 years, with 1,120 participants) (Appendix F Figure 7).

##### All Ischemic Stroke or Intracranial Hemorrhage

Across included trials, the mean annual event rate in control groups was 3.9 percent. Aspirin treatment over an average of 1.5 years was associated with a reduction in events, but the difference between aspirin and controls was not statistically significant (pooled RR, 0.81 [95% CI, 0.54 to 1.21]; I^2^=31.7%; 3 trials; 2,663 participants) (Figure 5).

#### Results of Previously Published Systematic Reviews and Meta-Analyses

Results of previously published systematic reviews^44,^ ^93–98^ were generally consistent with our findings and are summarized in Appendix E Table 3. Here we highlight the findings from those reviews that provide additional information (beyond what we have described already in this KQ). Overall, the included systematic reviews provide some additional details about subgroups (from individual patient data meta-analyses) and some information about head-to-head comparisons, including comparisons with novel oral anticoagulants (NOACs).

##### Warfarin vs. Placebo or Control

One systematic review from the Cochrane collaboration evaluated warfarin for primary prevention.^93^ It included the same five RCTs in our review but obtained unpublished data excluding the 3 to 8 percent of participants with prior stroke or TIA. The findings were very similar to those of our meta-analyses, although they reported ORs (e.g., for all-cause mortality, they reported OR 0.69 [0.50 to 0.94] vs. our pooled result of RR 0.68 [0.50 to 0.93]) (Appendix E Table 3).

##### Aspirin vs. Placebo or Control

One systematic review from the Cochrane collaboration evaluated aspirin for primary prevention.^94^ It included two of the three RCTs (AFASAK I and SPAF I) that were in our main analyses and included LASAF, which we excluded because of poor quality but used in sensitivity analyses. The review authors obtained unpublished data excluding participants with prior stroke or TIA. The findings were very similar to those of our meta-analyses, showing that aspirin treatment was associated with a reduced risk of several outcomes and that the difference between aspirin and controls was not statistically significant (e.g., for all-cause mortality, they reported OR 0.75 [0.54 to 1.04] vs. our pooled result of RR 0.84 [0.62 to 1.14]) (Appendix E Table 3). However, they reported one composite outcome that we did not pool data for (all stroke, myocardial infarction, or vascular death) and found a significant reduction in risk with aspirin compared with controls (OR, 0.71 [0.51 to 0.97]).

##### Subgroups

Three individual patient data meta-analyses used the Atrial Fibrillation Investigators database from clinical trials evaluating warfarin or aspirin.^95–97^ That database included all five warfarin trials described in this report (AFASAK I, CAFA, SPAF I, SPINAF, BAATAF) and two of the aspirin trials (AFASAK I and SPAF I). One evaluated subgroups based on sex and history of hypertension for both warfarin and aspirin,^95^ one evaluated whether benefits vary by age for both warfarin and aspirin,^97^ and one evaluated multiple subgroups for aspirin.^96^ The aspirin analyses are all limited by not including the JAST study (which was published after these analyses).

The individual patient data meta-analysis that evaluated subgroups based on sex and history of hypertension^95^ used the same five RCTs evaluating warfarin that we included in KQ 4. It reported that the efficacy of warfarin was consistent across subgroups. Warfarin was associated with a reduction in stroke for both men and women, without a statistically significant difference between them (relative risk reduction, 60% [35% to 76%] and 84% [55% to 95%], respectively). For aspirin, the analyses included two of the RCTs (AFASAK I and SPAF I) eligible for our report (JAST was not yet published). Aspirin was associated with a reduction in stroke for both men and women, without a statistically significant difference between them (relative risk reduction, all participants: 36% [4% to 57%]; p=0.03; men: 44% [3% to 68%], p=0.04; women: 23% [40% to 58%], p=0.38, test for interaction not reported). However, the effect of aspirin was found to vary by history of hypertension. For those with a history of hypertension, aspirin was associated with a reduction in stroke (relative risk reduction [RRR], 59% [28% to 77%]; p=0.002), but for those with no history of hypertension, it was not (10% [40% to 100%]; p=0.76; and p=0.02 for difference in effectiveness between those with and without hypertension).

The individual patient data meta-analysis that evaluated subgroups based on age^97^ used the same five RCTs evaluating warfarin that we included in KQ 4, but also included a secondary prevention trial (European Atrial Fibrillation Trial [EAFT], 439 participants treated with warfarin or placebo).^99^ Warfarin was associated with a reduced risk of ischemic stroke (compared with placebo/control) for all ages; for the assessment of relative benefit with increasing age, the interaction did not reach statistical significance (e.g., HR, 0.22 [95% CI, 0.11 to 0.41] for 50-year-olds; HR, 0.53 [0.35 to 0.81] for 90-year-olds, interaction of age and warfarin, p=0.07). For aspirin, the analyses included two of the RCTs (AFASAK I and SPAF I) eligible for our report and one secondary prevention trial (EAFT, 782 participants treated with aspirin or placebo). The relative benefit of aspirin for preventing ischemic stroke decreased significantly with increasing age. At age 50 years, the HR was 0.40 (95% CI, 0.22 to 0.72); by age 77 years, the HR no longer excluded the null; at age 82 years, the HR exceeded 1 (interaction of age and aspirin, p=0.01). Although the analyses included EAFT, the authors report conducting sensitivity analyses with serial exclusion of individual studies that did not alter estimates. Neither warfarin nor aspirin interacted significantly for cardiovascular events.

The individual patient data meta-analysis that evaluated multiple subgroups for aspirin^96^ included two of the RCTs (AFASAK I and SPAF I) eligible for our report and a secondary prevention trial (EAFT). The analyses considered age, sex, history of hypertension, systolic blood pressure 160 or lower versus not, history of CHF, and history of diabetes. The analyses reported finding no convincing evidence of specific subgroups for whom aspirin was more effective for reducing the risk of ischemic stroke. Like the individual patient data meta-analysis described above,^95^ the authors reported that those with a history of hypertension had a significant reduction in the risk of ischemic stroke (RR, 0.64 [95% CI, 0.46 to 0.89]), but those without a history of hypertension did not (RR, 0.98 [95% CI, 0.79 to 1.39]). Unlike the individual patient data meta-analysis above, however, the interaction between a history of hypertension and aspirin use was not significant (p=0.08). The difference between the two meta-analyses is likely because of including versus not including EAFT. A secondary (post hoc) analysis found that among patients without a previous stroke or TIA (thus excluding EAFT and 6% of participants from AFASAK I and SPAF I), those with a history of hypertension or diabetes had a greater reduction in ischemic stroke risk (RRR, 54% [17% to 74%]) than those without a history of hypertension or diabetes (RRR not reported) (interaction p=0.02).

##### Results of Previously Published Network Meta-Analysis

The one included network meta-analysis used 21 RCTs (96,017 participants) of treatment for nonvalvular AF.^98^ It was not limited to primary prevention populations, but most of the data was from studies in which most of the particiants had no history of stroke or TIA. Four of the 21 RCTs reported that more than 35 percent of their participants had a history of stroke or TIA: 100 percent in EAFT (warfarin vs. aspirin vs. placebo), 64 percent in the Japanese Rivaroxaban Once Daily Oral Direct Factor Xa Inhibition Compared with Vitamin K Antagonism for Prevention of Stroke and Embolism Trial in Atrial Fibrillation (rivaroxaban vs. warfarin), 55 percent in the Rivaroxaban Once Daily Oral Direct Factor Xa Inhibition Compared with Vitamin K Antagonism for Prevention of Stroke and Embolism Trial in Atrial Fibrillation (rivaroxaban vs. warfarin), and 38 percent in SPAF III (low-intensity fixed-dose warfarin adjusted to INR, 1.2–1.5 combined with aspirin 325 mg once daily vs. adjusted-dose warfarin with target INR, 2.0–3.0). The percentage of participants with a history of stroke or TIA was less than 10% in nine trials (AFASAK I, BAATAF, SPAF I, CAFA, SPAF II, AFASAK II, the Primary Prevention of Arterial Thromboembolism in Nonrheumatic Atrial Fibrillation study, Swedish Atrial Fibrillation Trial, and JAST) and ranged from 13 to 28 percent in the other eight included trials. Limitations of the network meta-analysis include (1) the lack of sensitivity analyses removing the studies with greater focus on secondary prevention, (2) limited ability to adjust for population characteristics (because some included studies were older and did not report CHADS_2_ scores, and they were estimated from baseline characteristics), and (3) heterogeneity of doses in intervention and control groups.

The primary efficacy outcome was the combination of stroke (of any type) and systemic embolism. All-cause mortality was the secondary efficacy outcome. The authors provided both unadjusted results and results adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup). The analysis found that all treatments (aspirin, vitamin K antagonists [VKAs], all four NOACs, and the Watchman device) reduced the risk of the primary and secondary efficacy outcomes in unadjusted analyses (Appendix E Table 3). Effect sizes for VKAs and aspirin compared with placebo/control were nearly identical to those from our pairwise meta-analyses for warfarin and aspirin. For the four NOACs (apixaban, dabigatran, edoxaban, and rivaroxaban), the authors reported statistically significant associations with reduction in the primary outcome compared with placebo/control (unadjusted ORs from 0.27 to 0.38; adjusted ORs from 0.32 to 0.44) (Appendix E Table 3), but no statistically significant differences for the four NOACs in comparison to one another. In adjusted analyses, the NOACs were not statistically different from VKAs for either efficacy outcome. VKAs and the NOACs showed greater reduction in risk of the primary outcome compared with aspirin.

### KQ5 What Are the Harms of Anticoagulation or Antiplatelet Therapy in Asymptomatic, Screen-Detected Older Adults With AF?

All six RCTs described in KQ 4 for benefits of warfarin or aspirin also reported harms.^86–92^ As for KQ 4, we found no trials or systematic reviews that focused on asymptomatic, screen-detected participants. Table 4 and Table 5 summarize the characteristics of the included studies and Appendix E Tables 1 and 2 summarize the results. We also included seven systematic reviews (Appendix E Table 3): four were traditional systematic reviews with meta-analyses,^44,^ ^93,^ ^94,^ ^100^ two were individual patient data meta-analyses,^95,^ ^97^ and one was a network meta-analysis.^98^

#### Warfarin: Results of Meta-Analyses

##### Major Bleeding

Across trials, 31 major bleeding events occurred, 20 in warfarin groups and 11 in control groups. Warfarin treatment over an average of 1.5 years was associated with an increased risk of major bleeding compared with controls, but the CI was wide, and the difference between groups was not statistically significant (pooled RR, 1.8 [95% CI, 0.85 to 3.7]; I2=0%; 5 trials; 2,415 participants) (Figure 4).

##### Major Extracranial Bleeding

Across trials, 23 events occurred, 14 in warfarin groups and 9 in control groups. Warfarin treatment over an average of 1.6 years was associated with an increased risk of major extracranial bleeding compared with controls, but the CI was wide, and the difference between groups was not statistically significant (pooled RR, 1.6 [95% CI, 0.67 to 3.6]; I2=0%; 4 trials; 1,744 participants) (Figure 4).

##### Intracranial Hemorrhage

Eight intracranial hemorrhages occurred, six in warfarin groups and two in control groups. Warfarin treatment over an average of 1.5 years was associated with an increased risk of intracranial hemorrhage compared with controls, but the CI was wide, and the difference between groups was not statistically significant (pooled RR, 1.9 [95% CI, 0.56 to 6.7]; I2=0%; 5 trials; 2,415 participants) (Figure 4).

##### Minor Bleeding

A total of 222 minor bleeding events occurred, 136 in warfarin groups and 86 in control groups. Warfarin treatment over an average of 1.6 years was associated with an increase in minor bleeding compared with controls (pooled RR, 1.6 [95% CI, 1.2 to 2.0]; I^2^=0%; 4 trials; 1,744 participants) (Appendix F Figure 2).

#### Aspirin: Results of Meta-Analyses

##### Major Bleeding

In the included trials, 34 major bleeding events occurred, 18 in aspirin groups and 16 in control groups. Aspirin treatment over an average of 1.5 years was associated with an increased risk of major bleeding compared with controls, but the CI was wide, and the difference between groups was not statistically significant (pooled RR, 1.5 [95% CI, 0.44 to 5.0]; I^2^=45%; 3 trials; 2,663 participants) (Figure 5).

##### Major Extracranial Bleeding

In the included trials, 24 major extracranial bleeding events occurred, 12 in aspirin groups and 12 in control groups. Aspirin treatment over an average of 1.5 years was associated with an increased risk of major extracranial bleeding compared with controls, but the CI was wide, and the difference between groups was not statistically significant (pooled RR, 1.4 [95% CI, 0.32 to 5.8]; I^2^=31.5%; 3 trials; 2,663 participants) (Figure 5).

##### Intracranial Hemorrhage

Ten intracranial hemorrhages occurred, six in aspirin groups and four in control groups (Appendix F Figure 9). AFASAK I reported no events in either group. SPAF I reported two events in both groups (RR, 1.0 [95% CI, 0.15 to 7.3]), and JAST reported four events in the aspirin group and two events in the control group (RR, 2.1 [95% CI, 0.38 to 11.4]).

#### Previously Published Systematic Reviews and Meta-Analyses

Results of previously published systematic reviews^44,^ ^93–95,^ ^97,^ ^98,^ ^100^ were generally consistent with our findings and are summarized in Appendix E Table 3. Here we highlight the findings from those reviews that provide additional information (beyond what we have described already in this KQ). Overall, the included systematic reviews provide some additional details about subgroups (from individual patient data meta-analyses) and some information about head-to-head comparisons, including comparisons with NOACs.

##### Warfarin vs. Placebo or Control

One systematic review from the Cochrane collaboration evaluated warfarin for primary prevention.^93^ It included the same five RCTs in our review but obtained unpublished data excluding the 3 to 8 percent of participants with prior stroke or TIA. The findings were very similar to those of our meta-analyses, although they reported ORs (e.g., for intracranial hemorrhage, they reported OR 2.38 [95% CI, 0.54 to 10.5] vs. our pooled result of RR 1.94 [95% CI, 0.56 to 6.68]) (Appendix E Table 3).

##### Aspirin vs. Placebo or Control

One systematic review from the Cochrane collaboration evaluated aspirin for primary prevention.^94^ It included two of the three RCTs (AFASAK I and SPAF I) that were in our main analyses and included LASAF, which we excluded because of poor quality but used in sensitivity analyses. The review authors obtained unpublished data excluding participants with prior stroke or TIA. The findings were very similar to those of our meta-analyses, showing that aspirin treatment was associated with an increased risk of bleeding compared with controls, but the CIs were wide and the difference between groups was not statistically significant (e.g., for major extracranial bleeding, they reported OR 1.14 [95% CI, 0.44 to 2.98] vs. our pooled result of RR, 1.4 [95% CI, 0.32 to 5.8]) (Appendix E Table 3).

##### Subgroups

Two of the individual patient data meta-analyses described in KQ 4 provided information about whether the risk of harms varies for subgroups.^95,^ ^97^ Both used the Atrial Fibrillation Investigators database of clinical trials evaluating warfarin or aspirin. That database included all five warfarin trials described in this report (AFASAK I, CAFA, SPAF I, SPINAF, BAATAF) and two of the aspirin trials (AFASAK I and SPAF I). The aspirin analyses are all limited by not including the JAST study (which was published later).

One meta-analysis of individual patient data concluded that the small number of patients with intracranial bleeding does not allow for reliable conclusions about whether the risk varies for subgroups.^95^ They also reported that the six warfarin-treated patients who had intracranial bleeding had higher blood pressure than warfarin-treated patients who did not have intracranial bleeding (169/93 vs. 141/83 mm Hg, p=0.001 for systolic and p=0.016 for diastolic). The mean age for patients with intracranial bleeding events was higher than for those without bleeding, but the difference between groups was not statistically significantly different (73 vs. 69 years, p not significant and not reported).

The other individual patient data meta-analysis evaluated subgroups based on age for risk of serious hemorrhage (intracranial hemorrhages or major bleeding).^97^ The analyses used the same five RCTs evaluating warfarin that we included, but also included a secondary prevention trial (EAFT). They found that neither warfarin nor aspirin interacted significantly with patient age for serious hemorrhage (data not reported; shown in figures only).

##### Results of Previously Published Network Meta-Analysis

The one included network meta-analysis used 21 RCTs (96,017 participants) of treatment for nonvalvular AF and is described in KQ 4.^98^ The primary safety outcome was major bleeding (the combination of major extracranial bleeding and intracranial hemorrhage). The authors provided both unadjusted results and results adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup). Effect sizes for VKAs and aspirin compared with placebo/control were nearly identical to those from our pairwise meta-analyses for warfarin and aspirin. Aspirin was associated with an increased risk of major bleeding compared with placebo/control, but the CI was wide, and the difference between groups was not statistically significant (adjusted OR, 1.65 [95% CI, 0.77 to 3.51]). Similarly, for the four NOACs (apixaban, dabigatran, edoxaban, and rivaroxaban), the authors reported associations with an increased risk of bleeding, but the CIs were wide, and differences between groups were not statistically significant (adjusted ORs from 1.38 to 2.21) (Appendix E Table 3), and there were no statistically significant differences between any of the four NOACs. Compared with VKAs, three of the NOACs (apixaban, dabigatran, and edoxaban) were associated with a lower risk of bleeding (range of ORs [95% CIs] from 0.64 [95% CI, 0.46 to 0.90] to 0.85 [95% CI, 0.65 to 1.11]), but the difference was only statistically significant for edoxaban (OR, 0.64 [95% CI, 0.46 to 0.90]) (Appendix E Table 3). For rivaroxaban compared with VKAs, the odds of major bleeding was 1.03 (95% CI, 0.68 to 1.57).