# Chapter 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and key questions (KQs). Figure 1 shows the analytic framework and KQs that guided the review. Five KQs were developed for this review:

1. Does screening for atrial fibrillation with ECG improve health outcomes (i.e., reduce all-cause mortality or reduce morbidity or mortality from stroke) in asymptomatic older adults? 1.a. Does improvement in health outcomes vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?
2. Does systematic screening for atrial fibrillation with ECG identify older adults with previously undiagnosed atrial fibrillation more effectively than usual care?
3. What are the harms of screening for atrial fibrillation with ECG in older adults? 3.a. Do the harms of screening vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?
4. What are the benefits of anticoagulation or antiplatelet therapy on health outcomes in asymptomatic, screen-detected older adults with atrial fibrillation? 4.a. Do the benefits of anticoagulation or antiplatelet therapy vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?
5. What are the harms of anticoagulation or antiplatelet therapy in asymptomatic, screen-detected older adults with atrial fibrillation?
5a. Do the harms of anticoagulation or antiplatelet therapy vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?

our KQs, we looked for evidence related to three contextual questions that focused on the prevalence of previously unrecognized or undiagnosed AF among asymptomatic adults by age, the stroke risk in asymptomatic older adults with previously unrecognized or undiagnosed AF, and the recommendations on and frequency of use of rate or rhythm control treatments for AF in asymptomatic adults ages 65 years or older. These contextual questions were not a part of our systematic review. They are intended to provide additional background information. Literature addressing these questions is summarized in Appendix A.

Figure 1 Analytic Framework

Abbreviations: CHA_2_DS_2_-VASc=Congestive heart failure, Hypertension, Age≥75 years (doubled), Diabetes mellitus, prior Stroke or TIA or thromboembolism (doubled), Vascular disease, Age 65-74 years, Sex category; ECG=electrocardiography; KQ=key question.

Key Questions to Be Systematically Reviewed

1. Does screening for atrial fibrillation with ECG improve health outcomes (i.e., reduce all-cause mortality or reduce morbidity or mortality from stroke) in asymptomatic older adults?
  a. Does improvement in health outcomes vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?
2. Does systematic screening for atrial fibrillation with ECG identify older adults with previously undiagnosed atrial fibrillation more effectively than usual care?
3. What are the harms of screening for atrial fibrillation with ECG in older adults?
  a. Do the harms of screening vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?
4. What are the benefits of anticoagulation or antiplatelet therapy on health outcomes in asymptomatic, screen-detected older adults with atrial fibrillation?
  a. Do the benefits of anticoagulation or antiplatelet therapy vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?
5. What are the harms of anticoagulation or antiplatelet therapy in asymptomatic, screen-detected older adults with atrial fibrillation?
  a. Do the harms of anticoagulation or antiplatelet therapy vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?

Figure 1 depicts the key questions (KQs) within the context of the eligible populations, screenings/interventions, comparisons, outcomes, timing, and settings. On the left, the population of interest is specified as asymptomatic adults age 65 years or older. Moving from left to right, the figure illustrates the overarching question: Does screening for atrial fibrillation with ECG improve health outcomes (i.e., reduce all-cause mortality or reduce morbidity or mortality from stroke) in asymptomatic older adults (KQ1)? The figure depicts the pathway from screening with ECG to diagnosis of atrial fibrillation to illustrate the question: Does systematic screening for atrial fibrillation with ECG identify older adults with previously undiagnosed atrial fibrillation more effectively than usual care (KQ2)? Screening may result in harms (KQ3). The figure also illustrates the question: What are the benefits of anticoagulation or antiplatelet therapy on health outcomes in asymptomatic, screen-detected older adults with atrial fibrillation (KQ4)? Treatment may also result in harms (KQ5).

## Data Sources and Searches

We searched PubMed/MEDLINE and the Cochrane Library for English-language articles published through May 24, 2017. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. Complete search terms and limits are detailed in Appendix B1. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform. To supplement electronic searches, we reviewed reference lists of pertinent articles, studies suggested by reviewers, and comments received during public commenting periods. Since May 2017, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on June 6, 2018 and identified no additional eligible studies.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, settings, and study designs with input from the USPSTF (Appendix B2). We included English-language studies focused on adults ages 65 years or older conducted in countries categorized as “very high” on the Human Development Index. We excluded studies focused on children, adolescents, adults younger than age 65, and adults with a history of stroke or transient ischemic attack (TIA).

For KQs 1 (direct evidence that screening improves health outcomes), 2 (detection of undiagnosed AF), and 3 (harms of screening), we required studies to enroll unselected or explicitly asymptomatic older adults or those selected for increased risk of nonvalvular AF (e.g., those with obesity, smoking, alcohol use, or hypertension). Studies of mixed asymptomatic and symptomatic populations were eligible if the results were reported separately for asymptomatic adults or if less than 10 percent of the sample was symptomatic. We tracked whether any studies were excluded because of the 10 percent threshold so that we could conduct sensitivity analyses by adding studies in which 10 to 50 percent of the population was symptomatic; however, no such studies were identified. Studies consisting of mostly symptomatic adults, those with a known history of AF, and those with mitral valve disease or repair/replacement were not eligible. Eligible screening tests for KQs 1, 2, and 3 included systematic ECG screening (e.g., in-office, single-application 12-lead ECG, continuous ECG, intermittent use of handheld ECG) or systematic screening with both pulse palpation and ECG for all participants in a given study. We excluded studies whose interventions were limited to physical examination (including pulse palpation), blood pressure monitoring, pulse oximetry, and other technologies. Eligible comparisons included screened versus nonscreened groups, systematic screening versus opportunistic screening, and systematic screening versus usual care (which may include pulse palpation, automated blood pressure measurement, or cardiac auscultation during the course of a physical examination, or examination for another reason, with subsequent ECG if an irregular heart beat or pulse is noted). For KQ 1, RCTs and controlled clinical trials were eligible. For KQs 2 and 3, prospective cohort studies were also eligible.

For KQs on benefits (KQ 4) and harms (KQ 5) of treatment, we excluded studies of adults with known heart disease, heart failure, and/or previous stroke or TIA. Eligible studies compared medical treatment with aspirin or oral anticoagulants (warfarin, apixaban, dabigatran, edoxaban, or rivaroxaban) versus no treatment (with or without placebo). We excluded all nonpharmacologic treatments and forms of treatment or management of AF for reasons other than prevention of stroke (e.g., rate or rhythm control, cardioversion, ablation). RCTs and controlled clinical trials of older adults with AF were eligible. Systematic reviews of trials were also eligible if they were directly relevant (i.e., met our eligibility criteria, focused on primary prevention studies, included the relevant aspirin or oral anticoagulant trials, and had not been updated). Appendix D Table 7 details our assessment of the relevance of potentially eligible systematic reviews. For KQ 5, prospective cohort studies were also eligible.

Two investigators independently reviewed titles and abstracts; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. Two investigators independently reviewed the full text to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second team member reviewed all data extractions for completeness and accuracy.

We assessed the quality of studies as good, fair, or poor, using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B3). Two independent investigators assigned quality ratings for each study. Disagreements were resolved by discussion. We included only studies with good or fair quality.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular and narrative format. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies following established guidance.^69^ We qualitatively assessed the populations, tests, treatments, comparators, outcomes, and study designs, looking for similarities and differences.

For KQ 2, fewer than three studies were available for each comparison, and absolute risk differences and odds ratios were calculated for detection of unknown AF. For KQs 4 and 5, when at least three similar studies were available, quantitative synthesis was conducted with random-effects models using the inverse-variance weighted method (DerSimonian and Laird) to estimate pooled effects.^70^ We calculated relative risks and 95 percent CIs for all-cause mortality, cardiovascular-related mortality, all ischemic stroke, moderately to severely disabling stroke, TIA, major bleeding, major extracranial bleeding, intracerebral hemorrhage, minor bleeding, and a composite outcome of all ischemic stroke or intracerebral hemorrhage. Results for the composite outcome, which includes a benefit and a harm, are provided in KQ 4. Statistical significance was assumed when 95 percent CIs of pooled results did not cross the null. All testing was two-sided. For all quantitative syntheses, the I^2^ statistic was calculated to assess statistical heterogeneity in effects between studies.^71,^ ^72^ An I^2^ from 0 to 40 percent might not be important; 30 to 60 percent may represent moderate heterogeneity; 50 to 90 percent may represent substantial heterogeneity; and 75 percent or greater represents considerable heterogeneity.^73^ We conducted sensitivity analyses by adding one trial rated as poor quality that evaluated aspirin.^74^ The results of the sensitivity analyses are provided in appendices of this report; estimates of effect were similar to main analyses, and statistical significance (or lack thereof) did not change. Quantitative analyses were conducted using Comprehensive Meta-Analysis version 3.3 (Biostat, Inc.) and Stata version 14 (StataCorp).

We assessed the overall strength of the body of evidence for each KQ as high, moderate, low, or insufficient using methods developed for the USPSTF (and the EPC program), based on the overall quality of studies, consistency of results between studies, precision of findings, and risk of reporting bias.^75^ We also assessed the applicability of the findings to U.S. primary care populations and settings.

## Expert Review and Public Comment

A draft report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments, as appropriate. It was also posted for public comment and revised based on public comments. Based on the comments received we revised the report to include the recently published REHEARSE-AF study. REHEARSE-AF was published after the original search cutoff date but was captured by surveillance during the public comment period. Minor edits were also made to the report to be more consistent and clear when describing “opportunistic” screening. At the request of reviewers, the list of recommendations from other groups was updated to include additional groups.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and members of the USPSTF participated in developing the scope of work and reviewed draft reports, but the authors are solely responsible for the content.