# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to inform a recommendation on the topic of screening asymptomatic adults for atrial fibrillation (AF) using an electrocardiogram (ECG). The USPSTF has not previously made a recommendation on AF. This report systematically evaluates the current evidence on screening for and treatment of AF for populations and settings relevant to primary care in the United States.

## Condition Definition

AF is a supraventricular tachyarrhythmia characterized by uncoordinated electrical activity and resulting inefficient atrial contraction.^1^ On an ECG, AF has the following features: (1) R-R intervals (intervals from the onset of one R wave to the onset of the next one, one complete cardiac cycle) are “irregularly irregular” (i.e., they follow no repetitive pattern) and (2) there are no distinct repeating P waves (the waves on an ECG associated with atrial depolarization), although atrial electrical activity (fibrillatory f waves) may be seen in some leads.^2^ Clinically helpful labels include paroxysmal, persistent, permanent, and nonvalvular (Table 1).

Table 1 Classification of Atrial Fibrillation

Type of AF | Definition
Paroxysmal | AF that terminates spontaneously or with intervention within 7 days of onset; episodes may recur with variable frequency.
Persistent | Continuous AF for more than 7 days.
Long-standing persistent | Continuous AF for more than 12 months.
Permanent | AF when the patient and clinician make a joint decision to stop further attempts to restore and/or maintain sinus rhythm; does not reflect a pathophysiological attribute of AF.
Nonvalvular | AF in the absence of rheumatic mitral valve disease, mitral valve repair, or valve replacement.

Source: Adapted from 2014 American Heart Association/American College of Cardiology/Heart Rhythm Society guidelines.^1^

Abbreviation: AF=atrial fibrillation.

## Etiology and Natural History

A number of disease pathways and mechanisms can cause structural or electrophysiological abnormalities that alter the atrial tissue, resulting in AF. Underlying heart disease (e.g., ischemic heart disease, valvular heart disease, cardiomyopathies, heart failure) can lead to inflammation, fibrosis, and hypertrophy in the atrial architecture, leading to increased left atrial pressure with subsequent atrial dilation and changes in wall stress.^3,^ ^4^ Multiple electrophysiological mechanisms may contribute to the initiation and perpetuation of AF in an individual with an anatomical vulnerability; the natural history of the condition generally involves a gradual worsening over time.^5,^ ^6^ Factors such as suboptimal ventricular rate control, loss of atrial contraction, variability in ventricular filling, and sympathetic activation can lead to the adverse hemodynamic effects of AF, resulting in reduced cardiac output with potential for fatigue, palpitations, dyspnea, hypotension, syncope, or heart failure.^7–9^ However, some patients have silent AF, with no obvious symptoms relevant to the disease.^10^ Persons may attribute mild symptoms (e.g., fatigue) to other causes.

Before widespread anticoagulant use, AF was associated with a fivefold increase in the risk of stroke, after adjustment for other factors.^11^ AF reduces cardiac blood flow; along with changes in blood composition involving platelets, other coagulatory proteins, and inflammatory cytokines, a reduction in cardiac blood flow predisposes patients to thrombus formation (particularly in the left atrial appendage) and confers an increased risk of stroke and systemic thromboembolism.^12^ Although earlier studies suggest similar risks of stroke for persons with paroxysmal AF compared with those who have persistent or permanent AF,^13–16^ more recent studies show lower risk for those with paroxysmal AF.^17–23^ For example, a recent randomized, controlled trial (RCT) comparing edoxaban with warfarin (21,105 participants in 46 countries) found lower mean annual rates of stroke or systemic embolism (the primary efficacy outcome) for those with paroxysmal AF than those with persistent AF or permanent AF over a median of 2.8 years of followup (1.49% vs. 1.83% vs. 1.95%, p<0.05 for both comparisons with paroxysmal AF).^17,^ ^18^

Increasing age is an independent predictor of stroke in persons with AF, associated with an increased risk of about 1.5 percent per decade; the annual stroke incidence increases from 1.3 percent in those ages 50 to 59 years to 5.1 percent in those ages 80 to 89 years.^24^ Strokes due to AF are associated with a poor prognosis as measured by both 28-day and 3-month mortality, disability, and discharge to institution rather than home.^25–27^ Approximately 30 percent of patients with AF who have a stroke die within 1 year of the stroke, and up to 30 percent of survivors are permanently disabled.^28^

## Risk Factors

Risk factors for AF include diabetes, previous cardiothoracic surgery, smoking, prior stroke, age, underlying heart disease, hypertension, sleep apnea, obesity, alcohol/drug use, and hyperthyroidism.^29^ Models for predicting the risk of future AF have been developed from several large longitudinal study cohorts,^30^ including the Atherosclerosis Risk in Communities Study^31^ and the Framingham Heart Study, and externally validated in additional population-based cohorts.^30^ An externally validated risk prediction model derived from the Atherosclerosis Risk in Communities Study, Cardiovascular Health Study, and Framingham Heart Study cohorts includes age, race, height, weight, systolic and diastolic blood pressure, current smoking, use of antihypertensive medication, diabetes, and history of myocardial infarction and heart failure as predictors of future AF risk.^31,^ ^32^

## Prevalence and Burden

AF is the most common arrhythmia. Prevalence increases with age, from less than 0.2 percent for those younger than age 55 years to about 10 percent for those age 85 years or older, and is higher for men than women (Appendix A Table 1).^33^ In 2013, the estimated prevalence was 8.3 percent for U.S. Medicare beneficiaries.^34^ About 25 percent of AF is paroxysmal;^35^ however, assessing the prevalence of AF—particularly paroxysmal AF—is challenging because episodes may be brief and undetected.^36^

In 2011, AF was mentioned in the death certificates of 116,247 persons in the United States and was listed as the underlying cause of death in 17,729 cases. The National Center for Health Statistics reported 479,000 hospitalizations in 2010 with AF as the primary diagnosis. According to Medicare and MarketScan databases from 2004–2006, persons with AF are approximately twice as likely to be hospitalized as age- and sex- matched control individuals (37.5 vs. 17.5%). This analysis also revealed that care for AF adds approximately $8,700 per year to the cost of a patient’s health care and accounts for $26 billion in U.S. health care expenditures annually.^37^

## Rationale for Screening and Screening Strategies

Because patients may not notice any symptoms of AF before a serious first event, such as stroke, identifying asymptomatic persons for treatment may reduce risk for future morbidity and mortality. Of patients who have a stroke because of AF, it is estimated that 20 percent or more are diagnosed with AF at the time of the stroke or shortly thereafter.^38–40^ For subclinical AF, screening with ECG could identify patients with asymptomatic AF who might benefit from treatment to reduce the risk for thromboembolic events, reduce frequency or severity of future symptoms related to AF, and reduce overall mortality.

To characterize the potential yield of screening for AF with ECG or pulse palpation, a 2013 systematic review found an overall incidence of screen-detected, previously unknown AF of 1 percent (95% confidence interval [CI], 0.89% to 1.04%; 14 studies, 67,772 participants) and an incidence of 1.4 percent (95% CI, 1.2% to 1.6%; 8 studies, 18,189 participants) for those age 65 years or older.^41^ However, the review did not require studies to have control groups, so it may have overestimated the added yield beyond usual medical care.

Screening for AF could potentially use a variety of approaches, including 12-lead ECG, devices that record fewer than 12 leads (including handheld ECG), pulse oximetry, ambulatory pulse monitors, consumer-directed devices (e.g., smartphone applications), or pulse palpation. A 2015 systematic review evaluated the accuracy of methods for identifying an irregular pulse and found that pulse palpation had the lowest accuracy among various methods, largely because of its lower specificity.^42^ Health care professionals, including medical assistants, nurses, and physicians, often perform pulse measurement and/or palpation using automated or manual approaches during routine or acute care encounters. When an irregular pulse is detected during usual medical care, a diagnostic evaluation that includes a standard 12-lead ECG typically is performed and may result in AF case-finding. This approach assumes that the patient is in AF at the time of the 12-lead ECG and may not identify patients with paroxysmal AF. Further, some patients have tremors or other rate or rhythm disturbances that make interpretation of ECG challenging.^43^

## Treatment Approaches

Oral anticoagulant medications can prevent thromboembolic events in AF patients by reducing the formation of clots in the left atrium or atrial appendage.^44^ Oral anticoagulants to prevent stroke and reduce all-cause mortality in persons with AF include warfarin (a vitamin K antagonist) and the newer target-specific anticoagulants, direct thrombin and Factor Xa inhibitors.^1^ Dabigatran etexilate (Pradaxa) is the only currently available oral direct thrombin inhibitor in the United States. Oral Factor Xa inhibitors include apixaban (Eliquis), edoxaban (Savaysa), and rivaroxaban (Xarelto).^1^ Reviews of current global treatment practices for stroke prevention in AF, including those in the United States, reported underuse of anticoagulation and antiplatelet therapy in AF patients at every level of stroke risk.^45,^ ^46^ Aspirin, an antiplatelet agent, might be considered as a treatment option for persons with AF who have a low risk of stroke (i.e., those who do not warrant anticoagulation).

Randomized trials have shown anticoagulant therapies to be more effective than antiplatelet therapies in reducing stroke; however, their use is associated with an increased risk of bleeding.^47,^ ^48^ Individualized assessment of the balance of potential benefits (i.e., risk reduction in stroke or embolism) versus potential harms (i.e., risk increase in major bleeding) is recommended when choosing a therapeutic strategy. Validated risk prediction tools (Appendix A Tables 2 and 3) for stroke risk (e.g., the Congestive heart failure, Hypertension, Age ≥75 years [doubled], Diabetes mellitus, prior Stroke or TIA or thromboembolism [doubled], Vascular disease, Age 65-74 years, Sex category [CHA_2_DS_2_-VASc] score) and bleeding risk (e.g., HAS-BLED, HEMORR_2_HAGES^1^) have been developed to aid in this assessment, which is complicated because many risk factors for anticoagulation-related bleeding are also risk factors for stroke in patients with AF.

A U.S. Food and Drug Administration–approved device, the WATCHMAN™, offers a nonpharmacologic alternative to oral anticoagulation.^49^ In patients with nonvalvular AF at increased risk for embolism (based on the Congestive heart failure, Hypertension, Age≥75 years, Diabetes mellitus, prior Stroke or TIA or thromboembolism [CHADS_2_] or CHA_2_DS_2_-VASc scores) and eligible for treatment with warfarin, this catheter-delivered heart implant is designed to reduce the risk of thromboembolism by closing off the left atrial appendage.

Therapies for rate or rhythm control are also routinely used in clinical practice, primarily to prevent and treat hemodynamic consequences of AF. Rate control therapies include beta blockers and nondihydropyridine calcium channel blockers. When pharmacologic therapy is inadequate to control symptoms, atrioventricular (AV) nodal ablation with ventricular pacing is an option. Rhythm control strategies (i.e., direct current or pharmacologic cardioversion or radiofrequency catheter ablation) may be appropriate for select persons (e.g., persons who have persistent symptoms, are not able to achieve rate control, or are young^1^); however, RCTs have not demonstrated a mortality benefit for rhythm control over rate control strategies.^50,^ ^51^ Neither rate nor rhythm control of AF is intended to prevent strokes.

## Recommendations and Clinical Practice in the United States

In recent years, several U.S. and international professional organizations have issued recommendations for managing AF and preventing stroke (Appendix A Table 4). Some organizations recommended screening for AF in selected patients. The 2014 guidelines from the American Heart Association and the American Stroke Association recommended conducting active screening with pulse palpation (followed by ECG as appropriate) in older adults.^52,^ ^53^ Similarly, guidelines from the European Society of Cardiology (ESC), the Royal College of Physicians of Edinburgh (one of the founding groups of the Scottish Intercollegiate Guidelines Network), European Primary Care Cardiovascular Society, and others recommended opportunistic screening with pulse taking for persons age 65 years or older.^54–57^ The guidelines recommending screening for AF usually state that screening should be performed with pulse palpation and the diagnosis confirmed by ECG.^53–59^ No recommendations are given for screening frequency except for the EPCCS, which recommends at least yearly pulse palpation.^59^ The ESC, European Heart Rhythm Association, and AF-SCREEN recommended that pulse taking or ECG (rhythm strip or single-lead) could be used for screening. Guidelines from the ESC, EHRA, and AF-SCREEN recommend that systematic ECG screening be considered in patients age 75 years or older or for those at high stroke risk.^59,^ ^60^

Professional organizations have consistently recommended the use of risk prediction tools to guide the appropriate use of therapy in patients with AF. Recent guidelines recommend using the CHA_2_DS_2_-VASc score. In general, guidelines recommend no antithrombotic therapy or antiplatelet therapy for those at lowest risk of stroke (CHA_2_DS_2_-VASc score=0) and recommend anticoagulant therapy for those at high risk (CHA_2_DS_2_-VASc score≥2). Recent guidelines are mixed in their recommendations for those with a CHA_2_DS_2_-VASc score of 1, with some recommending anticoagulant therapy^61–63^ and others recommending treatment based on risk and patient preference.^1,^ ^54,^ ^60,^ ^64^ Older guideline recommendations based on the CHADS_2_ score differ somewhat in their recommendations.^65–68^