# Appendix F Additional Meta-Analysis Results

Appendix F Figure 1 Warfarin vs. Placebo/Control, TIA

Q =1.25, df=3, p= 0.74, I-sq= 0.00

Appendix F Figure 1 displays a forest plot reporting the risk ratio (RR) of transient ischemic attack (TIA) with warfarin vs. placebo/control. 19 TIAs occurred, 7 in warfarin groups and 12 in control groups. Warfarin was associated with a lower risk of events, but the difference between warfarin and controls was not statistically significant (pooled RR, 0.66 [95% CI, 0.26 to 1.68]; I2=0%; 4 studies).

Appendix F Figure 2 Warfarin vs. Placebo/Control, Minor Bleeding

Q =1.38, df=3, p= 0.71, I-sq= 0.00

AFASAK did not specify bleeding severity and was therefore not included in this analysis. It reported bleeding events leading to withdrawal from study, 21 for warfarin and 0 for placebo.

BAATAF, minor bleeding was defined as bleeding that did not include intracranial bleeding, fatal bleeding, or bleeding that required a blood transfusion (four or more units of blood within 48 hours).

SPAF I, minor bleeding defined as bleeding that did not involve the central nervous system, management requiring hospitalization with transfusion and/or surgery, or permanent residual impairment.

CAFA, minor bleeding defined as non-life-threatening bleeding.

SPINAF, minor bleeding defined as bleeding that did not require a blood transfusion, an emergency procedure, removal of a hematoma, or ICU admission.

Appendix F Figure 2 displays a forest plot reporting the risk ratio (RR) of minor bleeding with warfarin compared to placebo/control. 222 minor bleeding events occurred, 136 in warfarin groups and 86 in control groups. Warfarin treatment, over an average of 1.6 years, was associated with an increase in minor bleeding compared with controls (pooled RR, 1.6 [95% CI, 1.2 to 2.0]; I2=0%; 4 trials; 1,744 participants).

Appendix F Figure 3 Aspirin vs. Placebo/Control, All-Cause Mortality Sensitivity Analyses

Q =1.62, df=3, p= 0.65, I-sq= 0.00; AFASAK, includes data from a previously published meta-analysis that obtained data from the original study authors.

Appendix F Figure 3 displays a forest plot reporting the risk ratio (RR) of all-cause mortality with aspirin compared to placebo/control. 178 all-cause mortalities occurred, 82 in aspirin groups and 96 in control groups. Aspirin treatment was associated with a lower risk of mortality than controls, but the difference between aspirin and controls was not statistically significant (pooled RR, 0.80 [95% CI, 0.60 to 1.06]; I2=0%; 4 studies).

Appendix F Figure 4 Aspirin vs. Placebo/Control, Cardiovascular-Related Mortality Sensitivity Analyses

Q =0.70, df=3, p= 0.87, I-sq= 0.00

Appendix F Figure 4 displays a forest plot reporting the risk ratio (RR) of cardiovascular-related mortality with aspirin compared to placebo/control. 96 cardiovascular-related mortalities occurred, 45 in aspirin groups and 51 in control groups. Aspirin treatment was associated with a reduction in cardiovascular-related mortality, but the difference between aspirin and controls was not statistically significant (pooled RR, 0.81 [95% CI, 0.55 to 1.20]; I2=0%; 4 studies).

Appendix F Figure 5 Aspirin vs. Placebo/Control, All Ischemic Stroke

Q =2.42, df=3, p= 0.49, I-sq= 0.00

Appendix F Figure 5 displays a forest plot reporting the risk ratio (RR) of all ischemic strokes with aspirin compared to placebo/control. 138 ischemic strokes occurred, 59 in aspirin groups and 79 in control groups. Aspirin treatment was associated with a reduction in events, but the difference between aspirin and controls was not statistically significant (pooled RR, 0.74 [95% CI, 0.53 to 1.03]; I2=0%; 4 studies).

Appendix F Figure 6 Aspirin vs. Placebo/Control, All Ischemic Stroke or Intracranial Hemorrhage Sensitivity Analyses

Q =3.06, df=3, p= 0.38, I-sq= 1.81

Appendix F Figure 6 displays a forest plot reporting the risk ratio (RR) of all ischemic strokes or intracranial hemorrhages with aspirin compared to placebo/control. 142 ischemic strokes or intracranial hemorrhages occurred, 62 in aspirin groups and 80 in control groups. Aspirin treatment was associated with a reduction in events, but the difference between aspirin and controls was not statistically significant (pooled RR, 0.79 [95% CI, 0.57 to 1.10]; I2=1.81%; 4 studies).

Appendix F Figure 7 Aspirin vs. Placebo/Control, Moderately to Severely Disabling Stroke

Q =3.06 df=3, p= 0.87, I-sq= 0.00

AFASAK reported disabling stroke which was defined as a stroke leaving definite functional disability a month after onset. SPAF I reported moderately to severely disabling stroke which was defined as a stroke requiring assistance to perform basic activities of daily living after onset.

Appendix F Figure 7 displays a forest plot reporting the risk ratio (RR) of moderately to severely disabling stroke with aspirin compared to placebo/control. 2 of the 3 included trials reported on disabling strokes (AFASAK I and SPAF I) reported nonstatistically significant reductions in events for participants treated with aspirin (RR, 0.57 [95% CI, 0.17 to 1.9] in AFASAK I over an average followup of 1.2 years, with 672 participants; RR 0.64 [95% CI, 0.29 to 1.4] in SPAF I over an average followup of 1.3 years, with 1120 participants).

Appendix F Figure 8 Aspirin vs. Placebo/Control, TIA

Q =4.25 df=2, p= 0.12, I-sq= 52.98

Appendix F Figure 8 displays a forest plot reporting the risk ratio of TIA with aspirin compared to placebo/control. 34 TIAs occurred, 16 in aspirin groups and 18 in control groups (pooled RR, 1.01 [95% CI, 0.32 to 3.24]; I2 = 52.98%; 3 studies).

Appendix F Figure 9 Aspirin vs. Placebo/Control, Intracranial Bleeding

Q =0.29 df=1, p= 0.59, I-sq= 0.00

For AFASAK: zero for aspirin and zero for placebo. For SPAF I: aspirin, one fatal intracerebral hemorrhage and one fatal subdural hematoma; placebo, two subdural hematomas with full recovery.

Appendix F Figure 9 displays a forest plot reporting the risk ratio (RR) of intracranial bleeding with aspirin compared to placebo/control. 10 intracranial hemorrhages occurred, 6 in aspirin groups and 4 in control groups. AFASAK I reported no events in either group. SPAF I reported 2 events in both groups (RR, 1.0 [95% CI, 0.15 to 7.28]), and JAST reported 4 events in the aspirin group and 2 events in the control group (RR, 2.1 [95% CI, 0.38 to 11.4]).

1 Go AS, Hylek EM, Phillips KA, . Prevalence of diagnosed atrial fibrillation in adults: national implications for rhythm management and stroke prevention: the AnTicoagulation and Risk Factors in Atrial Fibrillation (ATRIA) Study. JAMA. 2001 May 9;285(18):2370–5. PMID: 11343485.11343485
2 Gage BF, Waterman AD, Shannon W, . Validation of clinical classification schemes for predicting stroke: results from the National Registry of Atrial Fibrillation. JAMA. 2001 Jun 13;285(22):2864–70. PMID: 11401607.11401607
3 Lip GY, Nieuwlaat R, Pisters R, . Refining clinical risk stratification for predicting stroke and thromboembolism in atrial fibrillation using a novel risk factor-based approach: the euro heart survey on atrial fibrillation. Chest. 2010 Feb;137(2):263–72. doi: 10.1378/chest.09-1584. PMID: 19762550.19762550
4 Piccini JP, Stevens SR, Chang Y, . Renal dysfunction as a predictor of stroke and systemic embolism in patients with nonvalvular atrial fibrillation: validation of the R(2)CHADS(2) index in the ROCKET AF (Rivaroxaban Once-daily, oral, direct factor Xa inhibition Compared with vitamin K antagonism for prevention of stroke and Embolism Trial in Atrial Fibrillation) and ATRIA (AnTicoagulation and Risk factors In Atrial fibrillation) study cohorts. Circulation. 2013 Jan 15;127(2):224–32. doi: 10.1161/circulationaha.112.107128. PMID: 23212720.23212720
5 Hippisley-Cox J, Coupland C, Brindle P. Derivation and validation of QStroke score for predicting risk of ischaemic stroke in primary care and comparison with other risk scores: a prospective open cohort study. BMJ. 2013;346:f2573. doi: 10.1136/bmj.f2573. PMID: 23641033.23641033
6 Singer DE, Chang Y, Borowsky LH, . A new risk scheme to predict ischemic stroke and other thromboembolism in atrial fibrillation: the ATRIA study stroke risk score. J Am Heart Assoc. 2013 Jun 21;2(3):e000250. doi: 10.1161/JAHA.113.000250. PMID: 23782923.23782923
7 Pisters R, Lane DA, Nieuwlaat R, . A novel user-friendly score (HAS-BLED) to assess 1-year risk of major bleeding in patients with atrial fibrillation: the Euro Heart Survey. Chest. 2010 Nov;138(5):1093–100. doi: 10.1378/chest.10-0134. PMID: 20299623.20299623
8 Gage BF, Yan Y, Milligan PE, . Clinical classification schemes for predicting hemorrhage: results from the National Registry of Atrial Fibrillation (NRAF). Am Heart J. 2006 Mar;151(3):713–9. doi: 10.1016/j.ahj.2005.04.017. PMID: 16504638.16504638
9 Fang MC, Go AS, Chang Y, . A new risk scheme to predict warfarin-associated hemorrhage: The ATRIA (Anticoagulation and Risk Factors in Atrial Fibrillation) Study. J Am Coll Cardiol. 2011 Jul 19;58(4):395–401. doi: 10.1016/j.jacc.2011.03.031. PMID: 21757117.21757117
10 Lopes RD, Crowley MJ, Shah BR, . Stroke Prevention in Atrial Fibrillation Agency for Healthcare Research and Quality. Rockville (MD): 2013. PMID: 2404984324049843. http://www.ncbi.nlm.nih.gov/pubmed/24049843
11 Cairns JA, Connolly S, McMurtry S, . Canadian Cardiovascular Society atrial fibrillation guidelines 2010: prevention of stroke and systemic thromboembolism in atrial fibrillation and flutter. Can J Cardiol. 2011 Jan–Feb;27(1):74–90. doi: 10.1016/j.cjca.2010.11.007. PMID: 21329865.21329865
12 Lip GY, Andreotti F, Fauchier L, . Bleeding risk assessment and management in atrial fibrillation patients: a position document from the European Heart Rhythm Association, endorsed by the European Society of Cardiology Working Group on Thrombosis. Europace. 2011 May;13(5):723–46. doi: 10.1093/europace/eur126. PMID: 21515596.21515596
13 National Institute for Health and Care Excellence. Atrial Fibrillation: The Management of Atrial Fibrillation National Institute for Health and Care Excellence (UK). London: 2014.
14 Freedman B, Camm J, Calkins H, . Screening for Atrial Fibrillation: A Report of the AF-SCREEN International Collaboration. Circulation. 2017 May 09;135(19):1851–67. doi: 10.1161/circulationaha.116.026693. PMID: 28483832.28483832
15 Murphy A, Banerjee A, Breithardt G, . The World Heart Federation Roadmap for Nonvalvular Atrial Fibrillation. Glob Heart. 2017 Dec;12(4):273–84. doi: 10.1016/j.gheart.2017.01.015. PMID: 28336387.28336387
16 Kirchhof P, Breithardt G, Bax J, . A roadmap to improve the quality of atrial fibrillation management: proceedings from the fifth Atrial Fibrillation Network/European Heart Rhythm Association consensus conference. Europace. 2016 Jan;18(1):37–50. doi: 10.1093/europace/euv304. PMID: 26481149.26481149
17 Mairesse GH, Moran P, Van Gelder IC, . Screening for atrial fibrillation: a European Heart Rhythm Association (EHRA) consensus document endorsed by the Heart Rhythm Society (HRS), Asia Pacific Heart Rhythm Society (APHRS), and Sociedad Latinoamericana de Estimulacion Cardiaca y Electrofisiologia (SOLAECE). Europace. 2017 Oct 1;19(10):1589–623. doi: 10.1093/europace/eux177. PMID: 29048522.29048522
18 Kirchhof P, Benussi S, Kotecha D, . 2016 ESC Guidelines for the management of atrial fibrillation developed in collaboration with EACTS. Eur Heart J. 2016 Oct 7;37(38):2893–962. doi: 10.1093/eurheartj/ehw210. PMID: 27567408.27567408
19 Hobbs FR, Taylor CJ, Jan Geersing G, . European Primary Care Cardiovascular Society (EPCCS) consensus guidance on stroke prevention in atrial fibrillation (SPAF) in primary care. Eur J Prev Cardiol. 2016 Mar;23(5):460–73. doi: 10.1177/2047487315571890. PMID: 25701017.25701017
20 Huisman M, Rothman K, Paquette M, . The Changing Landscape for Stroke Prevention in AF: findings From the GLORIA-AF Registry Phase 2. J Am Coll Cardiol; 2017. p. 777–85.28209218
21 National Screening Committee. The UK NSC recommendation on Atrial Fibrillation screening in adults National Health Service (UK). London: 2014. https://legacyscreening.phe.org.uk/atrialfibrillation
22 January CT, Wann LS, Alpert JS, . 2014 AHA/ACC/HRS guideline for the management of patients with atrial fibrillation: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Heart Rhythm Society. J Am Coll Cardiol. 2014 Dec 2;64(21):e1–76. doi: 10.1016/j.jacc.2014.03.022. PMID: 24685669.24685669
23 Meschia JF, Bushnell C, Boden-Albala B, . Guidelines for the primary prevention of stroke: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2014 Dec;45(12):3754–832. doi: 10.1161/STR.0000000000000046. PMID: 25355838.25355838
24 Culebras A, Messe SR, Chaturvedi S, . Summary of evidence-based guideline update: prevention of stroke in nonvalvular atrial fibrillation: report of the Guideline Development Subcommittee of the American Academy of Neurology. Neurology. 2014 Feb 25;82(8):716–24.24566225
25 Verma A, Cairns JA, Mitchell LB, . 2014 focused update of the Canadian Cardiovascular Society Guidelines for the management of atrial fibrillation. Can J Cardiol. 2014;30(10):1114–30.25262857
26 Antithrombotic Agents for the Prevention of Stroke and Systemic Embolism in Patients With Atrial Fibrillation Canadian Agency for Drugs and Technologies in Health. Ottawa (ON): 2013.
27 Scottish Intercollegiate Guidelines Network (SIGN). SIGN 129: Antithrombotics: Indications and Management. Edinburgh: Healthcare Improvement Scotland; 2013.
28 You JJ, Singer DE, Howard PA, . Antithrombotic therapy for atrial fibrillation: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012;141(2 Suppl):e513S–75S.
29 Furie KL, Goldstein LB, Albers GW, . Oral antithrombotic agents for the prevention of stroke in nonvalvular atrial fibrillation: a science advisory for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2012;43(12):3442–53.22858728
30 Stott DJ, Dewar RI, Garratt CJ, . RCPE UK Consensus Conference on ‘Approaching the comprehensive management of atrial fibrillation: evolution or revolution?’. J R Coll Physicians Edinb. 2012;42(Suppl 18):3–4. doi: 10.4997/JRCPE.2012.S01. PMID: 22518389.22518389
31 Greenland P, Alpert JS, Beller GA, . 2010 ACCF/AHA guideline for assessment of cardiovascular risk in asymptomatic adults: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2010 Dec 14;56(25):e50–103. doi: 10.1016/j.jacc.2010.09.001. PMID: 21144964.21144964
32 Lindsay MP, Gubitz G, Bayley M, . Canadian Best Practice Recommendations for Stroke Care (Update 2010). On behalf of the Canadian Stroke Strategy Best Practices and Standards Writing Group Canadian Stroke Network. Ottawa (ON): 2010.
33 Chan N-y, Choy C-c. Screening for atrial fibrillation in 13 122 Hong Kong citizens with smartphone electrocardiogram. Heart. 2016 October 12, 2016doi: 10.1136/heartjnl-2016-309993.
34 Doliwa PS, Frykman V, Rosenqvist M. Short-term ECG for out of hospital detection of silent atrial fibrillation episodes. Scand Cardiovasc J. 2009 Jun;43(3):163–8. doi: 10.1080/14017430802593435. PMID: 19096977.19096977
35 Kaasenbrood F, Hollander M, Rutten FH, . Yield of screening for atrial fibrillation in primary care with a hand-held, single-lead electrocardiogram device during influenza vaccination. Europace. 2016 Oct;18(10):1514–20. doi: 10.1093/europace/euv426. PMID: 26851813.26851813
36 Morgan S, Mant D. Randomised trial of two approaches to screening for atrial fibrillation in UK general practice. Br J Gen Pract. 2002 May;52(478):373–4, 7–80. PMID: 12014534.12014534
37 Lowres N, Neubeck L, Salkeld G, . Feasibility and cost-effectiveness of stroke prevention through community screening for atrial fibrillation using iPhone ECG in pharmacies. The SEARCH-AF study. Thromb Haemost. 2014 Jun;111(6):1167–76. doi: 10.1160/th14-03-0231. PMID: 24687081.24687081
38 Claes N, Van Laethem C, Goethals M, . Prevalence of atrial fibrillation in adults participating in a large-scale voluntary screening programme in Belgium. Acta Cardiol. 2012 Jun;67(3):273–8. doi: 10.2143/ac.67.3.2160714. PMID: 22870733.22870733
39 Deif B, Lowres N, Freedman SB. Screening for atrial fibrillation above age 65 detects an asymptomatic subset at high risk of stroke. Int J Cardiol. 2013 Apr 15;164(3):371–2. doi: 10.1016/j.ijcard.2012.08.002. PMID: 22964080.22964080
40 Schnabel RB, Wilde S, Wild PS, . Atrial fibrillation: its prevalence and risk factor profile in the German general population. Dtsch Arztebl Int. 2012 Apr;109(16):293–9. doi: 10.3238/arztebl.2012.0293. PMID: 22577476.22577476
41 Meschia JF, Merrill P, Soliman EZ, . Racial disparities in awareness and treatment of atrial fibrillation: the REasons for Geographic and Racial Differences in Stroke (REGARDS) study. Stroke. 2010 Apr;41(4):581–7. doi: 10.1161/strokeaha.109.573907. PMID: 20190000.20190000
42 Clua-Espuny JL, Lechuga-Duran I, Bosch-Princep R, . Prevalence of undiagnosed atrial fibrillation and of that not being treated with anticoagulant drugs: the AFABE study. Rev Esp Cardiol (Engl Ed). 2013 Jul;66(7):545–52. doi: 10.1016/j.rec.2013.03.003. PMID: 24776203.24776203
43 Fitzmaurice DA, Hobbs FD, Jowett S, . Screening versus routine practice in detection of atrial fibrillation in patients aged 65 or over: cluster randomised controlled trial. BMJ. 2007 Aug 25;335(7616):383. doi: 10.1136/bmj.39280.660567.55. PMID: 17673732.17673732
44 Frewen J, Finucane C, Cronin H, . Factors that influence awareness and treatment of atrial fibrillation in older adults. QJM. 2013 May;106(5):415–24. doi: 10.1093/qjmed/hct060. PMID: 23504411.23504411
45 Furberg CD, Psaty BM, Manolio TA, . Prevalence of atrial fibrillation in elderly subjects (the Cardiovascular Health Study). Am J Cardiol. 1994 Aug 01;74(3):236–41. PMID: 8037127.8037127
46 Hill JD, Mottram EM, Killeen PD. Study of the prevalence of atrial fibrillation in general practice patients over 65 years of age. J R Coll Gen Pract. 1987 Apr;37(297):172–3. PMID: 3694577.3694577
47 Wheeldon NM, Tayler DI, Anagnostou E, . Screening for atrial fibrillation in primary care. Heart. 1998 Jan;79(1):50–5. PMID: 9505919.9505919
48 Svennberg E, Engdahl J, Al-Khalili F, . Mass screening for untreated atrial fibrillation: the STROKESTOP Study. Circulation. 2015 Jun 23;131(25):2176–84. doi: 10.1161/circulationaha.114.014343. PMID: 25910800.25910800
49 Engdahl J, Andersson L, Mirskaya M, . Stepwise screening of atrial fibrillation in a 75-year-old population: implications for stroke prevention. Circulation. 2013 Feb 26;127(8):930–7. doi: 10.1161/circulationaha.112.126656. PMID: 23343564.23343564
50 Turakhia MP, Ullal AJ, Hoang DD, . Feasibility of extended ambulatory electrocardiogram monitoring to identify silent atrial fibrillation in high-risk patients: the Screening Study for Undiagnosed Atrial Fibrillation (STUDY-AF). Clin Cardiol. 2015 May;38(5):285–92. doi: 10.1002/clc.22387. PMID: 25873476.25873476
51 Bury G, Swan D, Cullen W, . Screening for atrial fibrillation in general practice: a national, cross-sectional study of an innovative technology. Int J Cardiol. 2015 Jan 15;178:247–52. doi: 10.1016/j.ijcard.2014.10.037. PMID: 25464263.25464263
52 Martinez C, Katholing A, Freedman SB. Adverse prognosis of incidentally detected ambulatory atrial fibrillation. A cohort study. Thromb Haemost. 2014 Aug;112(2):276–86. doi: 10.1160/th4-04-0383. PMID: 24953051.24953051
53 Fitzmaurice DA, McCahon D, Baker J, . Is screening for AF worthwhile? Stroke risk in a screened population from the SAFE study. Fam Pract. 2014 Jun;31(3):298–302. doi: 10.1093/fampra/cmu011. PMID: 24728774.24728774
54 Boriani G, Laroche C, Diemberger I, . Asymptomatic atrial fibrillation: clinical correlates, management, and outcomes in the EORP-AF Pilot General Registry. Am J Med. 2015 May;128(5):509–18.e2. doi: 10.1016/j.amjmed.2014.11.026. PMID: 25534423.25534423
55 Potpara TS, Polovina MM, Marinkovic JM, . A comparison of clinical characteristics and long-term prognosis in asymptomatic and symptomatic patients with first-diagnosed atrial fibrillation: the Belgrade Atrial Fibrillation Study. Int J Cardiol. 2013 Oct 12;168(5):4744–9. doi: 10.1016/j.ijcard.2013.07.234. PMID: 23958417.23958417
56 Tsang TS, Barnes ME, Pellikka PA, . Silent atrial fibrillation in Olmsted County: a community-based study. Can J Cardiol. 2011;27(5):S122–S.
57 Siontis KC, Gersh BJ, Killian JM, . Typical, atypical, and asymptomatic presentations of new-onset atrial fibrillation in the community: Characteristics and prognostic implications. Heart Rhythm. 2016 Jul;13(7):1418–24. doi: 10.1016/j.hrthm.2016.03.003. PMID: 26961300.26961300
58 Packer DL, Bardy GH, Worley SJ, . Tachycardia-induced cardiomyopathy: a reversible form of left ventricular dysfunction. Am J Cardiol. 1986 Mar 01;57(8):563–70. PMID: 3953440.3953440
59 Nerheim P, Birger-Botkin S, Piracha L, . Heart failure and sudden death in patients with tachycardia-induced cardiomyopathy and recurrent tachycardia. Circulation. 2004 Jul 20;110(3):247–52. doi: 10.1161/01.CIR.0000135472.28234.CC. PMID: 15226218.15226218
60 Roy D, Talajic M, Nattel S, . Rhythm control versus rate control for atrial fibrillation and heart failure. N Engl J Med. 2008 Jun 19;358(25):2667–77. doi: 10.1056/NEJMoa0708789. PMID: 18565859.18565859
61 Olshansky B, Rosenfeld LE, Warner AL, . The Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study: approaches to control rate in atrial fibrillation. J Am Coll Cardiol. 2004 Apr 7;43(7):1201–8. doi: 10.1016/j.jacc.2003.11.032. PMID: 15063430.15063430
62 Hohnloser SH, Kuck KH, Lilienthal J. Rhythm or rate control in atrial fibrillation-Pharmacological Intervention in Atrial Fibrillation (PIAF): a randomised trial. Lancet. 2000 Nov 25;356(9244):1789–94. PMID: 11117910.11117910
63 January CT, Wann LS, Alpert JS, . 2014 AHA/ACC/HRS guideline for the management of patients with atrial fibrillation: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Heart Rhythm Society. J Am Coll Cardiol. 2014 Dec 02;64(21):e1–76. doi: 10.1016/j.jacc.2014.03.022. PMID: 24685669.24685669
64 Caldeira D, David C, Sampaio C. Rate versus rhythm control in atrial fibrillation and clinical outcomes: updated systematic review and meta-analysis of randomized controlled trials. Arch Cardiovasc Dis. 2012 Apr;105(4):226–38. doi: 10.1016/j.acvd.2011.11.005. PMID: 22633297.22633297
65 Wyse DG, Waldo AL, DiMarco JP, . A comparison of rate control and rhythm control in patients with atrial fibrillation. N Engl J Med. 2002 Dec 5;347(23):1825–33. doi: 10.1056/NEJMoa021328. PMID: 12466506.12466506
66 Shariff N, Desai RV, Patel K, . Rate-control versus Rhythm-control Strategies and Outcomes in Septuagenarians with Atrial Fibrillation. Am J Med; 2013. p. 887–93.24054956
67 Camm AJ, Lip GY, De Caterina R, . 2012 focused update of the ESC Guidelines for the management of atrial fibrillation: an update of the 2010 ESC Guidelines for the management of atrial fibrillation-developed with the special contribution of the European Heart Rhythm Association. Europace. 2012 Oct;14(10):1385–413. doi: 10.1093/europace/eus305. PMID: 22923145.22923145
68 National Clinical Guideline Centre. National Institute for Health and Clinical Excellence: Guidance. Atrial Fibrillation: The Management of Atrial Fibrillation. London: National Institute for Health and Care Excellence; 2014.
69 Van Gelder IC, Hagens VE, Bosker HA, . A comparison of rate control and rhythm control in patients with recurrent persistent atrial fibrillation. N Engl J Med. 2002 Dec 5;347(23):1834–40. doi: 10.1056/NEJMoa021375. PMID: 12466507.12466507
70 Van Gelder IC, Groenveld HF, Crijns HJ, . Lenient versus strict rate control in patients with atrial fibrillation. N Engl J Med. 2010 Apr 15;362(15):1363–73. doi: 10.1056/NEJMoa1001337. PMID: 20231232.20231232
71 Mead GE, Elder AT, Flapan AD, . Electrical cardioversion for atrial fibrillation and flutter. Cochrane Database Syst Rev. 2005(3):Cd002903. doi: 10.1002/14651858.CD002903.pub2. PMID: 16034878.16034878
72 Van Gelder IC, Crijns HJ, Van Gilst WH, . Prediction of uneventful cardioversion and maintenance of sinus rhythm from direct-current electrical cardioversion of chronic atrial fibrillation and flutter. Am J Cardiol. 1991 Jul 01;68(1):41–6. PMID: 2058558.2058558
73 Mancini GB, Goldberger AL. Cardioversion of atrial fibrillation: consideration of embolization, anticoagulation, prophylactic pacemaker, and long-term success. Am Heart J. 1982 Sep;104(3):617–21. PMID: 7113903.7113903
74 Lafuente-Lafuente C, Valembois L, Bergmann J-F, . Antiarrhythmics for maintaining sinus rhythm after cardioversion of atrial fibrillation. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015.
75 Tracy CM, Akhtar M, DiMarco JP, . American College of Cardiology/American Heart Association 2006 update of the clinical competence statement on invasive electrophysiologystudies,catheterablation,andcardioversion: a report of the American College of Cardiology/American Heart Association/American College of Physicians Task Force on Clinical Competence and Training developed in collaboration with the Heart Rhythm Society. J Am Coll Cardiol. 2006 Oct 03;48(7):1503–17. doi: 10.1016/j.jacc.2006.06.043. PMID: 17010821.17010821
76 Chen Huai S, Wen Jun M, Wu Sheng N, . Catheter ablation for paroxysmal and persistent atrial fibrillation. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2012.
77 Nyong J, Amit G, Adler AJ, . Efficacy and safety of ablation for people with non-paroxysmal atrial fibrillation. Cochrane Database Syst Rev. 2016 Nov 22;11:Cd012088. doi: 10.1002/14651858.CD012088.pub2. PMID: 27871122.27871122
78 Liu J, Sylwestrzak G, Barron J, . Evaluation of practice patterns in the treatment of atrial fibrillation among the commercially insured. Curr Med Res Opin. 2014 Sep;30(9):1707–13. doi: 10.1185/03007995.2014.922061. PMID: 24809834.24809834
79 Allen LaPointe NM, Governale L, Watkins J, . Outpatient use of anticoagulants, rate-controlling drugs, and antiarrhythmic drugs for atrial fibrillation. Am Heart J. 2007 Nov;154(5):893–8. doi: 10.1016/j.ahj.2007.06.035. PMID: 17967595.17967595
80 Kneeland PP, Fang MC. Trends in catheter ablation for atrial fibrillation in the United States. J Hosp Med. 2009 Sep;4(7):E1–5. doi: 10.1002/jhm.445. PMID: 19753578.19753578
81 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes Accessed May 17, 2017.
82 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20(3 Suppl):21–35. PMID: 11306229.11306229
83 Benito L, Coll-Vinent B, Gómez E, . EARLY: a pilot study on early diagnosis of atrial fibrillation in a primary healthcare centre. Europace. 2015;17(11):1688–93. doi: 10.1093/europace/euv146. PMID: CN-01257576.26071233
84 Connolly SJ, Laupacis A, Gent M, . Canadian Atrial Fibrillation Anticoagulation (CAFA) Study. J Am Coll Cardiol. 1991 Aug;18(2):349–55. PMID: 1856403.1856403
85 Ezekowitz MD, Bridgers SL, James KE, . Warfarin in the prevention of stroke associated with nonrheumatic atrial fibrillation. Veterans Affairs Stroke Prevention in Nonrheumatic Atrial Fibrillation Investigators. N Engl J Med. 1992 Nov 12;327(20):1406–12. doi: 10.1056/nejm199211123272002. PMID: 1406859.1406859
86 Mant J, Fitzmaurice DA, Hobbs FD, . Accuracy of diagnosing atrial fibrillation on electrocardiogram by primary care practitioners and interpretative diagnostic software: analysis of data from screening for atrial fibrillation in the elderly (SAFE) trial. BMJ. 2007 Aug 25;335(7616):380. doi: 10.1136/bmj.39227.551713.AE. PMID: 17604299.17604299
87 Hobbs FD, Fitzmaurice DA, Mant J, . A randomised controlled trial and cost-effectiveness study of systematic screening (targeted and total population screening) versus routine practice for the detection of atrial fibrillation in people aged 65 and over. The SAFE study. Health Technol Assess. 2005 Oct;9(40):iii–iv, ix–x, 1–74. PMID: 16202350.16202350
88 Swancutt D, Hobbs R, Fitzmaurice D, . A randomised controlled trial and cost effectiveness study of systematic screening (targeted and total population screening) versus routine practice for the detection of atrial fibrillation in the over 65s: (SAFE) [ISRCTN19633732]. BMC Cardiovasc Disord. 2004 Jul 29;4:12. doi: 10.1186/1471-2261-4-12. PMID: 15283871.15283871
89 Halcox JPJ, Wareham K, Cardew A, . Assessment of Remote Heart Rhythm Sampling Using the AliveCor Heart Monitor to Screen for Atrial Fibrillation: The REHEARSE-AF Study. Circulation. 2017 Nov 7;136(19):1784–94. doi: 10.1161/circulationaha.117.030583. PMID: 28851729.28851729
90 Petersen P, Boysen G, Godtfredsen J, . Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Lancet. 1989 Jan 28;1(8631):175–9. PMID: 2563096.2563096
91 Posada IS, Barriales V. Alternate-day dosing of aspirin in atrial fibrillation. LASAF Pilot Study Group. Am Heart J. 1999 Jul;138(1 Pt 1):137–43. PMID: 10385777.10385777
92 Sato H, Ishikawa K, Kitabatake A, . Low-dose aspirin for prevention of stroke in low-risk patients with atrial fibrillation: Japan Atrial Fibrillation Stroke Trial. Stroke. 2006 Feb;37(2):447–51. doi: 10.1161/01.STR.0000198839.61112.ee. PMID: 16385088.16385088
93 Stroke Prevention in Atrial Fibrillation Study Group Investigators. Preliminary report of the Stroke Prevention in Atrial Fibrillation Study. N Engl J Med. 1990 Mar 22;322(12):863–8. doi: 10.1056/nejm199003223221232. PMID: 2407959.2407959
94 Stroke Prevention in Atrial Fibrillation Study. Final results. Circulation. 1991 Aug;84(2):527–39. PMID: 1860198.1860198
95 Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators. The effect of low-dose warfarin on the risk of stroke in patients with nonrheumatic atrial fibrillation. N Engl J Med. 1990 Nov 29;323(22):1505–11. doi: 10.1056/nejm199011293232201. PMID: 2233931.2233931
96 Caro JJ, Flegel KM, Orejuela ME, . Anticoagulant prophylaxis against stroke in atrial fibrillation: effectiveness in actual practice. CMAJ. 1999 Sep 7;161(5):493–7. PMID: 10497604.10497604
97 Forslund T, Wettermark B, Wandell P, . Risks for stroke and bleeding with warfarin or aspirin treatment in patients with atrial fibrillation at different CHA(2)DS(2)VASc scores: experience from the Stockholm region. Eur J Clin Pharmacol. 2014 Dec;70(12):1477–85. doi: 10.1007/s00228-014-1739-1. PMID: 25219360.25219360
98 Humphries KH, Kerr CR, Connolly SJ, . New-onset atrial fibrillation: sex differences in presentation, treatment, and outcome. Circulation. 2001 May 15;103(19):2365–70. PMID: 11352885.11352885
99 Kodani E, Atarashi H, Inoue H, . Beneficial Effect of Non-Vitamin K Antagonist Oral Anticoagulants in Patients With Nonvalvular Atrial Fibrillation- Results of the J-RHYTHM Registry 2. Circ J. 2016;80(4):843–51. doi: 10.1253/circj.CJ-16-0066. PMID: 27001190.27001190
100 Aguilar Maria I, Hart R. Oral anticoagulants for preventing stroke in patients with non-valvular atrial fibrillation and no previous history of stroke or transient ischemic attacks. Cochrane Database of Systematic Reviews. 2005(3)doi: 10.1002/14651858.CD001927.pub2. PMID: CD001927.
101 Aguilar Maria I, Hart R. Antiplatelet therapy for preventing stroke in patients with non-valvular atrial fibrillation and no previous history of stroke or transient ischemic attacks. Cochrane Database of Systematic Reviews. 2005(4)doi: 10.1002/14651858.CD001925.pub2. PMID: CD001925.
102 Coleman CI, Sobieraj DM, Winkler S, . Effect of pharmacological therapies for stroke prevention on major gastrointestinal bleeding in patients with atrial fibrillation (Structured abstract). Int J Clin Pract. 2012;66(1):53–63. PMID: DARE-12012000802.22093613
103 Risk factors for stroke and efficacy of antithrombotic therapy in atrial fibrillation. Analysis of pooled data from five randomized controlled trials. Arch Intern Med. 1994 Jul 11;154(13):1449–57. PMID: 8018000.8018000
104 Tereshchenko LG, Henrikson CA, Cigarroa J, . Comparative Effectiveness of Interventions for Stroke Prevention in Atrial Fibrillation: A Network Meta-Analysis. J Am Heart Assoc. 2016 May;5(5)doi: 10.1161/jaha.116.003206. PMID: 27207998.27207998
105 Atrial Fibrillation Investigators. The efficacy of aspirin in patients with atrial fibrillation. Analysis of pooled data from 3 randomized trials. Arch Intern Med. 1997 Jun 9;157(11):1237–40. PMID: 9183235.9183235
106 van Walraven C, Hart RG, Connolly S, . Effect of age on stroke prevention therapy in patients with atrial fibrillation: the atrial fibrillation investigators. Stroke. 2009 Apr;40(4):1410–6. doi: 10.1161/strokeaha.108.526988. PMID: 19182090.19182090
107 Hart RG, Pearce LA, Aguilar MI. Meta-analysis: antithrombotic therapy to prevent stroke in patients who have nonvalvular atrial fibrillation. Ann Intern Med. 2007 Jun 19;146(12):857–67. PMID: 17577005.17577005
108 Aguilar M, Hart R. Antiplatelet therapy for preventing stroke in patients with non-valvular atrial fibrillation and no previous history of stroke or transient ischemic attacks. Cochrane Database Syst Rev. 2005 Oct 19(4):CD001925. doi: 10.1002/14651858.CD001925.pub2. PMID: 16235290.16235290
109 Assiri A, Al-Majzoub O, Kanaan AO, . Mixed treatment comparison meta-analysis of aspirin, warfarin, and new anticoagulants for stroke prevention in patients with nonvalvular atrial fibrillation (Provisional abstract). Clin Ther. 2013;35(7):967–84.e2. PMID: DARE-12013042121.23870607
110 Cameron C, Coyle D, Richter T, . Systematic review and network meta-analysis comparing antithrombotic agents for the prevention of stroke and major bleeding in patients with atrial fibrillation (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):e004301. PMID: DARE-12014036609.
111 Ezekowitz MD, Levine JA. Preventing stroke in patients with atrial fibrillation. JAMA. 1999 May 19;281(19):1830–5. PMID: 10340371.10340371
112 Hart RG, Benavente O, McBride R, . Antithrombotic therapy to prevent stroke in patients with atrial fibrillation: a meta-analysis. Ann Intern Med. 1999 Oct 05;131(7):492–501. PMID: 10507957.10507957
113 Lapner S, Cohen N, Kearon C. Influence of sex on risk of bleeding in anticoagulated patients: a systematic review and meta-analysis. J Thromb Haemost. 2014 May;12(5):595–605. PMID: 24977286.24977286
114 Roskell NS, Lip GY, Noack H, . Treatments for stroke prevention in atrial fibrillation: a network meta-analysis and indirect comparisons versus dabigatran etexilate. Thromb Haemost. 2010 Dec;104(6):1106–15. doi: 10.1160/th10-10-0642. PMID: 20967400.20967400
115 Sahay S, Nombela-Franco L, Rodes-Cabau J, . Efficacy and safety of left atrial appendage closure versus medical treatment in atrial fibrillation: a network meta-analysis from randomised trials. Heart. 2016 Sep 1doi: 10.1136/heartjnl-2016-309782. PMID: 27587437.27587437
116 Sardar P, Chatterjee S, Chaudhari S, . New oral anticoagulants in elderly adults: evidence from a meta-analysis of randomized trials. J Am Geriatr Soc. 2014 May;62(5):857–64. doi: 10.1111/jgs.12799. PMID: 24786913.24786913
117 Tawfik A, Bielecki JM, Krahn M, . Systematic review and network meta-analysis of stroke prevention treatments in patients with atrial fibrillation. Clin Pharmacol. 2016;8:93–107. doi: 10.2147/cpaa.s105165. PMID: 27570467.27570467