# Appendix E Additional Tables of Study Results

Appendix E Table 1 Results of Included Randomized, Controlled Trials for KQs 4 and 5

First Author, Year Trial Name | G1 (N) G2 (N) G3 (N) | All-Cause Mortality G1 N (%) G2 N (%) ES (95% CI) | Stroke- or CV-Related Mortality G1 N (%) G2 N (%) ES (95% CI) | Any Stroke G1 N (%) G2 N (%) ES (95% CI) | Cardioembolic or Ischemic Stroke G1 N (%) G2 N (%) ES (95% CI) | Stroke-Related Morbidity G1 N (%) G2 N (%) ES (95% CI) | Other G1 N (%) G2 N (%) ES (95% CI)
Petersen, 1989^90^ AFASAK | Warfarin, adjusted dose (335) Aspirin 75 mg daily (336) Placebo (336) | 71 total deaths Total mortality by group NR | [underlined: Stroke-related mortality] 1 (0.3) 3 (0.9) 4 (1.2) NR [underlined: Vascular deaths] 3 (0.9) 12 (3.6) 15 (4.5) p<0.02 | NR | [underlined: Cumulative incidence of thromboembolic related complications] 5 (1.5) 15 (6.0) 16 (6.3) p<0.05 [underlined: Annual incidence of thromboembolic complications] 2.0%/year (0.6 to4.8%) 5.5%/year (2.9 to 9.4%) 5.5%/year (2.9 to 9.4%) | [underlined: Minor stroke] 0 (0) 1 (0.3) 2 (0.6) NR [underlined: Nondisabling stroke] 0 (0) 7 (2.1) 3 (0.9) NR [underlined: Disabling stroke] 4 (1.2) 4 (1.2) 7 (2.1) NR | [underlined: TIA] 0 (0) 2 (0.6) 3 (0.9) NR [underlined: Visceral emboli] 0 (0) 2 (0.6) 2 (0.6) NR [underlined: Emboli in both extremities] 0 (0) 1 (0.3) 0 (0) NR
The Boston Area Trial for Atrial Fibrillation Investigators, 1990^95^ BAATAF | Warfarin, adjusted dose (212) Control (208) | [underlined: Total death] 11 (5.2) 26 (12.5) Rate ratio: 0.38 (0.17 to 0.82) p=0.005 [underlined: Noncardiac death (includes stroke-related mortality)] 4 (1.9) 14 (6.7) p=0.008 | [underlined: Stroke-related mortality] 0 (0) 1 (0.5) NR [underlined: CV-related mortality] 7 (3.3) 12 (5.8) p=0.17 | NR | [underlined: Ischemic/cardioembolic stroke] 2 (0.9) 13 (6.3) Incidence ratio: 0.14 (0.04 to 0.49) Risk reduction: 86% (96 to 51) | [underlined: Mild] 0 (0) 4 (1.9) NR [underlined: Moderate] 1 (0.5) 3 (1.4) NR [underlined: Severe] 1 (0.5) 5 (2.4) NR | [underlined: Possible ischemic stroke] 1 (0.5) 2 (1) NR [underlined: TIA] 2 (0.9) 3 (1.4) NR
Stroke Prevention in Atrial Fibrillation Investigators, 1990 & 1991 Stroke Prevention in Atrial Fibrillation Investigators, 1990 & 1991^93,^ ^94^ SPAF I | [underlined: Group 1 (anti-coagulation candidates)] Warfarin, adjusted dose (210) Aspirin 325 mg/day (206) Placebo (211) [underlined: Group 2 (non-anticoagulation candidates)] Aspirin 325 mg/day (346) Placebo (357) | [underlined: Total mortality warfarin vs. placebo (Group 1)] Warfarin: 6 (2.2%/year) Placebo: 8 (3.1%/year) Risk reduction: 0.25 (-1.11 to .73), p=0.56 [underlined: Total mortality aspirin vs. placebo (Groups 1 and 2 combined)] Aspirin: 39 (5.3%/year) Placebo: 50 (6.5%/year) Risk reduction: 0.20 (-0.20 to 0.46), p=0.37 | [underlined: Fatal ischemic stroke (Group 1)] Warfarin: 0 Placebo: 0 NA [underlined: Fatal ischemic stroke (Groups 1 and 2 combined)] Aspirin: 3 (0.5) Placebo: 2 (0.4) NR [underlined: Vascular death (Group 1)] Warfarin: 3 (1.4) Placebo: 5 (2.4) NA [underlined: Vascular death (Groups 1 and 2 combined)] Aspirin: 18 (3.3) Placebo: 19 (3.3) NR [underlined: Probable vascular death (Group 1)] Warfarin: 1 (0.5) Placebo: 2 (0.9) NA [underlined: Probable vascular death (Groups 1 and 2 combined)] Aspirin: 5 (0.9) Placebo: 8 (1.4) NR | NR | [underlined: Ischemic stroke or systemic embolism warfarin vs. placebo (Group 1)] Warfarin: 6 (2.3%/year) Placebo: 18 (7.4%/year) Risk reduction: 0.67 (0.27 to 0.85), p=0.01 [underlined: Ischemic stroke or systemic embolism vs. placebo (Groups 1 and 2 combined)] Aspirin: 26 (3.6%/year) Placebo: 46 (6.3%/year) Risk reduction: 0.42 (-0.09 to 0.63), p=0.02 | [underlined: Minimally disabling ischemic stroke (Group 1)] Warfarin: 4 (1.9) Placebo: 10 (4.7) NA [underlined: Minimally disabling ischemic stroke (Groups 1 and 2 combined)] Aspirin: 10 (1.8) Placebo: 24 (4.2) NR [underlined: Moderate to severely disabling ischemic stroke (Group 1)] Warfarin: 2 (1.0) Placebo: 7 (3.3) NA [underlined: Moderate to severely disabling ischemic stroke (Groups 1 and 2 combined)] Aspirin: 10 (1.8) Placebo: 16 (2.8) NR | [underlined: TIA without ischemic stroke or systemic embolism (Group 1)] Warfarin: 3 (1.1%/year) Placebo: 4 (1.6%/year) NR [underlined: TIA without ischemic stroke or systemic embolism (Group 2)] Aspirin: 7 (1.0%/year) Placebo: 13 (1.7%/year) Risk reduction: 0.45 (-0.32 to 0.77), p=0.19 [underlined: Myocardial infarction (Group 1)] Warfarin: 2 (0.8%/year) Placebo: 2 (0.8%/year) NR [underlined: Myocardial infarction (Group 2)] Aspirin: 7 (0.9%/year) Placebo: 12 (1.6%/year) Risk reduction: 0.40 (-0.46 to 0.75), p=0.29 [underlined: Primary event or death Warfarin vs. placebo (Group 1)] Warfarin: 10 (3.8%/year) Placebo: 24 (9.8%/year) Risk reduction: 0.58 (0.20 to 0.78), p=0.01 [underlined: Primary event or death aspirin vs. placebo (Groups 1 and 2 combined)] Aspirin: 57 (7.9%/year) Placebo: 86 (11.8%/year) Risk reduction: 0.32 (0.07 to 0.50), p=0.02
Connolly, 1991^84^ CAFA | Warfarin, adjusted dose (187) Placebo (191) | [underlined: All-cause mortality] NR [underlined: Other deaths & vascular deaths] (Efficacy analysis) 7 4) 6 (3) (ITT analysis) 10 (5) 8 (4) | [underlined: Vascular death] (Efficacy analysis) 6 (3.2) 6 (3.1) NR (ITT analysis) 9 (4.8) 6 (3.1) NR | NR | [underlined: Lacunar stroke] (Efficacy analysis) 1 (0.5) 0 (0) NR (ITT analysis) 1 (0.5) 0 (0) NR [underlined: Non-lacunar stroke] (Efficacy analysis) 4 (2.1) 9 (4.7) NR (ITT analysis) 5 (2.7) 9 (4.7) NR | [underlined: Severe non-lacunar stroke] (ITT analysis) 2 (1.1) 4 (2.1) NR [underlined: Mild non-lacunar stroke] (ITT analysis) 3 (1.6) 5 (2.6) NR | [underlined: TIA] (Efficacy analysis) 1 (0.5) 2 (1.0) NR (ITT analysis) 2 (1.1) 2 (1.0) NR [underlined: Non-CNS embolic event] (Efficacy analysis) 1 (0.5) 2 (1.0) NR (ITT analysis) 1 (0.5) 2 (1.0) NR
Ezekowitz et al, 1992^85^ SPINAF | Warfarin 4 mg/day and adjusted to meet PT ratios (260) Placebo (265) | 15 (5.8) (3.3%/year) 22 (8.3) (5.0%/year) Risk reduction: 0.31 (-0.29 to 0.63) p=0.19 | [underlined: Cardiac cause (not related to cerebral outcome)] 7 (2.7) 6 (2.3) ES NR [underlined: Fatal stroke] 1 (0.4) 1 (0.4) ES NR | 4 (1.5) (0.9%/year) 19 (7.2) (4.3%/year) Risk reduction: 0.79 (0.52 to 0.90) p=0.001 | 4 (1.5) (0.9%/year) 19 (7.2) (4.3%/year) Risk reduction: 0.79 (0.52 to 0.90) p=0.001 | [underlined: Stroke with no impairment] 0 9 (3.4) NR [underlined: Stroke with minor impairment] 3 (1.2) 7 (2.6) NR [underlined: Stroke with major impairment] 0 (0) 2 (0.8) NR | [underlined: Cerebral infarction or death] 19 (7.3) (4.2%/year) 41 (15.5) (9.3%/year) Risk reduction: 0.53 (0.24 to 0.71) p=0.003 [underlined: Thrombotic vascular events] 9 (3.5) (2.0%/year) 16 (6.0) (3.6%/year) Risk reduction: 0.43 (-0.22 to 0.74) p=0.16
Sato et al, 2006^92^ JAST | Aspirin 150–200 mg/day (426) Control (445) | [underlined: Cardiovascular death] 3 (.7) 3 (.67) p=1.00 [underlined: Noncardio-vascular death] 7 (1.6) 6 (1.35) p=0.720 | NR | 17 (4) 18 (4.04) p=0.967 | NR | NR | [underlined: TIA] 7 (1.64) 2 (.45) p=0.101 [underlined: Cardiogenic embolism] 14 (3.29) 12 (2.70) p=0.609 [underlined: Peripheral emboli] 0 (0) 1 (.22) p=1.000 [underlined: Thrombotic infarction] 3 (.70) 2 (.45) p=0.959 [underlined: Lacunar infarction] 0 (0) 4 (.9) p=0.135

Abbreviations: AFASAK=Copenhagen Atrial Fibrillation, Aspirin and Anticoagulation study; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; CI=confidence interval; CNS=central nervous system; CV=cardiovascular; ES=effect size; G=group; ITT=intent to treat; JAST=Japan Atrial Fibrillation Stroke Trial; KQ=key question; N=sample size; NA=not applicable; NR=not reported; PT=prothrombin time; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study; TIA=transient ischemic attack.

Appendix E Table 2 Results of Included Studies for KQ 5: Harms of Treatment

First Author, Year Trial Name | G1 (N) G2 (N) | Major Bleeding G1 N (%) G2 N (%) ES (95% CI) | Major GI Bleeding G1 N (%) G2 N (%) ES (95% CI) | Allergic Reaction G1 N (%) G2 N (%) ES (95% CI) | Hemorrhagic Stroke G1 N (%) G2 N (%) ES (95% CI) | Subarachnoid Hemorrhage G1 N (%) G2 N (%) ES (95% CI) | Intracerebral Hemorrhage G1 N (%) G2 N (%) ES (95% CI) | Subdural Hemorrhage/Hematoma G1 N (%) G2 N (%) ES (95% CI) | Minor Bleeding G1 N (%) G2 N (%) ES (95% CI) | Other Harms G1 N (%) G2 N (%) ES (95% CI)
Petersen, 1989^90^ The Copenhagen AFASAK Study | Warfarin dose adjusted per subject (335) Aspirin 75 mg 1x daily (336) Placebo (336) | [underlined: Bleeding (non-fatal) causing withdrawal from study] 21 (6.3) 2 0 [underlined: Respiratory tract bleeding] 4 (1.2) 1 (0.3) 0 (0) NR [underlined: Urogenital bleeding] 6 (1.8) 0 (0) 0 (0) NR [underlined: Other bleeding] 0 (0) 2 (0.6) 0 (0) NR | GI bleeding 4 (1.2) 1 (0.3) 0 (0) NR | 0 (0) 2 (0.6) 0 (0) NR | NR | NR | 1 (0.3) NR NR | NR | All bleeding reported in other columns (no definitions of severity) | [underlined: GI discomfort] 0 (0) 4 (1.2) 3 (0.9) NR
The Boston Area Trial for Atrial Fibrillation Investigators, 1990^95^ Boston Area Anticoagulation Trial for Atrial Fibrillation (BAATAF) | Warfarin, low dose NR (212) Control (208) | 2 (0.9) 1 (0.5) NR | 1 (0.5) 0 (0) NR | NR | NR | NR | 0 (0) 0 (0) NR | NR | Total 38 (17.9) 21 (10.1) Incidence Ratio: 1.62 (95% CI, 0.95 to 2.74) Leading to hospitali-zation 4 (1.9) 6 (2.9) NR Leading to transfusion 2 (0.9) 1 (0.5) NR | Transient Monocular Vision Loss 2 (0.9) 1 (0.5) NR Fatal pulmonary hemorrhage 0 (0) 1 (0.5) NR Fatal intracranial hemorrhage (due to loss of consciousness then falling) 1 (0.5) 0 (0) NR
Stroke Prevention in Atrial Fibrillation Investigators, 1990 & 1991^93,^ ^94^ Stroke Prevention in Atrial Fibrillation (SPAF) Study | [underlined: Group 1 (anti-coagulation candidates)] Warfarin-adjusted dose (210) Aspirin 325 mg/day (206) Placebo (211) [underlined: Group 2 (non-anticoagu-lation candidates)] Aspirin 325 mg/day (346) Placebo (357) | [underlined: Major bleeding complications intention to treat population] [underlined: (Group 1)] Warfarin: 4 (1.5%/year) Placebo: 4 (1.6%/year) NR [underlined: (Groups 1 and 2)] Aspirin: 10 (1.4%/year) Placebo: 14 (1.9%/year) NR [underlined: Major bleeding complications relevant bleeding] [underlined: (Group 1)] Warfarin: 3 (1.4) Placebo: 1 (0.5) NR [underlined: (Groups 1 and 2)] Aspirin: 5 (0.9) Placebo: 4 (0.7) NR | NR | [underlined: Severe allergic reactions] 0 (0) 0 (0) NR | NR | NR | [underlined: Group 1] Warfarin: 1 (0.5) Placebo: 0 (0) NR [underlined: Group 1 and 2] Aspirin: 1 (0.2) Placebo: 0 (0) NR | [underlined: Subdural hematoma] [underlined: (Group 1)] Warfarin: 1 (0.5) Placebo: 2 (0.9) NR [underlined: Subdural hematoma (Groups 1 and 2)] Aspirin: 1 (0.2) Placebo: 2 (0.4) NR | [underlined: Minor bleeding leading to therapy withdrawal] [underlined: (Group 1)] Warfarin: 4 (1.9) Placebo: 1 (0.5) NR [underlined: (Groups 1 and 2)] Aspirin: 0 (0) Placebo: 2 (0.4) NR | Intracerebral Fatal Hemorrhage Warfarin: 1 Placebo: 0 [underlined: (Groups 1 and 2)] Aspirin: 1 Placebo: 0
Connolly, 1991^84^ Canadian Atrial Fibrillation Anticoagulation (CAFA) Study^78^ | Warfarin dose adjusted per subject (187) Placebo (191) | [underlined: Life-threatening or major bleeding] 5 (2.7) 1 (0.5) NR [underlined: Other major bleeding after permanent discontinuation of medication] 0 1 | NR | NR | NR | NR | NR | NR | 30 (16) 18 (9.4) NR | [underlined: Intracranial hemorrhage] (Efficacy analysis) 1 (0.5) 0 (0) NR (Intention to treat analysis) 1 (0.5) 0 (0) NR [underlined: Other fatal hemorrhage] (Efficacy analysis) 1 (0.5) 0 (0) NR (Intention to treat analysis) 1 (0.5) 0 (0) NR [underlined: Annual rate of fatal or major hemorrhage] 2.5%/year 0.5%/year NR
Ezekowitz et al, 1992^85^ Veterans Affairs Cooperative Study SPINAF | Patients without previous cerebral infarction: Warfarin: 4 mg/day and adjusted to meet PT ratios (260) Control (265) Patients with previous cerebral infarction: Warfarin: 4 mg/day and adjusted to meet PT ratios (21) Control (25) | Without previous cerebral infarction: Major hemorrhage 6 (2.3) (1.3%/year) 4 (1.5) (0.9%/year) Risk reduction: -0.53 (-4.22 to 0.55) p=0.54 With previous cerebral infarction: 0 (0) 0 (0) | Without previous cerebral infarction: Major hemorrhage 6 (2.3) (1.3%/year) 4 (1.5) (0.9%/year) Risk reduction: -0.53 (-4.22 to 0.55) p=0.54 With previous cerebral infarction: 0 (0) 0 (0) | NR | NR | NR | Without previous cerebral infarction: Cerebral hemorrhage 1 (0.4) 0 (0) ES NR With previous cerebral infarction: Cerebral hemorrhage 0 (0) 0 (0) | NR | Without previous cerebral infarction: Minor hemorrhage 64 (24.6) (14.0%/year) 46 (17.4) (10.5%/year) Risk reduction: -0.42 (-0.98 to -0.02) p=0.04 With previous cerebral infarction: Minor hemorrhage 3 (14.3) (9.2%/year) 7 (28.0) (16.2%/year) Risk reduction: 0.49 (-0.53 to 0.83) p=0.31 | NR
Sato et al, 2006^92^ Japan Atrial Fibrillation Stroke Trial (JAST) | Aspirin 150–200 mg/day (426) Control (445) | Major bleeding 7 (1.64) 2 (0.45) p=0.101 | NR | NR | NR | NR | NR | NR | NR | Intracranial bleeding 4 (0.94) 2 (0.45) NR

AFASAK did not specify bleeding severity and was therefore not included in this analysis. It reported bleeding events leading to withdrawal from study, 21 for warfarin and 0 for placebo.

BAATAF, minor bleeding was defined as bleeding that did not include intracranial bleeding, fatal bleeding, or bleeding that required a blood transfusion (four or more units of blood within 48 hours).

SPAF I, minor bleeding defined as bleeding that did not involve the central nervous system, management requiring hospitalization with transfusion and/or surgery, or permanent residual impairment.

CAFA, minor bleeding defined as non-life-threatening bleeding.

SPINAF, minor bleeding defined as bleeding that did not require a blood transfusion, an emergency procedure, removal of a hematoma, or ICU admission.

Abbreviations: AFASAK=Copenhagen Atrial Fibrillation, Aspirin and Anticoagulation study; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; CI=confidence interval; ES=effect size; G=group; JAST=Japan Atrial Fibrillation Stroke Trial; KQ=key question; N=sample size; NA=not applicable; NR=not reported; PT=prothrombin time; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study.

Appendix E Table 3 Summary of Included Systematic Reviews, Individual Patient Data Meta-Analyses, and Network Meta-Analyses on Benefits and Harms of Treatment for Atrial Fibrillation

Author, Year Intervention vs. Comparison | Review Type | Total N | Characteristics of Participants | Main Findings
Aguilar, 2009^100^ Warfarin vs. Placebo | SR with MA | 2,313 | Mean age: 69 Female: 26% Nonwhite: NR History of HF: 45% Diabetes: 15% Prior MI: 15% HTN: 45% Prior stroke or TIA: 3 to 8% in published results of the included studies, but they report obtaining the unpublished results without those 3 to 8% | Included same RCTs as our report Odds ratio (95% CI) All strokes (including ischemic and hemorrhagic): 0.39 (0.26 to 0.59) All Ischemic strokes: 0.34 (0.23 to 0.52)^a^ Disabling or fatal strokes (including ischemic and hemorrhagic): 0.47 (0.28 to 0.80) MI: 0.87 (0.32 to 2.42) All systemic emboli: 0.45 (0.13 to 1.57) Intracranial hemorrhage: 2.38 (0.54 to 10.5) Major extracranial bleeding: 1.07 (0.53 to 2.12)^b^ Vascular death: 0.84 (0.56 to 1.27) Stroke, MI, or vascular death: 0.56 (0.42 to 0.76) All-cause mortality: 0.69 (0.50 to 0.94)
Aguilar, 2011^108^ AP vs. Placebo | SR with MA | 2,622 | Mean age: 70 Female: 38% % nonwhite: NR History of HF: NR Diabetes and prior MI: NR Prior stroke or TIA: NR HTN: NR | Included AFASAK I, SPAF I, and LASAF (not JAST) Odds ratio (95% CI) All strokes (including ischemic and hemorrhagic): 0.70 (0.47 to 1.07) Ischemic strokes: 0.70 (0.46 to 1.07) All disabling or fatal strokes (including ischemic and hemorrhagic): 0.86 (0.50 to 1.49) MI: 0.47 (0.19 to 1.14) Systemic emboli: 0.67 (0.19 to 2.3) Intracranial hemorrhage: 1.32 (0.22 to 7.80) Major extracranial bleeding: 1.14 (0.44 to 2.98) Vascular death: 0.82 (0.54 to 1.25) Composite outcome: all stroke, MI, or vascular death: 0.71 (0.51 to 0.97) All-cause mortality: 0.75 (0.54 to 1.04)
Atrial Fibrillation Investigators, 1997^105^ Aspirin vs. Placebo | IPD | 2,574 | Mean age: 70 Female: 38% Nonwhite: NR History of HF: 28 Diabetes: 14% Prior MI: 10% Prior stroke or TIA: 35% HTN: 46% | Included AFASAK I and SPAF I, and a secondary prevention trial (EAFT). Relative risk reduction (95% CI) Stroke: 21% (0% to 38%); p=0.05 Disabling stroke: 17% (-12% to 38%; p=0.23) Nondisabling stroke occurrence: 27% (-7% to 51%; p=0.10) Subgroups Age: 1.02 (0.99 to 1.05) Age ≤75: 0.73 (0.54 to 0.99) Male: 0.80 (0.58 to 1.11) Female: 0.80 (0.56 to 1.13) SBP>160 mm Hg: 0.75 (0.48 to 1.18) SBP<160 mm Hg: 0.81 (0.61 to 1.07) History of hypertension: 0.64 (0.46 to 0.89), p=009; interaction NS, p=.08 No history of hypertension: 0.98 (0.70 to 1.39) History of CHF: 0.54 (0.33 to 0.89) No history of CHF: 0.89 (0.68 to 1.16) History of diabetes: 0.60 (0.34 to 1.06) No history of diabetes: 0.84 (0.65 to 1.09) Risk stratification No clinical risk factors: 1.33 (0.66 to 2.68) >1 clinical risk factors: 0.72 (0.56 to 0.93) (interaction between aspirin and risk factor NS, p=0.10) History of hypertension or diabetes but with no previous stroke or TIA: 54% (17% to 74%; p=0.009; interaction term, p=0.02) Except for patients younger than 65 years, the absolute risk of stroke with aspirin therapy did not decrease below 3.0% per year for any of the risk strata
Atrial Fibrillation Investigators, 1994^103^ Warfarin vs. Placebo Aspirin vs. Placebo | IPD | 4,174 | Mean age: 69 Female: 26% Nonwhite: 7% History of HF: 20% Diabetes: 14% Prior MI: 14% Prior stroke or TIA: 6% HTN: 45% | Included same RCTs as our report for warfarin; only included AFASAK and SPAF for aspirin (JAST was not yet published) Warfarin (1889 patient-years receiving warfarin) Relative risk reduction (95% CI) Stroke: 68% (50% to 79%); 3.1% Absolute annual reduction, p<0.001 Stroke with residual deficit: 68% (39% to 83%); 1.4% absolute annual reduction, p<0.001 Death: 33% (9% to 51%); p=0.010 Stroke, systemic embolism, or death: 48% (34% to 60%); p<0.001 Annual frequency of major bleeding events: 1.3% (vs. 1.0% for controls). Patients taking warfarin who had intracranial bleeding (n=6) had a higher systolic (p=0.001) and diastolic (p=0.016) blood pressure at entry to study than patients taking warfarin who did not have intracranial bleeding (mean 169/93 vs. 141/83) Mean age of those with and without intracranial bleeding as 73 and 69, NS Effect of Warfarin on Stroke by Subgroup Women: 84% (55% to 95%), p<0.001 Men: 60% (35% to 76%), p<0.001 Aspirin 1,132 (patient-years receiving aspirin) Relative risk reduction (95% CI) Stroke: 36% (4% to 57%); p=0.03 Stroke with residual deficit: 30% (20% to 60%); NS Rate of death: 17% (20% to 40%); NS Combination of stroke, systemic embolism, or death: 28% (6% to 45%); p=0.02 Annual frequency of major bleeding events: 1.0% Effect of Aspirin on Stroke by Subgroup History of hypertension: 59% (28% to 77%); p=0.002 No history of hypertension: 10% (40% to 100%); p=0.76 p=0.02 for difference in effectiveness between those with and without hypertension Effect of Aspirin on Stroke by Subgroup Women: 23% (40% to 58%), p=0.38 Men: 44% (3% to 68%), p=0.04
Coleman, 2012^102^ Warfarin vs. Placebo Aspirin vs. Placebo VKA vs. Aspirin | SR with MA | 42,983 | Mean age: 65–75 Female: 0–59% % nonwhite: NR History of HF: NR Diabetes and prior MI: NR Prior stroke or TIA: NR Target range of INRs: NA Median followup: 2 years | Combines studies of primary and secondary prevention (participants had a TIA or stroke) and does not provide any analyses separating them, possibly limiting applicability; did not include SPAF-1, CAFA, or LASAF (but those did not report major gastrointestinal bleeding); also included studies of combinations of medications (e.g., aspirin plus low-dose VKA) Major gastrointestinal bleeding odds ratio (95% CI), 4 trials (including EAFT), 2,219 participants Adjusted-dose warfarin vs. placebo/control: 3.21 (1.32 to 7.82) Aspirin vs. placebo/control: 3.23 (0.56 to 18.66); 3 trials (AFASAK I, JAST, and EAFT), 2,325 participants Adjusted-dose VKA vs. aspirin: 1.92 (1.08 to 3.41); 7 trials, 4,819 participants
Hart, 2007^107^ Warfarin vs. Placebo Aspirin vs. Placebo Warfarin vs. Aspirin | SR with MA | 28,044 (but most of those from secondary prevention trials) | Warfarin Mean age: 69 Female: 29% Prior stroke or TIA: 20% Aspirin Mean age: 69 Female: 37% Prior stroke or TIA: 29% Median followup: 1.6 to 1.7 years overall | Included secondary prevention RCTs in addition to primary prevention RCTs for most analyses; only separated primary prevention results (using the same trials we included) when reporting absolute risk reduction and NNT Warfarin vs. placebo or no treatment for primary prevention: Stroke, ARR: 2.7%/year (vs. 8.4% for secondary prevention); NNT 40 Aspirin vs. placebo or no treatment for primary prevention: Stroke, ARR: 0.8%/year (vs. 2.5% for secondary prevention); NNT 111 Warfarin vs. aspirin for primary prevention: Stroke, ARR: 0.7%/year (vs. 7% for secondary prevention); NNT 81 Safety outcomes included all trials identified (not limited to primary prevention): Warfarin vs. placebo or no treatment Intracranial hemorrhage: 6 vs. 3 events (RR not calculated) Major extracranial hemorrhage: -66 (-235 to 18); -0.3%/year ARR All-cause mortality: 26 (3 to 43); 1.6%/year ARR Aspirin vs. placebo or no treatment Intracranial hemorrhage: 8 vs. 4 events (RR not calculated) Major extracranial hemorrhage: -2 (-98 to 52); -0.2%/year ARR All-cause mortality: 14 (-7 to 31); 0.5 %/year ARR
Tereshchenko, 2016^104^ All comparisons | NMA | 96,017 | Mean age: 71.5 Female: 35% Nonwhite: NR Prior stroke or TIA: NR overall, but ranged from 0% to 100%; 4 (of 21) included trials had over 35% secondary prevention; and both trials of rivaroxaban, JROCKET and ROCKET AF, included more than 50% for secondary prevention. Median followup: 1.7 years | Included 21 RCTs of treatment for nonvalvular AF. Not limited to primary prevention. Results below were unadjusted unless otherwise noted (for the major bleeding outcome, unadjusted data were not provided in the published article but were obtained from the author). VKAs vs. placebo/control odds ratio (95% CI) Stroke or systemic embolism: 0.38 (0.29 to 0.49) All-cause mortality: 0.69 (0.57 to 0.85) Placebo/control vs. VKA Unadjusted; adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup) Stroke or systemic embolism: 2.65 (2.03 to 3.46); 2.30 (1.50 to 3.54) All-cause mortality: 1.44 (1.17 to 1.76);1.33 (0.90 to 1.95); Major bleeding: 0.40 (0.24 to 0.68); 0.47 (0.22 to 1.00) Aspirin vs. placebo/control odds ratio (95% CI) Unadjusted; adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup) Stroke or systemic embolism: 0.75 (0.60 to 0.95); 0.77 (0.53, 1.11) All-cause mortality: 0.82 (0.68 to 0.99); 0.82 (0.57, 1.17) Major bleeding: 1.79 (1.06 to 3.04); 1.65 (0.77 to 3.51) NOACs vs. placebo/control odds ratio (95% CI) for stroke or systemic embolism Unadjusted; Adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup) Apixaban 0.31 (0.22 to 0.45); 0.35 (0.21 to 0.58) Dabigatran 0.29 (0.20 to 0.43); 0.34 (0.19 to 0.60) Edoxaban 0.38 (0.26 to 0.54); 0.44 (0.25 to 0.77) Rivaroxaban 0.27 (0.18 to 0.42); 0.32 (0.16 to 0.66) Comparison of NOACs: no statistically significant differences in effectiveness for each of the 4 NOACs in comparison to one another NOACs vs. VKA: risk of stroke or systemic embolism; OR (95% CI) Unadjusted; adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup) Apixaban 0.82 (0.62 to 1.10); 0.81 (0.57 to 1.15) Dabigatran 0.78 (0.60 to 1.01); 0.78 (0.53 to 1.14) Edoxaban 1.00 (0.79 to 1.27); 1.01 (0.70 to 1.45) Rivaroxaban 0.72 (0.51 to 1.00); 0.74 (0.42 to 1.31) NOACs vs. VKA: risk of all-cause mortality; OR (95% CI) Unadjusted; Adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup) Apixaban 0.89 (0.80 to 0.99); 0.89 (0.71 to 1.13) Dabigatran 0.90 (0.82 to 0.99); 0.88 (0.70 to 1.12) Edoxaban 0.89 (0.82 to 0.96); 0.90 (0.71 to 1.14) Rivaroxaban 0.84 (0.70 to 1.01); 0.84 (0.48 to 1.48) NOACs vs. VKA: major bleeding Edoxaban 0.61 (0.36 to 1.01); 0.64 (0.46 to 0.90) Only edoxaban was significantly different (adjusted ORs from 0.74 to 0.85 for the others but CIs go up to 1.02 through 1.57 for the various NOACs)
van Walraven, 2008^106^ Oral anticoagulant (mostly warfarin)^c^ vs. Placebo Antiplatelet (mostly Aspirin) vs. Placebo | IPD | 8,932 | Mean age: 70.9 for all studies except for BAFTA with was 81.5 Female: 37% History of HF: 20% Diabetes and prior MI: 15 Prior stroke or TIA: 22% HTN: 50% AP dose range: 75 mg to 325 mg daily Median followup: 2.0 years | Included secondary prevention RCTs in addition to primary prevention RCTs; did not separate primary prevention results OAC hazard ratio (95% CI) Ischemic stroke: 0.36 (0.29 to 0.45) Systemic or intracranial hemorrhage: 1.56 (1.03 to 2.37) Cardiovascular event: 0.59 (0.52 to 0.66) Interaction of age and OAC Ischemic stroke: X^2^=3.2, p=0.07; trend toward decreasing relative benefit of OAC (HR moved toward 1 as patients age. HR 0.22 [95% CI, 0.11, 0.41] for 50-year-olds and HR 0.53 [0.35, 0.81] for 90-year-olds) Serious hemorrhage: NS Cardiovascular events: NS AP hazard ratio (95% CI) Ischemic stroke: 0.81 (0.72 to 0.90) Systemic or intracranial hemorrhage: 1.03 (0.71 to 1.49) Cardiovascular event: 0.81 (0.75 to 0.88) Interaction of age and AP Ischemic stroke: X^2^=6.5, p= 0.01; relative benefit of AP for preventing stroke decreased significantly with age; HR, 0.40; 95% CI, 0.22 to 0.72 at age 50; by age 77, the HR no longer excluded the null; at age 82, the HR exceeded 1. Serious hemorrhage: NS Cardiovascular events: NS

a Subgroup analysis was performed for the outcome “ischemic stroke (fatal and nonfatal).” There was no evidence of a difference in the treatment effect between double-blind trials and open-label trials, p=0.92.

b In the text, they also report that meta-analysis of data from six trials in which 20% had prior stroke, TIA, or both, major extracranial bleeding was increased in those assigned to OAC (OR 1.80, 95% CI, 1.01 to 3.18), presumably that was by adding EAFT (in which all participants had a history of stroke or TIA).

c Some secondary prevention studies used 4-hydroxycoumarin instead of warfarin.

d One secondary prevention study used triflusal.

Abbreviations: AFASAK=Copenhagen Atrial Fibrillation, Aspirin and Anticoagulation study; AP= antiplatelet therapy; ARR=absolute risk reduction; BAFTA=Birmingham Atrial Fibrillation in the Aged; CAFA=Canadian Atrial Fibrillation Anticoagulation study; CHADS_2_=Congestive heart failure, Hypertension, Age≥75 years, Diabetes mellitus, Prior stroke or TIA or thromboembolism; CHF=cardiac heart failure; CI=confidence interval; EAFT=European Atrial Fibrillation Trial Study Group; G=group; HF=heart failure; Hg=hemoglobin; HR=hazard ratio; HTN: hypertension; INR=International Normalized Ratio, assay used to determine clotting tendency; IPD=individual patient data meta-analysis; JAST=Japan Atrial Fibrillation Stroke Trial; JROCKET=Japanese Rivaroxaban Once Daily Oral Direct Factor Xa Inhibition Compared with Vitamin K Antagonism for Prevention of Stroke and Embolism Trial in Atrial Fibrillation; LASAF=low-dose aspirin, stroke atrial fibrillation trial; MA=meta-analysis; MI=myocardial infarction; N=sample size; NA=not applicable; NR=not reported; NS=not significant; NMA=network meta-analysis; NNT=number-needed-to-treat; NOAC=novel oral anticoagulants; OAC=oral anticoagulant; OR=odds ratio; RCT=randomized, controlled trial; ROCKET AF=Rivaroxaban Once Daily Oral Direct Factor Xa Inhibition Compared with Vitamin K Antagonism for Prevention of Stroke and Embolism Trial in Atrial Fibrillation; RR=relative risk; SBP=systolic blood pressure; SPAF=Stroke Prevention in Atrial Fibrillation Study; SR=systematic review; TIA=transient ischemic attack; TTR=time in therapeutic range; VKA=vitamin K antagonists.