# Appendix D Quality and Relevance Assessments

Appendix D Table 1 Quality Assessment of Randomized, Controlled Trials (All KQs): Part 1

First Author, Year Trial Name | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | What was the reported intervention fidelity? | What was the reported adherence to the intervention? | Did the study have cross-overs or contamination raising concern for bias? | What was the overall attrition? | What was the differential attrition? | Did the study have differential attrition or overall high attrition raising concern for bias?
Benito, 2015^83^ EARLY pilot study | Unclear | Unclear | Yes, for those analyzed, but NR for those randomized; and not many characteris-tics reported (e.g., medications and smoking NR) | NR | NR | Unclear | 77% of the 4,000 randomized were not included in analyses; the authors report an overall loss to followup of 5.8% (using a smaller denominator around 900 that does not consider all of the post-randomization exclusions) | 9.7% vs. 1.9% | Yes, very high overall attrition
Connolly, 1991^84^ CAFA study | Unclear, method of sequence generation NR | NR | Yes | NA | NR | No (<3%) | Lost to followup NR (implied 0 or very low); 25% discontinued medication | NR; 4% | No
Ezekowitz, 1992^85^ | Unclear | Unclear | Yes | NA | NR | NR | 4% lost to followup; 16% dropped out | 2%; 3% | No
Fitzmaurice, 2014^53^; Fitzmaurice, 2007^43^; Mant, 2007^86^; Hobbs, 2005^87^; Swancutt, 2004^88^ SAFE | Yes | No | Yes for age and sex; unclear otherwise | 53% of patients invited for systematic screening underwent ECG | NA | NR, but not suspected | 0.6% missing data | 0.1% | No
Halcox, 2017^89^ REHEARSE-AF | Unclear, method of sequence generation NR but was centralized process with interactive voice response | NR | Yes | NR | 74% submitted single-lead ECG recordings every week | No | G1: 5/500 (1%) G2: NR | NR, but likely low | No
Morgan, 2002^36^ | Yes | Unclear | Yes for age and sex; unclear otherwise | 73% of those invited for screening had pulse assessed | NA | NR | NR | NR | Unclear
Petersen, 1989^90^ AFASAK | Yes | Unclear | Yes | NA | NR | No | Unable to determine amount of missing data (lost to followup NR), Number of withdrawals is reported (222/1,007=22%) but it indicates that these subjects were still followed up for outcomes. | Unable to determine for missing data (lost to followup); For withdrawals, 126 (38%) warfarin vs. 44 (12%) aspirin vs. 52 (16%) placebo and most of the difference was due to refusal to continue the medication. | Unclear
Posada, 1999^91^ LASAF Pilot Study | Unclear, method of sequence generation NR | NR | Yes for things in Table 1, but unclear for many risk factors for the outcomes that were NR (e.g., hypertension, smoking, medications) | NA | NR, although they report that 7% of those treated with aspirin withdrew because of GI discomfort or mild bleeding | NR | 0% missing data; 18% dropped out (including due to adverse effects and events/outcomes) | 0%; 8% | No
Sato, 2006^92^ JAST | Unclear, method of sequence generation NR | Yes | Yes | NA | NR | NR | 0.3% missing data; 21.2% noncompleters (including due to side effects, cardiac and other diseases, and personal reasons) | 0.7%; 2.5% | No
Stroke Prevention in Atrial Fibrillation Study Group, 1990^93^ Stroke Prevention in Atrial Fibrillation Study Group, 1991^94^ SPAF | Yes | Unclear | Yes | NA | 88% of participants averaged over 80% adherence by pill count | NR | 0% lost to followup; 1.5% of scheduled followup visits not completed | 0%; NR; 11.2% discontinued warfarin vs. 5% for aspirin, vs. 6.6% for placebo | No
The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators, 1990^95^ BAATAF | Yes | Yes | Yes | NA | NR, although high time in therapeutic range over 80% suggests high adherence | Yes, aspirin allowed in control group (but not in warfarin group) and was being taken during 46% of all patient-years in control group | 0% lost to followup; 10% of warfarin group discontinued the medication (NA for control; no placebo control) | 0%; NA | No

Abbreviations: AFASAK=Atrial Fibrillation, Aspirin and Anticoagulation study; BAATAF= Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation; EARLY=Early diagnosis of Atrial fibrillation: a Randomized triaL in primarY care; ECG=electrocardiogram; GI=gastrointestinal; JAST=Japan Atrial Fibrillation Stroke Trial; KQ=key question; LASAF= low-dose aspirin, stroke atrial fibrillation trial; NA=not applicable; NR=not reported; REHEARSE-AF=Assessment of REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation; SAFE= Screening for AF in the elderly study; SPAF= Stroke Prevention in Atrial Fibrillation.

Appendix D Table 2 Quality Assessment of Randomized, Controlled Trials (All KQs): Part 2

First Author, Year Trial Name | Were outcome measurements equal, valid, and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did the study use acceptable statistical methods? | Quality Rating | Comments
Benito, 2015^83^ EARLY pilot study | No, outcomes measures were not equal between groups; IG had visits every 6 months that included an ECG, whereas CG only had outcomes based on clinical history from EHR and as needed phone calls | No, not feasible | Yes | Unclear | Yes | NR | Yes | Poor | High risk of selection bias, measurement bias, and confounding. Very high overall attrition (>70% of those randomized were not included in analyses), methods of outcome assessment differed between IG and CG, unclear methods of randomization and allocation concealment, and no information about handling of missing data, or masking of outcome assessors. We note that it is self-described as a pilot study (indicating that the purpose may be mainly for planning a future study).
Connolly, 1991^84^ CAFA study | Yes | Yes | Yes, except for person seeing PT/INR and making dose adjustments | Yes | Yes (mean followup 15.2months) | NR | Yes | Fair | Stopped early because of other positive studies with similar design and objectives; planned 630 participants and 2.5 years followup (378 analyzed)
Ezekowitz, 1992^85^ | Yes | Yes | No, for those adjusting doses; yes for cardiologist and neurologist | Yes | Yes (mean followup 1.7 to 1.8 years) | Censored | Yes | Fair | Warfarin vs. placebo; Stopped early with DSMB involvement and prespecified interim analyses showing benefit of warfarin and other similar studies being stopped early
Fitzmaurice, 2014^53^; Fitzmaurice, 2007^43^; Mant, 2007^86^; Hobbs, 2005^87^; Swancutt, 2004^88^ SAFE | Yes | No | No | Yes | Yes | Excluded; complete records only | Yes | Fair | Practices randomized to screening intervention or not (and randomization again within intervention group for opportunistic vs. systematic); no concealment of allocation; baseline comparison only provided for age and sex (no information on other variables or on practice characteristics, although randomization was stratified by practice size); good approach to determining when atrial fibrillation was previously diagnosed
Halcox, 2017^89^ REHEARSE-AF | Uncertain but seems that approach to confirming AF may have differed between groups | No | No | No | Yes (for primary outcome of AF detection) | NR | Yes | Fair | Moderate risk of measurement bias with lack of any masking and uncertainty about what workup was done to confirm AF. Underpowered for KQ 1 outcomes.
Morgan, 2002^36^ | Unclear, single observer reviewed medical records | No | No | NR | Unclear (6 months and few new cases of atrial fibrillation) | NR | Yes | Fair | The main outcomes describe total numbers of atrial fibrillation cases detected (inclusive of both previously known atrial fibrillation and newly diagnosed atrial fibrillation), so their main outcomes are not relevant for our questions; they also report incident cases, but they give somewhat limited details on methods of medical record review process for determining whether patients had previously diagnoses atrial fibrillation, and it was done by a single person (and masking NR); given that there were only 12 vs. 7 new cases (few events) and the study only covered 6 months of screening, the study provides limited information, although it shows pretty good uptake/fidelity; Allocation concealment NR; baseline comparison only provided for age and sex
Petersen, 1989^90^ AFASAK | Yes | No for warfarin Yes for ASA and placebo | No for warfarin Yes for ASA and placebo | Yes | Yes | NR | Yes | Fair | Thromboembolic endpoints were clinically confirmed, and also classified by a neurologist using a priori criteria. Information on missing data NR, unable to determine attrition; open-label for warfarin
Posada, 1999^91^ LASAF Pilot Study | Unclear | No | No | NR | Unclear (all followed a minimum 12 months) | NR | Yes | Poor | Open-label; stopped early because of results from other trials on aspirin being published; methods of randomization sequence generation and allocation concealment NR; methods of outcome ascertainment unclear and masking of outcome assessors NR; high risk of measurement bias
Sato, 2006^92^ JAST | Yes | No | No | Yes | Unclear, mean followup of 2-3 years planned (stopped early) | NR | Yes | Fair | Open-label; trial stopped early because of interim analysis showing possibly higher risk of bleeding and aspirin unlikely to be superior to no treatment for benefits
Stroke Prevention in Atrial Fibrillation Study Group, 1990^93^ Stroke Prevention in Atrial Fibrillation Study Group, 1991^94^ SPAF | Yes | No | No | Yes | Yes (mean followup 1.3 years) | NA | Yes | Fair | Placebo arm was stopped early (multi-arm trial, and the warfarin and aspirin arms continued); open-label warfarin (although aspirin and placebo were given in a double-blind fashion); allocation concealment unclear
The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators, 1990^95^ BAATAF | Yes | No | No | Yes | Yes (mean followup 2.2 years) | NA, reported no missing data | Yes | Fair | Stopped early because of evidence favoring warfarin over control (had already enrolled target number of participants, but had not reached the mean 4.1 years planned); contamination with aspirin in control group (might lead to underestimation of both benefits and harms of warfarin); no placebo; open-label

Abbreviations: AFASAK=Copenhagen Atrial Fibrillation, Aspirin and Anticoagulation study; ASA=aspirin; BAATAF= Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation; CG=control group; DSMB=Data and Safety Monitoring Board; EARLY=Early diagnosis of Atrial fibrillation: a Randomized triaL in primarY care; ECG=electrocardiogram; EHR=electronic health record; IG=intervention group; JAST=Japan Atrial Fibrillation Stroke Trial; LASAF=Low-dose Aspirin, Stroke Atrial Fibrillation trial; NR=not reported; PT/INF=prothrombin time/International Normalized Ratio; REHEARSE-AF=Assessment of REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation; SAFE=Screening for AF in the Elderly study; SPAF= Stroke Prevention in Atrial Fibrillation.

Appendix D Table 3 Quality Assessment of Randomized, Controlled Trials: Additional Questions for Studies Reporting Harms (KQs 3 and 5 Only)

First Author, Year Trial Name | Were harms pre-specified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Quality Rating | Comments
Benito, 2015^83^ EARLY pilot study | No | No | No | Yes | Poor | High risk of selection bias, measurement bias, and confounding
Connolly, 1991^84^ Canadian Atrial Fibrillation Anticoagulation (CAFA) study | Yes | Yes | Yes | Yes (mean followup 15.2 months) | Fair | Self-report of bleeding events
Ezekowitz, 1992^85^ | Yes | Yes | Yes | Yes (mean followup 1.7 to 1.8 years) | Fair
Fitzmaurice, 2014^53^; Fitzmaurice, 2007^43^; Mant, 2007^86^; Hobbs, 2005^87^; Swancutt, 2004^88^ SAFE | Yes | Yes | NA (only measured for intervention group) | Yes | Fair | Limited information about harms, but protocol/methods paper prespecified measurement of anxiety (intervention group only) and evaluation of primary care provider accuracy of interpretation of ECGs (direct implications for mislabeling and potential harms); the anxiety information was only collected for those getting ECGs and was not collected for the control group (so unable to make any conclusions for anxiety that directly address our question)
Halcox, 2017^89^ REHEARSE-AF | Yes | Yes | Yes, equal; uncertain validity and reliability for some outcomes | Yes | Poor | Potential harms of screening reported in the study included anxiety. High risk of measurement bias. No masking. Did not use a valid and reliable instrument. The question used was “Did participation in this study make you more anxious about your risk of heart rhythm abnormalities and / or stroke”? (response options were from 1 = No more anxious to 10 = More anxious). They also had a question about anxiousness using the device (“To what extent did you feel anxious in using the AliveCor device”?), but it was only asked of the intervention group.
Petersen, 1989^90^ AFASAK | Yes | Yes | Yes | Yes | Fair
Posada, 1999^91^ LASAF Pilot Study | Unclear whether prespecified; hemorrhagic stroke was defined, bleeding events were not | No | Unclear | Unclear (all followed a minimum of 12 months) | Poor | See comments for KQ 4 quality evaluation of this study
Sato, 2006^92^ JAST | Yes | Yes | Yes | Unclear | Fair | Open-label; stopped early
Stroke Prevention in Atrial Fibrillation Study Group, 1990^93^ Stroke Prevention in Atrial Fibrillation Study Group, 1991^94^ SPAF | Yes | Yes | Yes | Yes (mean followup 1.3 years) | Fair
The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators, 1990^95^ BAATAF | Yes | Yes | Yes | Yes (mean followup 2.2 years) | Fair

Abbreviations: AFASAK=Copenhagen Atrial Fibrillation, Aspirin and Anticoagulation study; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; EARLY=Early diagnosis of Atrial fibrillation: a Randomized triaL in primarY care; ECG=electrocardiography; JAST=Japan Atrial Fibrillation Stroke Trial; KQ=key question; NA=not applicable; NR=not reported; REHEARSE-AF=Assessment of REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation; SAFE= Screening for AF in the elderly study; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study.

Appendix D Table 4 Quality Assessment of Cohort Studies (KQs 2, 3, 5 Only): Part 1

First Author, Year, Study Name | Were eligibility criteria clearly described? | Were groups similar at baseline? | What was the reported intervention fidelity? | What was the reported adherence to the intervention? | Did the study have cross-overs or contamination raising concern for bias? | What was the overall attrition? | What was the differential attrition? | Did the study have differential attrition or overall high attrition raising concern for bias?
Caro, 1999^96^ | Yes | No | NA | NR | Yes | NR | NR | Unclear
Forslund, 2014^97^ | Yes | No | NA | NR | Yes | NR | NR | Unclear
Humphries, 2001^98^ | Yes | NR for warfarin vs. no warfarin (only reported for men vs. women, and they were not similar) | NA | NR | Unclear | 1% loss to followup; 14% did not complete 3-year visit evaluation | NR | Unclear
Kodani, 2016^99^ J-RHYTHM Registry 2 | Yes | No | NR. Analysis based on final status of medication use (at time of an event or end of followup). | NR. Analysis based on final status of medication use. | Yes | Loss to followup: 0.7% | NR | NR for differential; no for overall

Abbreviations: KQ=key question; NA=not applicable; NR=not reported; vs=versus.

Appendix D Table 5 Quality Assessment of Cohort Studies (KQs 2, 3, 5 only): Part 2

First Author, Year | Was assessment of the drug exposure (dose and duration) valid and reliable? | Were outcome measure-ments equal, valid, and reliable? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did the study use acceptable statistical methods? | Did the analysis adjust for potential confounders? | Quality Rating | Comments
Caro, 1999^96^ | Unclear for duration (self-report, but vague description of ascertainment methods); no assessment of dose | Yes equal, but uncertain validity and reliability (relied on patient recall, although they sought confirmation from charts) | No | Yes | Censored | Complete data only; and not ITT (reassigned to “blended” group if treatment changed) | No (Cox model but did not report adjusting for anything for the bleeding assessment) | Poor | High risk of confounding and selection bias; no adjustment for potential confounders; high risk of contamination; many baseline characteristics differ significantly between groups; not ITT analysis; sample size under 250 may be inadequate; attrition NR
Forslund, 2014^97^ | No | Unclear | No | Yes | NR | No | No | Poor | High risk of selection bias and confounding; no adjustment for potential confounders; not ITT; concern for cross-over and contamination; aspirin ascertainment based on prescriptions only; determined whether participants had atrial fibrillation based on 2005 to 2009 data, but treatment group assignment based on a 6-month window within the 2009 data or the 6 months prior to any event that occurred; 25% not assigned to warfarin group got warfarin prior to 2009
Humphries, 2001^98^ | Yes, for warfarin vs. no warfarin; dose information NR and no assessment of INRs except for people with bleeding events | Yes equal, but uncertain validity and reliability (relied on patient recall, and no mention of verification) | No | Yes | None | Complete data only; no handling of missing data | No, only adjusted for age | Poor | High risk of confounding and selection bias; prospective cohort study focused on comparing sex differences for presentation, treatment, and outcomes; only potentially eligible for our KQ 5 for the information on major bleeds; analysis only adjusted for age, unclear how many in each group were on aspirin, did not report baseline characteristics for warfarin vs. no warfarin groups; and participants had very few major bleeding events (15 total events); differential attrition NR for our comparison of interest
Kodani, 2016^99^ J-RHYTHM Registry 2 | No (analysis based on final status of use) | Yes | Unclear | Yes | None, excluded from analyses (15% excluded because of unknown OAC status; NR how much missing/ex-cluded for other reasons) | Yes | Adjusted for some potential confounders (CHA_2_DS_2_components and antiplatelet use) | Poor | High risk of selection bias and confounding; not an inception cohort, high likelihood of residual confounding and confounding by indication, exposure groups analyzed based on final exposure at end of observation period, not based on exposure at baseline or changes over time; inadequate handling of missing data; unclear masking.

Abbreviations: CHA_2_DS_2_-VASc=Congestive heart failure, Hypertension, Age ≥75 years [doubled], Diabetes mellitus, prior Stroke or TIA or thromboembolism [doubled], Vascular disease, Age 65-74 years, Sex category; INR=international normalized ratio; ITT=intent to treat; KQ=key question; NA=not applicable; NR=not reported; OAC=oral anticoagulant; TIA=transient ischemic attack.

Appendix D Table 6 Quality Assessment of Systematic Reviews, Network Meta-analyses, and IPD Meta-analyses (KQs 4, 5)

First Author, Year | Was the review based on a focused question of interest? | Was a comprehensive literature search (including grey literature) clearly described? | Were there explicit a priori inclusion/exclusion criteria for the selection of studies? | Did at least 2 people independently review studies? | Were the characteristics of the included studies provided? | Was the internal validity (quality) of included studies adequately assessed? | Was heterogeneity assessed and addressed? | Was the approach used to synthesize the information adequate and appropriate? | Were the authors’ conclusions supported by the evidence? | Was publication bias assessed? | Quality Rating
Aguilar Maria, 2005^100^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
Aguilar Maria, 2005^101^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
Coleman, 2012^102^ | Yes | Yes for published literature; no mention of grey literature | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes (some statistical tests reported, although not described in methods) | Fair
Atrial Fibrillation Investigators, 1994^103^ | Yes | No, but they identified all relevant known studies | Yes | NR | No | No | Yes (it is an IPD meta-analysis allowing greater assessment of heterogeneity) (e.g., analyses of women separated) | Yes | Yes | NR | Fair
Teresh-chenko, 2016^104^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
The Atrial Fibrillation Investigators, 1997^105^ | Yes | No, but they identified all relevant known studies | Yes | NR | Partially | No | Yes (it is an IPD meta-analysis allowing greater assessment of heterogeneity) (e.g., analyses of women separated) | Yes | Yes | NR | Fair
van Walraven, 2009^106^ | Yes | No, but they identified all relevant known studies (IPD analysis of data from a central database of clinical trials on patients with AF) | Yes | NR | Partially | No | Yes | Yes | Yes | NR | Fair
Hart, 2007^107^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good

Abbreviations: AF=atrial fibrillation; IPD=individual patient data; KQ=key question; NR=not reported.

Appendix D Table 7 Relevance of Systematic Reviews and Meta-Analyses for the Benefits and Harms of Anticoagulation or Antiplatelet Therapy (KQs 4, 5)

First Author, Year | Review type (IPD, aggregate data SR, NMA)? | Did the review meet our initial eligibility criteria? | Did the review focus only on studies of primary prevention (with no or few participants with history of stroke or TIA)? | Did the review include all relevant trials on aspirin? | Did the review include all relevant trials on warfarin? | If the review is an NMA, did it include the relevant trials for newer OACs? | Has the review been updated? | Was the review relevant and included in our current review? | Comments
Aguilar, 2009^100^ | SR with MA | Yes | Yes | NA | Yes | NA | No | Yes | Cochrane review. Focuses on patients without history of stroke or TIA and got unpublished results from the Atrial Fibrillation Investigators that removed the 3% to 8% of participants with prior TIA or stroke from the studies.
Aguilar, 2011^108^ | SR with MA | Yes | Yes | No, did not include JAST (JAST was not yet published) | NA | NA | No | Yes | Cochrane review. Focuses on patients without history of stroke or TIA and got unpublished results from the Atrial Fibrillation Investigators that removed the 6% of participants with prior TIA or stroke from the studies.
Assiri, 2013^109^ | NMA | Yes | No | Yes | No, did not include CAFA or BAATAF | No, did not include ENGAGE or JROCKET | No | No | Review excludes 2 warfarin trials and 2 trials of NOACs. Also combined studies of primary and secondary prevention.
Atrial Fibrillation Investigators, 1994^103^ | IPD | Yes | Yes | No, it did not include JAST or LASAF | Yes | NA | No | Yes | Used the Atrial Fibrillation Investigators database; used only the 5 warfarin trials (2 of those also included ASA)
Atrial Fibrillation Investigators, 1997^105^ | IPD | Yes | No, but it provides separate analyses in some places for the studies that were primary prevention | No, it did not include JAST or LASAF | NA | NA | No | Yes | Used the 3 ASA trials in Atrial Fibrillation Investigators database; 1 of those is secondary prevention (EAFT), but those data are not in all analyses in Tables 2 and 3 (and Table 4 provides data for patients with no clinical risk factors, one of which was prior stroke or TIA)
Cameron, 2014 ^110^ | NMA | Yes | Yes | No, it did not include LASAF or SPAF-1 | No, it did not include SPINAF, BAATAF, or SPAF-1 | No, did not include AVERROES or JROCKET | No | No | Review excluded 2 of the aspirin trials, 3 of the warfarin trials, and 2 of NOCAS
Coleman, 2012^102^ | SR with MA | Yes | No, combines primary prevention and secondary prevention studies; studies in the review were not selected because of history of stroke/TIA | No, it did not include SPAF-1 or LASAF (but those did not report MGIB) | No, it did not include SPAF-1 or CAFA (but those did not report MGIB) | NA | No | Yes | Combined studies of primary and secondary prevention (participants had a TIA or stroke) and does not provide any analyses separating them;^a^ possibly limiting applicability
Ezekowitz, 1999^111^ | IPD | Yes | No, included 1 secondary prevention trial (EAFT), 1 with over a third having previous stroke or TIA (SPAF3), and 1 with around 20% secondary prevention (NASPEAF) | No, it did not include JAST or LASAF | Yes | NA | No | No | Relevant data were presented in a previous publication. This just reiterates those findings.
Hart, 2007^112^ | SR with MA | Yes | No, but separated (primary vs. secondary prevention) results for absolute risk reduction of stroke | No, it did not include JAST | Yes | NA | Yes | No | Excluded, superseded by an updated publication
Hart, 2007^107^ | SR with MA | Yes | No, but separated (primary vs. secondary prevention) results for absolute risk reduction of stroke | Yes | Yes | NA | No (it is an update of a 1999 review)^112^ | Yes | Although the meta-analyses reporting relative reductions include both primary and secondary prevention studies, they stratify those for the absolute reduction data (in Tables 2 and 3)
Lapner, 2013^113^ | SR with MA | No | Yes | No, it did not include JAST, LASAF, SPAF-1, AFASAK-1 | No, it did not include SPINAF, CAFA, BAATAF, SPAF-1, AFASAK-1 | NA | No | No | Excluded for wrong comparator
Roskell, 2010^114^ | NMA | Yes | Yes | No, it did not include JAST or LASAF | No, it did not include SPINAF | No, published prior to ARISTOTLE, ENGAGE, ROCKET, and JROCKET | No | No | Excluded 2 of the aspirin trials, 1, of the warfarin trials, and 3 of the NOAC trials
Sahay, 2016^115^ | NMA | Yes | Yes | No, it did not include JAST or LASAF | No, it did not include SPINAF, CAFA, or BAATAF | No, it did not include AVERROES | No | No | Excluded 2 of the aspirin trials, 3 of the warfarin trials, and 1 NOAC trial
Sardar, 2014^116^ | SR and MA | No | Yes | No, it did not include JAST, LASAF, SPAF-1, or AFASAK-1 | No, it did not include SPINAF, CAFA, BAATAF, SPAF-1, or AFASAK-1 | NA | No | No | Wrong population; only placebo-controlled trials treated VTE
Tawfik, 2016^117^ | NMA | Yes | Yes | Yes | No, it did not include SPINAF or BAATAF | No, it did not include JROCKET | No | No | Review excluded 2 of the warfarin trials
Teresh-chenko, 2016^104^ | NMA | Yes | No, but most of the evidence is from trials focused mostly on primary prevention (4 of the 21 included trials had over 35% secondary prevention)^b^ | Yes (although ultimately excluded LASAF for poor quality) | Yes | Yes, all the newer relevant trials included (although this excluded phase II trials of NOACs) | No | Yes | Includes some contribution of data from people with a history of TIA or stroke. NOAC phase II studies were excluded.
van Walraven, 2009^106^ Atrial Fibrillation Investigators | IPD | Yes | No, included 1 secondary prevention trial (EAFT), 1 trial with over a third having previous stroke or TIA (SPAF3), and one with around 20% secondary prevention (NASPEAF) but sensitivity analyses provided serial exclusion of individual studies (and those did not alter estimates) | No, it did not include JAST or LASAF | Yes | NA | No | Yes | Used the Atrial Fibrillation Investigators database; included head-to-head studies and placebo-controlled

a One quarter studies in VKA meta-analysis, and one third in the aspirin meta-analysis were secondary prevention studies.

b The percentage of participants with a history of TIA or stroke was 100% in EAFT (VKA vs. aspirin vs. placebo), 64% in JROCKET (rivaroxaban vs. VKA), 55% in ROCKET AF (rivaroxaban vs. VKA), and 38% in SPAF III. It was <10% in 9 trials (AFASAK I, BAATAF, SPAF I, CAFA, SPAF II, AFASAK II, PATAF, SAFT, and JAST) and ranged from 13% to 28% in the other 8 included trials.

Abbreviations: AFASAK=Copenhagen Atrial Fibrillation, Aspirin and Anticoagulation study; ARISTOTLE=Apixaban for Reduction in Stroke and Other Thromboembolic Events in Atrial Fibrillation; ASA=aspirin; AVERROS=Apixaban Versus Acetylsalicylic Acid to Prevent Stroke in Atrial Fibrillation Patients Who Have Failed or Are Unsuitable for Vitamin K Antagonist Treatment; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; EAFT=European Atrial Fibrillation Trial Study Group; ENGAGE AF-TIMI=Effective Anticoagulation with Factor Xa Next Generation in Atrial Fibrillation - Thrombolysis in Myocardial Infarction 48; IPD=individual patient data; JAST=Japan Atrial Fibrillation Stroke Trial; JROCKET=Japanese Rivaroxaban Once Daily Oral Direct Factor Xa Inhibition Compared with Vitamin K Antagonism for Prevention of Stroke and Embolism Trial in Atrial Fibrillation; KQ=key question; LASAF=low-dose aspirin, stroke atrial fibrillation trial; MA=meta-analysis; MGIB=major gastrointestinal bleeding; NA=not applicable; NASPEAF=National Study for Prevention of Embolism in Atrial Fibrillation; NMA=network meta-analysis; NOAC=novel oral anticoagulant; OAC=oral anticoagulant; ROCKET AF=Rivaroxaban Once Daily Oral Direct Factor Xa Inhibition Compared with Vitamin K Antagonism for Prevention of Stroke and Embolism Trial in Atrial Fibrillation; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study; SR=systematic review; TIA=transient ischemic attack; VKA=vitamin K antagonist; VTE=venous thrombosis.