# Appendix C Excluded Studies

X1 Non-English
X2 Ineligible population
X3 Ineligible screening or treatment
X4 Ineligible or no comparator
X5 No relevant outcome reported
X6 Ineligible setting
X7 Ineligible study design
X8 Ineligible country
X9 Meets all criteria but abstract only
X10 Outdated publication superseded by more recent data
X11 Systematic Review that did not meet relevance criteria
X12 Poor quality rating

1 Cost-Effectiveness of antiarrhythmic drugs for prevention of thromboembolism in patients with paroxysmal atrial fibrillation. Jpn Circ J. 2001 Sep;65(9):765–8. PMID: 11548872. Exclusion Code: X3.11548872
2 Summaries for patients. What is the appropriate level of blood-thinning medication for elderly people with atrial fibrillation? Ann Intern Med. 2004 Nov 16;141(10):I38. PMID: 15545670. Exclusion Code: X7.15545670
3 Summaries for patients. Net benefit of warfarin in atrial fibrillation. Ann Intern Med. 2009 Sep 1;151(5):I36. PMID: 19721014. Exclusion Code: X7.19721014
4 Irbesartan did not reduce cardio events in atrial fibrillation patients. Australian Journal of Pharmacy. 2011;92(1095):83. PMID: CN-00893899. Exclusion Code: X7.
5 Aspirin and renal insufficiency progression in patients with atrial fibrillation and chronic kidney disease. International Journal of Cardiology. 223 (pp 619–624), 2016. Date of Publication: 15 Nov 2016. 2016doi: 10.1016/j.ijcard.2016.08.224. PMID: CN-01194146. Exclusion Code: X4.27565838
6 Risk of bleeding and thrombosis in patients 70 years or older using Vitamin K antagonists. JAMA Internal Medicine. 176 (8) (pp 1176–1183), 2016. Date of Publication: August 2016. 2016doi: 10.1001/jamainternmed.2016.3057. PMID: CN-01195175. Exclusion Code: X2.27379731
7 Adam SS, McDuffie JR, Ortel TL, . Comparative effectiveness of warfarin and new oral anticoagulants for the management of atrial fibrillation and venous thromboembolism: a systematic review (Structured abstract). Ann Intern Med. 2012;157(11):796–807. PMID: DARE-12012045713. Exclusion Code: X4.22928173
8 Agarwal S, Hachamovitch R, Menon V. Current trial-associated outcomes with warfarin in prevention of stroke in patients with nonvalvular atrial fibrillation: a meta-analysis (Structured abstract). Arch Intern Med. 2012;172(8):623–31. PMID: DARE-12012014674. Exclusion Code: X4.22450212
9 Aguilar Maria I, Hart R, Pearce Lesly A. Oral anticoagulants versus antiplatelet therapy for preventing stroke in patients with non-valvular atrial fibrillation and no history of stroke or transient ischemic attacks. Cochrane Database of Systematic Reviews. 2007(3)doi: 10.1002/14651858.CD006186.pub2. PMID: CD006186. Exclusion Code: X4.
10 Akao M, Chun YH, Esato M, . Inappropriate use of oral anticoagulants for patients with atrial fibrillation. Circ J. 2014;78(9):2166–72. PMID: 24976391. Exclusion Code: X4.24976391
11 Albertsen IE, Rasmussen LH, Overvad TF, . Risk of stroke or systemic embolism in atrial fibrillation patients treated with warfarin: a systematic review and meta-analysis. Stroke. 2013 May;44(5):1329–36. doi: 10.1161/strokeaha.113.000883. PMID: 23482597. Exclusion Code: X4.23482597
12 Alexander J, Andersson U, Lopes R, . Apixaban 5 mg twice daily and clinical outcomes in patients with atrial fibrillation and advanced age, low body weight, or high creatinine: a secondary analysis of a randomized clinical trial. JAMA cardiology. 2017;1(6):673–81. PMID: CN-01308892. Exclusion Code: X4.
13 Amin A, Boulanger L, Gatt E, . Exposure to warfarin and the risks of stroke and bleeding events among patients with non-valvular atrial fibrillation: Real-world vs. Clinical trial. Circ Cardiovasc Qual Outcomes. 2012;5(3 suppl. 1) PMID: CN-01023993. Exclusion Code: X7.
14 Amin A, Stokes M, Wu N, . Application of randomized clinical trial data to actual practice: apixaban therapy for reduction of stroke risk in non-valvular atrial fibrillation patients. Curr Med Res Opin. 2013 Oct;29(10):1253–61. doi: 10.1185/03007995.2013.818967. PMID: 23796193. Exclusion Code: X4.23796193
15 Angoulvant D, Villejoubert O, Bejan-Angoulvant T, . Effect of Active Smoking on Comparative Efficacy of Antithrombotic Therapy in Patients With Atrial Fibrillation: The Loire Valley Atrial Fibrillation Project. Chest. 2015 Aug;148(2):491–8. doi: 10.1378/chest.14-3006. PMID: 25812113. Exclusion Code: X4.25812113
16 Apenteng PN, Murray ET, Holder R, . An international longitudinal registry of patients with atrial fibrillation at risk of stroke (GARFIELD): the UK protocol. BMC Cardiovasc Disord. 2013;13:31. doi: 10.1186/1471-2261-13-31. PMID: 23617744. Exclusion Code: X5.23617744
17 Ashburner JM, Go AS, Reynolds K, . Comparison of frequency and outcome of major gastrointestinal hemorrhage in patients with atrial fibrillation on versus not receiving warfarin therapy (from the ATRIA and ATRIA-CVRN cohorts). Am J Cardiol. 2015 Jan 1;115(1):40–6. doi: 10.1016/j.amjcard.2014.10.006. PMID: 25456871. Exclusion Code: X4.25456871
18 Assiri A, Al-Majzoub O, Kanaan AO, . Mixed treatment comparison meta-analysis of aspirin, warfarin, and new anticoagulants for stroke prevention in patients with nonvalvular atrial fibrillation (Provisional abstract). Clin Ther. 2013;35(7):967–84.e2. PMID: DARE-12013042121. Exclusion Code: X11.23870607
19 Avgil Tsadok M, Jackevicius CA, Rahme E, . Sex differences in stroke risk among older patients with recently diagnosed atrial fibrillation. JAMA. 2012 May 9;307(18):1952–8. doi: 10.1001/jama.2012.3490. PMID: 22570463. Exclusion Code: X7.22570463
20 Azoulay L, Dell’Aniello S, Simon T, . The concurrent use of antithrombotic therapies and the risk of bleeding in patients with atrial fibrillation. Thromb Haemost. 2013 Mar;109(3):431–9. doi: 10.1160/th12-08-0542. PMID: 23306435. Exclusion Code: X7.23306435
21 Bai Y, Chen H, Yang Y, . Safety of antithrombotic drugs in patients with atrial fibrillation and non-end-stage chronic kidney disease: Meta-analysis and systematic review. Thromb Res. 2016 Jan;137:46–52. doi: 10.1016/j.thromres.2015.11.020. PMID: 26610746. Exclusion Code: X2.26610746
22 Bajorek BV, Krass I, Ogle SJ, . Optimizing the use of antithrombotic therapy for atrial fibrillation in older people: a pharmacist-led multidisciplinary intervention. J Am Geriatr Soc. 2005 Nov;53(11):1912–20. doi: 10.1111/j.1532-5415.2005.53564.x. PMID: 16274372. Exclusion Code: X3.16274372
23 Baker WL, Phung OJ. Systematic review and adjusted indirect comparison meta-analysis of oral anticoagulants in atrial fibrillation. Circ Cardiovasc Qual Outcomes. 2012 Sep 1;5(5):711–9. doi: 10.1161/circoutcomes.112.966572. PMID: 22912382. Exclusion Code: X4.22912382
24 Banerjee A, Clementy N, Haguenoer K, . Prior history of falls and risk of outcomes in atrial fibrillation: the Loire Valley Atrial Fibrillation Project. Am J Med. 2014 Oct;127(10):972–8. doi: 10.1016/j.amjmed.2014.05.035. PMID: 24929021. Exclusion Code: X4.24929021
25 Banerjee A, Fauchier L, Vourc’h P, . A prospective study of estimated glomerular filtration rate and outcomes in patients with atrial fibrillation: the Loire Valley Atrial Fibrillation Project. Chest. 2014 Jun;145(6):1370–82. doi: 10.1378/chest.13-2103. PMID: 24356875. Exclusion Code: X4.24356875
26 Barrios V, Escobar C, Calderon A, . Use of antithrombotic therapy according to CHA2DS2-VASc score in patients with atrial fibrillation in primary care. Rev Esp Cardiol (Engl Ed). 2014 Feb;67(2):150–1. doi: 10.1016/j.rec.2013.07.009. PMID: 24795129. Exclusion Code: X5.24795129
27 Baruch L, Gage BF, Horrow J, . Can patients at elevated risk of stroke treated with anticoagulants be further risk stratified? Stroke. 2007 Sep;38(9):2459–63. doi: 10.1161/strokeaha.106.477133. PMID: 17673721. Exclusion Code: X4.17673721
28 Bath PM, Prasad A, Brown MM, . Survey of use of anticoagulation in patients with atrial fibrillation. BMJ. 1993 Oct 23;307(6911):1045. PMID: 8166802. Exclusion Code: X7.8166802
29 Baxter J, Crabtree L, Hildreth A, . Atrial fibrillation. Lancet. 1998 Dec 5;352(9143):1858. doi: 10.1016/s0140-6736(05)79924-4. PMID: 9851411. Exclusion Code: X7.9851411
30 Benito L, Coll-Vinent B, Gómez E, . EARLY: a pilot study on early diagnosis of atrial fibrillation in a primary healthcare centre. Europace. 2015;17(11):1688–93. doi: 10.1093/europace/euv146. PMID: CN-01257576. Exclusion Code: X12.26071233
31 Biase L, Burkhardt JD, Santangeli P, . Silent thromboembolic lesions following catheter ablation for atrial fibrillation using radiofrequency energy: Results from a sub-study of the “compare” randomized trial. Circulation. 2013;128(22 suppl. 1) PMID: CN-01062460. Exclusion Code: X3.
32 Biondi-Zoccai G, Malavasi V, D’Ascenzo F, . Comparative effectiveness of novel oral anticoagulants for atrial fibrillation: evidence from pair-wise and warfarin-controlled network meta-analyses (Provisional abstract). HSR Proceedings in Intensive Care and Cardiovascular Anesthesia. 2013;5(1):40–54. PMID: DARE-12013029969. Exclusion Code: X4.23734288
33 Birman-Deych E, Radford MJ, Nilasena DS, . Use and effectiveness of warfarin in Medicare beneficiaries with atrial fibrillation. Stroke. 2006 Apr;37(4):1070–4. doi: 10.1161/01.STR.0000208294.46968.a4. PMID: 16528001. Exclusion Code: X7.16528001
34 Bjorck S, Palaszewski B, Friberg L, . Atrial fibrillation, stroke risk, and warfarin therapy revisited: a population-based study. Stroke. 2013 Nov;44(11):3103–8. doi: 10.1161/strokeaha.113.002329. PMID: 23982711. Exclusion Code: X7.23982711
35 Blin P, Dureau-Pournin C, Lassalle R, . A population database study of outcomes associated with Vitamin K antagonists in atrial fibrillation before DOAC. Br J Clin Pharmacol. 2016;81(3):569–78. doi: 10.1111/bcp.12807. PMID: CN-01137679. Exclusion Code: X7.26493768
36 Bo M, Li Puma F, Badinella Martini M, . Health status, geriatric syndromes and prescription of oral anticoagulant therapy in elderly medical in-patients with atrial fibrillation: a prospective observational study. Int J Cardiol. 2015;187:123–5. doi: 10.1016/j.ijcard.2015.03.334. PMID: 25828331. Exclusion Code: X4.25828331
37 Bo S, Valpreda S, Scaglione L, . Implementing hospital guidelines improves warfarin use in non-valvular atrial fibrillation: a before-after study. BMC Public Health. 2007;7:203. doi: 10.1186/1471-2458-7-203. PMID: 17692112. Exclusion Code: X3.17692112
38 Bonde AN, Lip GY, Kamper AL, . Net clinical benefit of antithrombotic therapy in patients with atrial fibrillation and chronic kidney disease: a nationwide observational cohort study. J Am Coll Cardiol. 2014 Dec 16;64(23):2471–82. doi: 10.1016/j.jacc.2014.09.051. PMID: 25500231. Exclusion Code: X7.25500231
39 Bonnet-Zamponi D, Aumont MC, Comets E, . Heparin bridging therapy and bleeding events in octogenarian inpatients with atrial fibrillation starting anticoagulation: results of an ancillary study. J Am Geriatr Soc. 2011 Nov;59(11):2174–8. doi: 10.1111/j.1532-5415.2011.03649.x. PMID: 22098039. Exclusion Code: X6.22098039
40 Bosch RF, Kirch W, Theuer JD, . Atrial fibrillation management, outcomes and predictors of stable disease in daily practice: prospective non-interventional study. Int J Cardiol. 2013 Aug 10;167(3):750–6. doi: 10.1016/j.ijcard.2012.03.053. PMID: 22475841. Exclusion Code: X5.22475841
41 Bover R, Perez-Gomez F, Maluenda MP, . Long-term follow-up of atrial fibrillation patients in the NASPEAF study. Prospective evaluation of different antiplatelet treatments. Rev Esp Cardiol. 2009 Sep;62(9):992–1000. PMID: 19712620. Exclusion Code: X4.19712620
42 Bruins Slot Karsten MH, Berge E. Factor Xa inhibitors versus vitamin K antagonists for preventing cerebral or systemic embolism in patients with atrial fibrillation. Cochrane Database of Systematic Reviews. 2013(8)doi: 10.1002/14651858.CD008980.pub2. PMID: CD008980. Exclusion Code: X4.
43 Burton CD, Hamilton KE, Isles CG, . Warfarin for nonvalvular atrial fibrillation in primary care-another example of the age paradox? J Cardiovasc Risk. 2001 Oct;8(5):307–9. PMID: 11702037. Exclusion Code: X3.11702037
44 Bury G, Swan D, Cullen W, . Screening for atrial fibrillation in general practice: a national, cross-sectional study of an innovative technology. Int J Cardiol. 2015 Jan 15;178:247–52. doi: 10.1016/j.ijcard.2014.10.037. PMID: 25464263. Exclusion Code: X4.25464263
45 Cadth. Dabigatran for stroke prevention in atrial fibrillation: a review of the evidence on safety (Structured abstract). Health Technology Assessment Database: Canadian Agency for Drugs and Technologies in Health (CADTH); 2012. Exclusion Code: X4.
46 Caldeira D, Barra M, Pinto FJ, . Intracranial hemorrhage risk with the new oral anticoagulants: a systematic review and meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):epub. PMID: DARE-12014051415. Exclusion Code: X4.
47 Caldeira D, Costa J, Fernandes RM, . Performance of the HAS-BLED high bleeding-risk category, compared to ATRIA and HEMORR2HAGES in patients with atrial fibrillation: a systematic review and meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):277–84. PMID: DARE-12014045687. Exclusion Code: X3.
48 Cameron C, Coyle D, Richter T, . Systematic review and network meta-analysis comparing antithrombotic agents for the prevention of stroke and major bleeding in patients with atrial fibrillation (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):e004301. PMID: DARE-12014036609. Exclusion Code: X11.
49 Capodanno D, Capranzano P, Giacchi G, . Novel oral anticoagulants versus warfarin in non-valvular atrial fibrillation: a meta-analysis of 50,578 patients (Provisional abstract). Int J Cardiol. 2013;167(4):1237–41. PMID: DARE-12013055125. Exclusion Code: X4.22494863
50 Caro JJ, Flegel KM, Orejuela ME, . Anticoagulant prophylaxis against stroke in atrial fibrillation: effectiveness in actual practice. CMAJ. 1999 Sep 7;161(5):493–7. PMID: 10497604. Exclusion Code: X12.10497604
51 Casciano JP, Dotiwala ZJ, Martin BC, . The costs of warfarin underuse and nonadherence in patients with atrial fibrillation: a commercial insurer perspective. J Manag Care Pharm. 2013 May;19(4):302–16. doi: 10.18553/jmcp.2013.19.4.302. PMID: 23627576. Exclusion Code: X7.23627576
52 Cha MJ, Oh GC, Hahn S, . Thromboembolic risk evaluation in patients with atrial fibrillation using a modified CHADS(2) scoring system. J Cardiovasc Electrophysiol. 2012 Feb;23(2):155–62. doi: 10.1111/j.1540-8167.2011.02181.x. PMID: 21955174. Exclusion Code: X4.21955174
53 Chan N-y, Choy C-c. Screening for atrial fibrillation in 13 122 Hong Kong citizens with smartphone electrocardiogram. Heart. 2016 October 12, 2016doi: 10.1136/heartjnl-2016-309993. Exclusion Code: X4.
54 Chatterjee S, Sardar P, Biondi-Zoccai G, . New oral anticoagulants and the risk of intracranial hemorrhage: traditional and Bayesian meta-analysis and mixed treatment comparison of randomized trials of new oral anticoagulants in atrial fibrillation (Provisional abstract). JAMA Neurology. 2013;70(12):1486–90. PMID: DARE-12013063998. Exclusion Code: X4.24166666
55 Chen T, Yang YM, Tan HQ, . Baseline characteristics and 1-year follow-up of Chinese atrial fibrillation patients according to age: a registry study. Pacing Clin Electrophysiol. 2014 Oct;37(10):1392–403. doi: 10.1111/pace.12443. PMID: 25039463. Exclusion Code: X4.25039463
56 Cheng HY. The association of warfarin use with osteoporotic fracture in elderly patients with atrial fibrillation. Arch Intern Med. 2006 Jul 24;166(14):1525; author reply doi: 10.1001/archinte.166.14.1525-a. PMID: 16864765. Exclusion Code: X7.16864765
57 Chishaki A, Kumagai N, Takahashi N, . Non-valvular atrial fibrillation patients with low CHADS2 scores benefit from warfarin therapy according to propensity score matching subanalysis using the J-RHYTHM Registry. Thromb Res. 2015 Aug;136(2):267–73. doi: 10.1016/j.thromres.2015.06.009. PMID: 26092429. Exclusion Code: X4.26092429
58 Christow S, Seidl K, Diener HC, . Increased rate of previous stroke in asymptomatic/minimally symptomatic versus symptomatic patients with newly detected atrial fibrillation in western Europe - results from the GLORIA-AF registry. EP Europace. 2017;19(suppl_3):iii355–iii6. doi: 10.1093/ehjci/eux159.005. Exclusion Code: X4.
59 Claes N, Van Laethem C, Goethals M, . Prevalence of atrial fibrillation in adults participating in a large-scale voluntary screening programme in Belgium. Acta Cardiol. 2012 Jun;67(3):273–8. doi: 10.2143/ac.67.3.2160714. PMID: 22870733. Exclusion Code: X5.22870733
60 Clemens A, Fraessdorf M, Friedman J. Cardiovascular outcomes during treatment with dabigatran: Comprehensive analysis of individual subject data by treatment. Vascular Health and Risk Management. 2013;9(1):599–615. doi: 10.2147/VHRM.S49830. PMID: CN-00979960. Exclusion Code: X4.24143109
61 Coleman CI, Straznitskas AD, Sobieraj DM, . Cost-effectiveness of clopidogrel plus aspirin for stroke prevention in patients with atrial fibrillation in whom warfarin is unsuitable. Am J Cardiol. 2012 Apr 1;109(7):1020–5. doi: 10.1016/j.amjcard.2011.11.034. PMID: 22221944. Exclusion Code: X4.22221944
62 Connolly BJ, Pearce LA, Kurth T, . Aspirin therapy and risk of subdural hematoma: meta-analysis of randomized clinical trials. J Stroke Cerebrovasc Dis. 2013 May;22(4):444–8. doi: 10.1016/j.jstrokecerebrovasdis.2013.01.007. PMID: 23422345. Exclusion Code: X2.23422345
63 Connolly SJ, Ezekowitz MD, Yusuf S, . Newly identified events in the RE-LY trial. N Engl J Med. 2010 Nov 04;363(19):1875–6. doi: 10.1056/NEJMc1007378. PMID: 21047252. Exclusion Code: X4.21047252
64 Connolly SJ, Pogue J, Hart RG, . Effect of clopidogrel added to aspirin in patients with atrial fibrillation. N Engl J Med. 2009 May 14;360(20):2066–78. doi: 10.1056/NEJMoa0901301. PMID: 19336502. Exclusion Code: X4.19336502
65 Connolly SJ, Wallentin L, Ezekowitz MD, . The Long-Term Multicenter Observational Study of Dabigatran Treatment in Patients With Atrial Fibrillation (RELY-ABLE) Study. Circulation. 2013 Jul 16;128(3):237–43. doi: 10.1161/circulationaha.112.001139. PMID: 23770747. Exclusion Code: X4.23770747
66 Cullen MW, Kim S, Piccini JP, Sr., . Risks and benefits of anticoagulation in atrial fibrillation: insights from the Outcomes Registry for Better Informed Treatment of Atrial Fibrillation (ORBIT-AF) registry. Circ Cardiovasc Qual Outcomes. 2013 Jul;6(4):461–9. doi: 10.1161/circoutcomes.113.000127. PMID: 23759473. Exclusion Code: X7.23759473
67 Daacke IM. Systematic review and critical appraisal of the statistical methods used in published studies to indirectly compare novel anticoagulants (NOACS) with warfarin for the prevention of stroke in patients with atrial fibrillation (AF). Value Health. 2014;17(7):A579. doi: 10.1016/j.jval.2014.08.1958. PMID: CN-01023379. Exclusion Code: X4.
68 Dagres N, Nieuwlaat R, Vardas PE, . Gender-related differences in presentation, treatment, and outcome of patients with atrial fibrillation in Europe: a report from the Euro Heart Survey on Atrial Fibrillation. J Am Coll Cardiol. 2007 Feb 6;49(5):572–7. doi: 10.1016/j.jacc.2006.10.047. PMID: 17276181. Exclusion Code: X3.17276181
69 Darkow T, Vanderplas AM, Lew KH, . Treatment patterns and real-world effectiveness of warfarin in nonvalvular atrial fibrillation within a managed care system. Curr Med Res Opin. 2005 Oct;21(10):1583–94. doi: 10.1185/030079905x61956. PMID: 16238898. Exclusion Code: X7.16238898
70 Das AK, Willcoxson PD, Corrado OJ, . The impact of long-term warfarin on the quality of life of elderly people with atrial fibrillation. Age Ageing. 2007 Jan;36(1):95–7. doi: 10.1093/ageing/afl062. PMID: 16799180. Exclusion Code: X4.16799180
71 De Ruijter W, Assendelft WJ, Macfarlane PW, . The additional value of routine electrocardiograms in cardiovascular risk management of older people. Scand J Prim Health Care. 2008;26(3):147–53. doi: 10.1080/02813430802095812. PMID: 18609253. Exclusion Code: X4.18609253
72 Dentali F, Riva N, Crowther M, . Efficacy and safety of the novel oral anticoagulants in atrial fibrillation: a systematic review and meta-analysis of the literature. Circulation. 2012 Nov 13;126(20):2381–91. doi: 10.1161/circulationaha.112.115410. PMID: 23071159. Exclusion Code: X4.23071159
73 DeSilvey DL. Risk of anticoagulation for atrial fibrillation in the elderly. Am J Geriatr Cardiol. 2007 Sep–Oct;16(5):325–6. PMID: 17786064. Exclusion Code: X7.17786064
74 Dewhurst MJ, Adams PC, Gray WK, . Strikingly low prevalence of atrial fibrillation in elderly Tanzanians. J Am Geriatr Soc. 2012 Jun;60(6):1135–40. doi: 10.1111/j.1532-5415.2012.03963.x. PMID: 22646732. Exclusion Code: X7.22646732
75 Di Biase L, Burkhardt JD, Mohanty P, . Periprocedural stroke and management of major bleeding complications in patients undergoing catheter ablation of atrial fibrillation: the impact of periprocedural therapeutic international normalized ratio. Circulation. 2010 Jun 5;121(23):2550–6. doi: 10.1161/circulationaha.109.921320. PMID: 20516376. Exclusion Code: X6.20516376
76 Diederichsen S, Haugan K, Kober L, . Atrial fibrillation detected by continuous electrocardiographic monitoring using implantable loop recorder to prevent stroke in individuals at risk (the LOOP study): rationale and design of a large randomized controlled trial. Am Heart J. 2017;187:122–32. doi: 10.1016/j.ahj.2017.02.017. PMID: CN-01337357. Exclusion Code: X3.28454796
77 DiMarco JP, Flaker G, Waldo AL, . Factors affecting bleeding risk during anticoagulant therapy in patients with atrial fibrillation: observations from the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Am Heart J. 2005 Apr;149(4):650–6. doi: 10.1016/j.ahj.2004.11.015. PMID: 15990748. Exclusion Code: X3.15990748
78 Dogliotti A, Paolasso E, Giugliano RP. Novel oral anticoagulants in atrial fibrillation: a meta-analysis of large, randomized, controlled trials vs warfarin (Structured abstract). Clin Cardiol. 2013;36(2):61–7. PMID: DARE-12013014937. Exclusion Code: X4.23338902
79 Donze J, Clair C, Hug B, . Risk of falls and major bleeds in patients on oral anticoagulation therapy. Am J Med. 2012 Aug;125(8):773–8. doi: 10.1016/j.amjmed.2012.01.033. PMID: 22840664. Exclusion Code: X4.22840664
80 Duygu H, Barisik V, Kurt H, . Prognostic value of plasma soluble CD40 ligand in patients with chronic non-valvular atrial fibrillation. Europace. 2008 Feb;10(2):210–4. doi: 10.1093/europace/eum284. PMID: 18184662. Exclusion Code: X4.18184662
81 Echeto Garcia A, Bayon Yusta JC, Gardeazabal Romillo MJ, . Systematic review of the pharmacoeconomic evidence of dabigatran for stroke prevention in patients with nonvalvular atrial fibrillation (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):25–37. PMID: DARE-12014055285. Exclusion Code: X1.
82 Edvardsson N, Juul-Moller S, Omblus R, . Effects of low-dose warfarin and aspirin versus no treatment on stroke in a medium-risk patient population with atrial fibrillation. J Intern Med. 2003 Jul;254(1):95–101. PMID: 12823646. Exclusion Code: X3.12823646
83 Edwards SJ, Hamilton V, Nherera L, . A mixed treatment comparison (MTC) to compare the efficacy of anti-thrombotic agents in the prevention of stroke and systemic embolism (SE) in patients with non-valvular atrial fibrillation (NVAF). Value Health. 2012;15(7):A363. doi: 10.1016/j.jval.2012.08.950. PMID: CN-01004208. Exclusion Code: X4.
84 Ellis M, Avnery O, Derazne E, . Bleeding in patients with atrial fibrillation treated with different doses of direct oral anticoagulants and vitamin K antagonists: a population-based study. Blood. Conference: 58th annual meeting of the american society of hematology, ASH 2016. United states. Conference start: 20161203. Conference end: 20161206. 2017;128(22) (no pagination) PMID: CN-01335074. Exclusion Code: X4.
85 Engdahl J, Andersson L, Mirskaya M, . Stepwise screening of atrial fibrillation in a 75-year-old population: implications for stroke prevention. Circulation. 2013 Feb 6;127(8):930–7. doi: 10.1161/circulationaha.112.126656. PMID: 23343564. Exclusion Code: X4.23343564
86 Ertas F, Eren NK, Kaya H, . The atrial fibrillation in Turkey: Epidemiologic Registry (AFTER). Cardiol J. 2013;20(4):447–52. doi: 10.5603/CJ.a2013.0055. PMID: 23677730. Exclusion Code: X5.23677730
87 Evans A, Kalra L. Are the results of randomized controlled trials on anticoagulation in patients with atrial fibrillation generalizable to clinical practice? Arch Intern Med. 2001 Jun 1;161(11):1443–7. PMID: 11386894. Exclusion Code: X7.11386894
88 Ezekowitz MD, James KE, Nazarian SM, . Silent cerebral infarction in patients with nonrheumatic atrial fibrillation. The Veterans Affairs Stroke Prevention in Nonrheumatic Atrial Fibrillation Investigators. Circulation. 1995 Oct 5;92(8):2178–82. PMID: 7554199. Exclusion Code: X5.7554199
89 Ezekowitz MD, Levine JA. Preventing stroke in patients with atrial fibrillation. JAMA. 1999 May 9;281(19):1830–5. PMID: 10340371. Exclusion Code: X7.10340371
90 Fang MC, Go AS, Chang Y, . Thirty-day mortality after ischemic stroke and intracranial hemorrhage in patients with atrial fibrillation on and off anticoagulants. Stroke. 2012 Jul;43(7):1795–9. doi: 10.1161/strokeaha.111.630731. PMID: 22539546. Exclusion Code: X2.22539546
91 Fang MC, Go AS, Hylek EM, . Age and the risk of warfarin-associated hemorrhage: the anticoagulation and risk factors in atrial fibrillation study. J Am Geriatr Soc. 2006 Aug;54(8):1231–6. doi: 10.1111/j.1532-5415.2006.00828.x. PMID: 16913990. Exclusion Code: X7.16913990
92 Fang MC, Singer DE, Chang Y, . Gender differences in the risk of ischemic stroke and peripheral embolism in atrial fibrillation: the AnTicoagulation and Risk factors In Atrial fibrillation (ATRIA) study. Circulation. 2005 Sep 0;112(12):1687–91. doi: 10.1161/circulationaha.105.553438. PMID: 16157766. Exclusion Code: X4.16157766
93 Farmakis D, Pipilis A, Antoniou A, . Clinical profile and therapeutic management of patients with atrial fibrillation in Greece: results from the Registry of Atrial Fibrillation to Investigate New Guidelines (RAFTING). Hellenic J Cardiol. 2013 Sep–Oct;54(5):368–75. PMID: 24100180. Exclusion Code: X5.24100180
94 Fauchier L, Clementy N, Saint-Etienne C, . Efficacy of new oral anticoagulants in patients with atrial fibrillation previously treated with warfarin: a meta-analysis of randomized controlled trials (Provisional abstract). Int J Cardiol. 2014;173(1):122–4. PMID: DARE-12014021030. Exclusion Code: X4.24636544
95 Fauchier L, Lecoq C, Clementy N, . Oral Anticoagulation and the Risk of Stroke or Death in Patients With Atrial Fibrillation and One Additional Stroke Risk Factor: The Loire Valley Atrial Fibrillation Project. Chest. 2016 Apr;149(4):960–8. doi: 10.1378/chest.15-1622. PMID: 26425935. Exclusion Code: X5.26425935
96 Flaker GC, Belew K, Beckman K, . Asymptomatic atrial fibrillation: demographic features and prognostic information from the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Am Heart J. 2005 Apr;149(4):657–63. doi: 10.1016/j.ahj.2004.06.032. PMID: 15990749. Exclusion Code: X3.15990749
97 Forslund T, Wettermark B, Wandell P, . Risks for stroke and bleeding with warfarin or aspirin treatment in patients with atrial fibrillation at different CHA(2)DS(2)VASc scores: experience from the Stockholm region. Eur J Clin Pharmacol. 2014 Dec;70(12):1477–85. doi: 10.1007/s00228-014-1739-1. PMID: 25219360. Exclusion Code: X12.25219360
98 Fosbol EL, Holmes DN, Piccini JP, . Provider specialty and atrial fibrillation treatment strategies in United States community practice: findings from the ORBIT-AF registry. J Am Heart Assoc. 2013 Aug;2(4):e000110. doi: 10.1161/jaha.113.000110. PMID: 23868192. Exclusion Code: X7.23868192
99 Freedman B, Camm J, Calkins H, . Screening for Atrial Fibrillation: A Report of the AF-SCREEN International Collaboration. Circulation. 2017 May 9;135(19):1851–67. doi: 10.1161/circulationaha.116.026693. PMID: 28483832. Exclusion Code: X7.28483832
100 Frewen J, Finucane C, Cronin H, . Factors that influence awareness and treatment of atrial fibrillation in older adults. QJM. 2013 May;106(5):415–24. doi: 10.1093/qjmed/hct060. PMID: 23504411. Exclusion Code: X4.23504411
101 Friberg L, Engdahl J, Frykman V, . Population screening of 75- and 76-year-old men and women for silent atrial fibrillation (STROKESTOP). Europace. 2013 Jan;15(1):135–40. doi: 10.1093/europace/eus217. PMID: 22791299. Exclusion Code: X5.22791299
102 Friberg L, Hammar N, Pettersson H, . Increased mortality in paroxysmal atrial fibrillation: report from the Stockholm Cohort-Study of Atrial Fibrillation (SCAF). Eur Heart J. 2007 Oct;28(19):2346–53. doi: 10.1093/eurheartj/ehm308. PMID: 17670754. Exclusion Code: X5.17670754
103 Friberg L, Hammar N, Rosenqvist M. Stroke in paroxysmal atrial fibrillation: report from the Stockholm Cohort of Atrial Fibrillation. Eur Heart J. 2010 Apr;31(8):967–75. doi: 10.1093/eurheartj/ehn599. PMID: 19176537. Exclusion Code: X4.19176537
104 Friberg L, Rosenqvist M, Lip GY. Net clinical benefit of warfarin in patients with atrial fibrillation: a report from the Swedish atrial fibrillation cohort study. Circulation. 2012 May 5;125(19):2298–307. doi: 10.1161/circulationaha.111.055079. PMID: 22514252. Exclusion Code: X4.22514252
105 Friberg L, Rosenqvist M, Lip GY. Evaluation of risk stratification schemes for ischaemic stroke and bleeding in 182 678 patients with atrial fibrillation: the Swedish Atrial Fibrillation cohort study. Eur Heart J. 2012 Jun;33(12):1500–10. doi: 10.1093/eurheartj/ehr488. PMID: 22246443. Exclusion Code: X4.22246443
106 Frost L, Johnsen SP, Pedersen L, . Atrial fibrillation or flutter and stroke: a Danish population-based study of the effectiveness of oral anticoagulation in clinical practice. J Intern Med. 2002 Jul;252(1):64–9. PMID: 12074740. Exclusion Code: X7.12074740
107 Fu W, Guo H, Guo J, . Relative efficacy and safety of direct oral anticoagulants in patients with atrial fibrillation by network meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):873–9. PMID: DARE-12014063328. Exclusion Code: X4.
108 Gage BF, van Walraven C, Pearce L, . Selecting patients with atrial fibrillation for anticoagulation: stroke risk stratification in patients taking aspirin. Circulation. 2004 Oct 9;110(16):2287–92. doi: 10.1161/01.cir.0000145172.55640.93. PMID: 15477396. Exclusion Code: X3.15477396
109 Gallagher AM, Setakis E, Plumb JM, . Risks of stroke and mortality associated with suboptimal anticoagulation in atrial fibrillation patients. Thromb Haemost. 2011;106(5):968–77. doi: 10.1160/TH11-05-0353. PMID: CN-00889921. Exclusion Code: X4.21901239
110 Gallagher AM, van Staa TP, Murray-Thomas T, . Population-based cohort study of warfarin-treated patients with atrial fibrillation: incidence of cardiovascular and bleeding outcomes. BMJ Open. 2014;4(1):e003839. doi: 10.1136/bmjopen-2013-003839. PMID: 24468720. Exclusion Code: X7.24468720
111 Gamst J, Christiansen CF, Rasmussen BS, . Pre-existing atrial fibrillation and risk of arterial thromboembolism and death following pneumonia: a population-based cohort study. BMJ Open. 2014;4(11):e006486. doi: 10.1136/bmjopen-2014-006486. PMID: 25398678. Exclusion Code: X7.25398678
112 Ganjehei L, Wilson JM. Anticoagulants for stroke prevention in nonvalvular atrial fibrillation: New agents and an updated understanding. Tex Heart Inst J. 2012;39(4):517–25. PMID: CN-01004668. Exclusion Code: X7.22949768
113 Ghate SR, Biskupiak J, Ye X, . All-cause and bleeding-related health care costs in warfarin-treated patients with atrial fibrillation. J Manag Care Pharm. 2011 Nov;17(9):672–84. doi: 10.18553/jmcp.2011.17.9.672. PMID: 22050392. Exclusion Code: X7.22050392
114 Go AS, Hylek EM, Chang Y, . Anticoagulation therapy for stroke prevention in atrial fibrillation: how well do randomized trials translate into clinical practice? JAMA. 2003 Nov 6;290(20):2685–92. doi: 10.1001/jama.290.20.2685. PMID: 14645310. Exclusion Code: X4.14645310
115 Gold JA. Warfarin encouraged for stroke prevention in atrial fibrillation. Wis Med J. 1996 Jan;95(1):42–3. PMID: 8650954. Exclusion Code: X5.8650954
116 Gomes T, Mamdani MM, Holbrook AM, . Rates of hemorrhage during warfarin therapy for atrial fibrillation. CMAJ. 2013 Feb 5;185(2):E121–7. doi: 10.1503/cmaj.121218. PMID: 23184840. Exclusion Code: X4.23184840
117 Gomes T, Mamdani MM, Holbrook AM, . Persistence with therapy among patients treated with warfarin for atrial fibrillation. Arch Intern Med. 2012 Nov 6;172(21):1687–9. doi: 10.1001/archinternmed.2012.4485. PMID: 23090098. Exclusion Code: X4.23090098
118 Gomez-Outes A, Lagunar-Ruiz J, Terleira-Fernandez A-I, . Causes of Death in Anticoagulated Patients With Atrial Fibrillation. J Am Coll Cardiol. 2017;68(23):2508–21. doi: 10.1016/j.jacc.2016.09.944. PMID: CN-01301532. Exclusion Code: X4.
119 Gomez-Outes A, Terleira-Fernandez AI, Calvo-Rojas G, . Dabigatran, rivaroxaban, or apixaban versus warfarin in patients with nonvalvular atrial fibrillation: a systematic review and meta-analysis of subgroups (Provisional abstract). Thrombosis. 2013;2013(2):640723. PMID: DARE-12014008211. Exclusion Code: X4.24455237
120 González Blanco V, Pérula de Torres LÁ, Martín Rioboó E, . Opportunistic screening for atrial fibrillation versus detecting symptomatic patients aged 65 years and older: A cluster-controlled clinical trial. Med Clin (Barc). 2017 1/6/;148(1):8–15. doi: http://dx.doi.org/10.1016/j.medcli.2016.07.036. Exclusion Code: X2.28196583
121 Gonzalez-Juanatey JR, Alvarez-Sabin J, Lobos JM, . Cost-effectiveness of dabigatran for stroke prevention in non-valvular atrial fibrillation in Spain. Rev Esp Cardiol (Engl Ed). 2012 Oct;65(10):901–10. doi: 10.1016/j.recesp.2012.06.006. PMID: 22958943. Exclusion Code: X7.22958943
122 Gorin L, Fauchier L, Nonin E, . Antithrombotic treatment and the risk of death and stroke in patients with atrial fibrillation and a CHADS2 score=1. Thromb Haemost. 2010 Apr;103(4):833–40. doi: 10.1160/th09-10-0746. PMID: 20135077. Exclusion Code: X7.20135077
123 Gorzelak P, Zyzak S, Krewko, . [Frequency of use of oral vitamin K antagonists in patients with atrial fibrillation and cognitive function disturbances]. Polski merkuriusz lekarski: organ Polskiego Towarzystwa Lekarskiego. 2014;36(215):302–6. PMID: CN-00999004. Exclusion Code: X1.24964505
124 Goto S, Bhatt DL, Rother J, . Prevalence, clinical profile, and cardiovascular outcomes of atrial fibrillation patients with atherothrombosis. Am Heart J. 2008 Nov;156(5):855–63, 63.e2. doi: 10.1016/j.ahj.2008.06.029. PMID: 19061698. Exclusion Code: X4.19061698
125 Granziera S, Nante G, Manzato E, . Prescription of vitamin K inhibitors in low-risk patients with atrial fibrillation. J Thromb Thrombolysis. 2011 May;31(4):501–2. doi: 10.1007/s11239-010-0518-9. PMID: 20865300. Exclusion Code: X4.20865300
126 Greenhalgh J, Bagust A, Boland A, . Clopidogrel and modified-release dipyridamole for the prevention of occlusive vascular events (review of technology appraisal no.90): a systematic review and economic analysis (Structured abstract). Health Technol Assess. 2011;15(31):1–178. PMID: DARE-12011006378. Exclusion Code: X2.
127 Guo Y, Pisters R, Apostolakis S, . Stroke risk and suboptimal thromboprophylaxis in Chinese patients with atrial fibrillation: would the novel oral anticoagulants have an impact? Int J Cardiol. 2013 Sep 0;168(1):515–22. doi: 10.1016/j.ijcard.2012.09.187. PMID: 23103146. Exclusion Code: X8.23103146
128 Guo Y, Wang H, Tian Y, . Time Trends of Aspirin and Warfarin Use on Stroke and Bleeding Events in Chinese Patients With New-Onset Atrial Fibrillation. Chest. 2015 Jul;148(1):62–72. doi: 10.1378/chest.14-2018. PMID: 25501045. Exclusion Code: X7.25501045
129 Gupta D, Giugliano R, Ruff C, . The Prognostic Significance of Cardiac Structure and Function in Atrial Fibrillation: The ENGAGE AF-TIMI 48 Echocardiographic Substudy. J Am Soc Echocardiogr. 2016;29(6):537–44. doi: 10.1016/j.echo.2016.03.004. PMID: CN-01158351. Exclusion Code: X2.27106009
130 Hannon N, Callaly E, Moore A, . Improved late survival and disability after stroke with therapeutic anticoagulation for atrial fibrillation: a population study. Stroke. 2011 Sep;42(9):2503–8. doi: 10.1161/strokeaha.110.602235. PMID: 21778447. Exclusion Code: X2.21778447
131 Hanon O, Vidal JS, Pisica-Donose G, . Therapeutic management in ambulatory elderly patients with atrial fibrillation: the S.AGES cohort. J Nutr Health Aging. 2015 Feb;19(2):219–27. doi: 10.1007/s12603-015-0444-9. PMID: 25651449. Exclusion Code: X5.25651449
132 Hansen ML, Sorensen R, Clausen MT, . Risk of bleeding with single, dual, or triple therapy with warfarin, aspirin, and clopidogrel in patients with atrial fibrillation. Arch Intern Med. 2010 Sep 3;170(16):1433–41. doi: 10.1001/archinternmed.2010.271. PMID: 20837828. Exclusion Code: X4.20837828
133 Harenberg J, Marx S, Diener HC, . Comparison of efficacy and safety of dabigatran, rivaroxaban and apixaban in patients with atrial fibrillation using network meta-analysis. Int Angiol. 2012 Aug;31(4):330–9. PMID: 22801398. Exclusion Code: X4.22801398
134 Hart RG, Benavente O, McBride R, . Antithrombotic therapy to prevent stroke in patients with atrial fibrillation: a meta-analysis. Ann Intern Med. 1999 Oct 5;131(7):492–501. PMID: 10507957. Exclusion Code: X10.10507957
135 Hart RG, Diener HC, Yang S, . Intracranial hemorrhage in atrial fibrillation patients during anticoagulation with warfarin or dabigatran: the RE-LY trial. Stroke. 2012 Jun;43(6):1511–7. doi: 10.1161/strokeaha.112.650614. PMID: 22492518. Exclusion Code: X7.22492518
136 Hart RG, Pearce LA, Miller VT, . Cardioembolic vs. noncardioembolic strokes in atrial fibrillation: frequency and effect of antithrombotic agents in the stroke prevention in atrial fibrillation studies. Cerebrovasc Dis. 2000 Jan-Feb;10(1):39–43. . PMID: 10629345. Exclusion Code: X4.10629345
137 Healey JS, Crystal E, Lamy A, . Left Atrial Appendage Occlusion Study (LAAOS): results of a randomized controlled pilot study of left atrial appendage occlusion during coronary bypass surgery in patients at risk for stroke. Am Heart J. 2005 Aug;150(2):288–93. doi: 10.1016/j.ahj.2004.09.054. PMID: 16086933. Exclusion Code: X3.16086933
138 Heidinger KS, Bernardo A, Taborski U, . Clinical outcome of self-management of oral anticoagulation in patients with atrial fibrillation or deep vein thrombosis. Thromb Res. 2000 May 5;98(4):287–93. PMID: 10822075. Exclusion Code: X3.10822075
139 Hendriks JM, Stromberg A. Integrated nurse-led oral anticoagulation management. Kardiovaskulare Medizin. 2015;18(1):9–15. PMID: CN-01084188. Exclusion Code: X3.
140 Ho CW, Ho MH, Chan PH, . Ischemic stroke and intracranial hemorrhage with aspirin, dabigatran, and warfarin: impact of quality of anticoagulation control. Stroke. 2015 Jan;46(1):23–30. doi: 10.1161/strokeaha.114.006476. PMID: 25406148. Exclusion Code: X7.25406148
141 Ho LY, Siu CW, Yue WS, . Safety and efficacy of oral anticoagulation therapy in Chinese patients with concomitant atrial fibrillation and hypertension. J Hum Hypertens. 2011 May;25(5):304–10. doi: 10.1038/jhh.2010.57. PMID: 20596062. Exclusion Code: X4.20596062
142 Hohnloser S, Yusuf S, Eikelboom J, . Apixaban in patients with atrial fibrillation and their risk for cardiovascular hospitalization: insights from the AVERROES trial. Eur Heart J. 2011;32 (Abstract Supplement)(671):Abstract 3904. PMID: CN-00872660. Exclusion Code: X4.
143 Hollerl F, Stollberger C, Finsterer J. Renal function, P-gp-affecting drugs and new anticoagulants for stroke prevention. Int J Cardiol. 2013 Sep 0;168(1):576–7. doi: 10.1016/j.ijcard.2013.01.013. PMID: 23394894. Exclusion Code: X7.23394894
144 Holster IL, Valkhoff VE, Kuipers EJ, . New oral anticoagulants increase risk for gastrointestinal bleeding: a systematic review and meta-analysis. Gastroenterology. 2013 Jul;145(1):105–12.e15. doi: 10.1053/j.gastro.2013.02.041. PMID: 23470618. Exclusion Code: X4.23470618
145 Huang B, Yang Y, Zhu J, . Clinical characteristics and prognostic significance of chronic obstructive pulmonary disease in patients with atrial fibrillation: results from a multicenter atrial fibrillation registry study. J Am Med Dir Assoc. 2014 Aug;15(8):576–81. doi: 10.1016/j.jamda.2014.04.009. PMID: 24894999. Exclusion Code: X4.24894999
146 Humphries KH, Kerr CR, Connolly SJ, . New-onset atrial fibrillation: sex differences in presentation, treatment, and outcome. Circulation. 2001 May 5;103(19):2365–70. PMID: 11352885. Exclusion Code: X12.11352885
147 Hunter RJ, McCready J, Diab I, . Maintenance of sinus rhythm with an ablation strategy in patients with atrial fibrillation is associated with a lower risk of stroke and death. Heart. 2012 Jan;98(1):48–53. doi: 10.1136/heartjnl-2011-300720. PMID: 21930724. Exclusion Code: X3.21930724
148 Hurley V, Ireson R, Fletcher K, . A cross-sectional study of hypertension in an elderly population (75 years and over) with atrial fibrillation: secondary analysis of data from the Birmingham Atrial Fibrillation in the Aged (BAFTA) randomised controlled trial. Int J Cardiol. 2007 Apr 5;117(2):152–6. doi: 10.1016/j.ijcard.2006.04.061. PMID: 16887213. Exclusion Code: X3.16887213
149 Hussain A, Cox JG. Anticoagulation for nonrheumatic atrial fibrillation: the dilemma. Stroke. 1995 Jan;26(1):138. PMID: 7839385. Exclusion Code: X7.7839385
150 Hylek EM, Evans-Molina C, Shea C, . Major hemorrhage and tolerability of warfarin in the first year of therapy among elderly patients with atrial fibrillation. Circulation. 2007 May 9;115(21):2689–96. doi: 10.1161/circulationaha.106.653048. PMID: 17515465. Exclusion Code: X4.17515465
151 Ikeda T, Atarashi H, Inoue H, . Study Design and Baseline Characteristics of the EXPAND Study: Evaluation of Effectiveness and Safety of Xa Inhibitor, Rivaroxaban for the Prevention of Stroke and Systemic Embolism in a Nationwide Cohort of Japanese Patients Diagnosed as Non-Valvular Atrial Fibrillation. Tohoku J Exp Med. 2016;240(4):259–68. doi: 10.1620/tjem.240.259. PMID: 27904005. Exclusion Code: X5.27904005
152 Imbert P, Pernod G, Jacquet JP, . Evaluation of a mobile electronic assistant to aid in fluindione prescription: the INRPlus cluster randomized trial. Thromb Res. 2014;133(5):756–61. doi: 10.1016/j.thromres.2014.02.003. PMID: CN-00988586. Exclusion Code: X3.24582071
153 Inoue H, Atarashi H, Okumura K, . Impact of gender on the prognosis of patients with nonvalvular atrial fibrillation. Am J Cardiol. 2014 Mar 5;113(6):957–62. doi: 10.1016/j.amjcard.2013.11.057. PMID: 24461771. Exclusion Code: X4.24461771
154 Inoue H, Nozawa T, Hirai T, . Accumulation of risk factors increases risk of thromboembolic events in patients with nonvalvular atrial fibrillation. Circ J. 2006 Jun;70(6):651–6. PMID: 16723782. Exclusion Code: X7.16723782
155 Inoue H, Okumura K, Atarashi H, . Target international normalized ratio values for preventing thromboembolic and hemorrhagic events in Japanese patients with non-valvular atrial fibrillation: results of the J-RHYTHM Registry. Circ J. 2013;77(9):2264–70. PMID: 23708863. Exclusion Code: X4.23708863
156 Jacobs LG. The sin of omission: a systematic review of antithrombotic therapy to prevent stroke in atrial fibrillation. J Am Geriatr Soc. 2001 Jan;49(1):91–4. PMID: 11207849. Exclusion Code: X7.11207849
157 Jahangir A, Lee V, Friedman PA, . Long-term progression and outcomes with aging in patients with lone atrial fibrillation: a 30-year follow-up study. Circulation. 2007 Jun 9;115(24):3050–6. doi: 10.1161/circulationaha.106.644484. PMID: 17548732. Exclusion Code: X4.17548732
158 Johnson BJ, Urrutia V. Stroke Risk Factor Screening in an Inner City Public Market- A Description of the Population-A Better Target for Screening/Education Efforts. Stroke. 2010;41(4):E205–E. Exclusion Code: X3.
159 Kaasenbrood F, Hollander M, Rutten FH, . Yield of screening for atrial fibrillation in primary care with a hand-held, single-lead electrocardiogram device during influenza vaccination. Europace. 2016 Oct;18(10):1514–20. doi: 10.1093/europace/euv426. PMID: 26851813. Exclusion Code: X4.26851813
160 Kagansky N, Knobler H, Rimon E, . Safety of anticoagulation therapy in well-informed older patients. Arch Intern Med. 2004 Oct 1;164(18):2044–50. doi: 10.1001/archinte.164.18.2044. PMID: 15477441. Exclusion Code: X6.15477441
161 Kakkar AK, Mueller I, Bassand JP, . Risk profiles and antithrombotic treatment of patients newly diagnosed with atrial fibrillation at risk of stroke: perspectives from the international, observational, prospective GARFIELD registry. PLoS One. 2013;8(5):e63479. doi: 10.1371/journal.pone.0063479. PMID: 23704912. Exclusion Code: X5.23704912
162 Kamel H, Easton JD, Johnston SC, . Cost-effectiveness of apixaban vs warfarin for secondary stroke prevention in atrial fibrillation. Neurology. 2012 Oct 2;79(14):1428–34. doi: 10.1212/WNL.0b013e31826d5fe8. PMID: 22993279. Exclusion Code: X2.22993279
163 Kansal AR, Sorensen SV, Gani R, . Cost-effectiveness of dabigatran etexilate for the prevention of stroke and systemic embolism in UK patients with atrial fibrillation. Heart. 2012 Apr;98(7):573–8. doi: 10.1136/heartjnl-2011-300646. PMID: 22422743. Exclusion Code: X7.22422743
164 Kansal AR, Zheng Y, Pokora T, . Cost-effectiveness of new oral anticoagulants in the prevention of stroke in patients with atrial fibrillation. Best Pract Res Clin Haematol. 2013 Jun;26(2):225–37. doi: 10.1016/j.beha.2013.07.012. PMID: 23953910. Exclusion Code: X7.23953910
165 Katona A, Mark L. The Belgian Improvement Study in Oral Anticoagulant Therapy: a randomized clinical trial. Eur Heart J. 2006 Jun;27(11):1382. doi: 10.1093/eurheartj/ehi856. PMID: 16595524. Exclusion Code: X7.16595524
166 Khan F, Huang H, Datta YH. Direct oral anticoagulant use and the incidence of bleeding in the very elderly with atrial fibrillation. J Thromb Thrombolysis. 2016 Nov;42(4):573–8. doi: 10.1007/s11239-016-1410-z. PMID: 27520093. Exclusion Code: X4.27520093
167 Khumri TM, Idupulapati M, Rader VJ, . Clinical and echocardiographic markers of mortality risk in patients with atrial fibrillation. Am J Cardiol. 2007 Jun 5;99(12):1733–6. doi: 10.1016/j.amjcard.2007.01.055. PMID: 17560884. Exclusion Code: X3.17560884
168 Klem I, Wehinger C, Schneider B, . Diabetic atrial fibrillation patients: mortality and risk for stroke or embolism during a 10-year follow-up. Diabetes Metab Res Rev. 2003 Jul–Aug;19(4):320–8. doi: 10.1002/dmrr.386. PMID: 12879410. Exclusion Code: X3.12879410
169 Kodani E, Atarashi H, Inoue H, . Beneficial Effect of Non-Vitamin K Antagonist Oral Anticoagulants in Patients With Nonvalvular Atrial Fibrillation- Results of the J-RHYTHM Registry 2. Circ J. 2016;80(4):843–51. doi: 10.1253/circj.CJ-16-0066. PMID: 27001190. Exclusion Code: X12.27001190
170 Komatsu T, Tachibana H, Sato Y, . Efficacy of antiarrhythmic drug therapy in preventing recurrence of atrial fibrillation and long-term cardiovascular prognosis in patients with asymptomatic paroxysmal atrial fibrillation. Int Heart J. 2010 Mar;51(2):98–104. PMID: 20379042. Exclusion Code: X3.20379042
171 Kong Y, Du X, Tang RB, . Whether Warfarin Therapy is Associated with Damage on Renal Function in Chinese Patients with Nonvalvular Atrial Fibrillation. Chin Med J (Engl). 2016 May 0;129(10):1135–9. doi: 10.4103/0366-6999.181970. PMID: 27174319. Exclusion Code: X5.27174319
172 Krishnan S, Chawla N, Ezekowitz MD, . Warfarin therapy and systolic hypertension in men with atrial fibrillation. Am J Hypertens. 2005 Dec;18(12 Pt 1):1592–9. doi: 10.1016/j.amjhyper.2005.06.001. PMID: 16364831. Exclusion Code: X5.16364831
173 Kumar S, Ling LH, Halloran K, . Esophageal hematoma after atrial fibrillation ablation: incidence, clinical features, and sequelae of esophageal injury of a different sort. Circ Arrhythm Electrophysiol. 2012 Aug 1;5(4):701–5. doi: 10.1161/circep.112.970624. PMID: 22544279. Exclusion Code: X4.22544279
174 Kwong JS, Lam YY, Yan BP, . Bleeding of new oral anticoagulants for stroke prevention in atrial fibrillation: a meta-analysis of randomized controlled trials (Provisional abstract). Cardiovasc Drugs Ther. 2013;27(1):23–35. PMID: DARE-12013011852. Exclusion Code: X4.23224686
175 Laguna P, Martin A, Del Arco C, . Differences among clinical classification schemes for predicting stroke in atrial fibrillation: implications for therapy in daily practice. Acad Emerg Med. 2005 Sep;12(9):828–34. doi: 10.1197/j.aem.2005.04.018. PMID: 16141016. Exclusion Code: X3.16141016
176 Lai HM, Aronow WS, Kalen P, . Incidence of thromboembolic stroke and of major bleeding in patients with atrial fibrillation and chronic kidney disease treated with and without warfarin. Int J Nephrol Renovasc Dis. 2009;2:33–7. PMID: 21694919. Exclusion Code: X7.21694919
177 Lane DA, Kamphuisen PW, Minini P, . Bleeding risk in patients with atrial fibrillation: the AMADEUS study. Chest. 2011 Jul;140(1):146–55. doi: 10.1378/chest.10-3270. PMID: 21415134. Exclusion Code: X4.21415134
178 Lane DA, Lip GY. Anticoagulation for atrial fibrillation patients with CHADS score of 1. J Cardiovasc Electrophysiol. 2010 May;21(5):508–10. doi: 10.1111/j.1540-8167.2009.01687.x. PMID: 20082649. Exclusion Code: X7.20082649
179 Lapner S, Cohen N, Kearon C. Influence of sex on risk of bleeding in anticoagulated patients: a systematic review and meta-analysis. J Thromb Haemost. 2014 May;12(5):595–605. PMID: 24977286. Exclusion Code: X4.24977286
180 Larsen TB, Skjoth F, Nielsen PB, . Comparative effectiveness and safety of non-vitamin K antagonist oral anticoagulants and warfarin in patients with atrial fibrillation: propensity weighted nationwide cohort study. BMJ. 2016 Jun 16;353:i3189. doi: 10.1136/bmj.i3189. PMID: 27312796. Exclusion Code: X4.27312796
181 Lavenson GS, Jr., Pantera RL, Garza RM, . Development and implementation of a rapid, accurate, and cost-effective protocol for national stroke prevention screening. Am J Surg. 2004 Dec;188(6):638–43. doi: 10.1016/j.amjsurg.2004.08.055. PMID: 15619477. Exclusion Code: X4.15619477
182 Lavitola Pde L, Spina GS, Sampaio RO, . Bleeding during oral anticoagulant therapy: warning against a greater hazard. Arq Bras Cardiol. 2009 Aug;93(2):174–9. PMID: 19838496. Exclusion Code: X4.19838496
183 Lee BH, Park JS, Park JH, . The effect and safety of the antithrombotic therapies in patients with atrial fibrillation and CHADS score 1. J Cardiovasc Electrophysiol. 2010 May;21(5):501–7. doi: 10.1111/j.1540-8167.2009.01661.x. PMID: 20021521. Exclusion Code: X7.20021521
184 Lee SJ, Shin DH, Hwang HJ, . Bleeding risk and major adverse events in patients with previous ulcer on oral anticoagulation therapy. Am J Cardiol. 2012 Aug 1;110(3):373–7. doi: 10.1016/j.amjcard.2012.03.036. PMID: 22516526. Exclusion Code: X7.22516526
185 Lega JC, Bertoletti L, Gremillet C, . Consistency of safety and efficacy of new oral anticoagulants across subgroups of patients with atrial fibrillation (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):e91398. PMID: DARE-12014031370. Exclusion Code: X4.
186 Lega JC, Mismetti P, Cucherat M, . Impact of double-blind vs open study design on the observed treatment effects of new oral anticoagulants in atrial fibrillation: a meta-analysis (Provisional abstract). J Thromb Haemost. 2013;11(7):1240–50. PMID: DARE-12013027862. Exclusion Code: X4.23659614
187 Lerner RG, Aronow WS, Sekhri A, . Warfarin use and the risk of valvular calcification. J Thromb Haemost. 2009 Dec;7(12):2023–7. doi: 10.1111/j.1538-7836.2009.03630.x. PMID: 19793187. Exclusion Code: X5.19793187
188 Link MS, Giugliano RP, Ruff CT, . Stroke and mortality risk in patients with various patterns of atrial fibrillation: results from the ENGAGE AF-TIMI 48 Trial (Effective Anticoagulation With Factor Xa Next Generation in Atrial Fibrillation-Thrombolysis in Myocardial Infarction 48). Circ Arrhythm Electrophysiol. 2017 Jan;10(1)doi: 10.1161/circep.116.004267. PMID: 28077507. Exclusion Code: X4.28077507
189 Lip GY, Frison L, Grind M. Effect of hypertension on anticoagulated patients with atrial fibrillation. Eur Heart J. 2007 Mar;28(6):752–9. doi: 10.1093/eurheartj/ehl504. PMID: 17289744. Exclusion Code: X4.17289744
190 Lip GY, Haguenoer K, Saint-Etienne C, . Relationship of the SAMe-TT(2)R(2) score to poor-quality anticoagulation, stroke, clinically relevant bleeding, and mortality in patients with atrial fibrillation. Chest. 2014 Sep;146(3):719–26. doi: 10.1378/chest.13-2976. PMID: 24722973. Exclusion Code: X4.24722973
191 Lip GY, Larsen TB, Skjoth F, . Indirect comparisons of new oral anticoagulant drugs for efficacy and safety when used for stroke prevention in atrial fibrillation. J Am Coll Cardiol. 2012 Aug 1;60(8):738–46. doi: 10.1016/j.jacc.2012.03.019. PMID: 22575324. Exclusion Code: X7.22575324
192 Lip GY, Rasmussen LH, Olsson SB, . Oral direct thrombin inhibitor AZD0837 for the prevention of stroke and systemic embolism in patients with non-valvular atrial fibrillation: a Phase II study of AZD0837 in patients who are appropriate for but unable or unwilling to take vitamin K antagonist therapy. Thromb Res. 2011 Feb;127(2):91–9. doi: 10.1016/j.thromres.2010.11.012. PMID: 21172721. Exclusion Code: X4.21172721
193 Lip GY, Rushton-Smith SK, Goldhaber SZ, . Does sex affect anticoagulant use for stroke prevention in nonvalvular atrial fibrillation? The prospective global anticoagulant registry in the FIELD-Atrial Fibrillation. Circ Cardiovasc Qual Outcomes. 2015 Mar;8(2 Suppl 1):S12–20. doi: 10.1161/circoutcomes.114.001556. PMID: 25714828. Exclusion Code: X5.25714828
194 Lip GY, Skjoth F, Rasmussen LH, . Oral anticoagulation, aspirin, or no therapy in patients with nonvalvular AF with 0 or 1 stroke risk factor based on the CHA2DS2-VASc score. J Am Coll Cardiol. 2015 Apr 4;65(14):1385–94. doi: 10.1016/j.jacc.2015.01.044. PMID: 25770314. Exclusion Code: X7.25770314
195 Liu GJ, Wang YF, Chen PY, . The efficacy and safety of novel oral anticoagulants for the preventive treatment in atrial fibrillation patients: a systematic review and meta-analysis. Drug Deliv. 2014 Sep;21(6):436–52. doi: 10.3109/10717544.2013.873500. PMID: 24400656. Exclusion Code: X4.24400656
196 Lopes LC, Spencer FA, Neumann I, . Bleeding risk in atrial fibrillation patients taking vitamin K antagonists: systematic review and meta-analysis (Provisional abstract). Clin Pharmacol Ther. 2013;94(3):367–75. PMID: DARE-12013027705. Exclusion Code: X4.23670121
197 Lopes LC, Spencer FA, Neumann I, . Systematic review of observational studies assessing bleeding risk in patients with atrial fibrillation not using anticoagulants. PLoS One. 2014;9(2):e88131. doi: 10.1371/journal.pone.0088131. PMID: 24523876. Exclusion Code: X4.24523876
198 Lopez-Lopez JA, Sterne J, Bodalia PN, . Network meta-analysis of oral anticoagulants for primary prevention, treatment and secondary prevention of venous thromboembolic disease, and for prevention of stroke in atrial fibrillation. Value Health. 2015;18(7):A374. PMID: CN-01126898. Exclusion Code: X4.
199 Lowres N, Neubeck L, Redfern J, . Screening to identify unknown atrial fibrillation. A systematic review. Thromb Haemost. 2013 Aug;110(2):213–22. doi: 10.1160/th13-02-0165. PMID: 23595785. Exclusion Code: X7.23595785
200 Lowres N, Neubeck L, Salkeld G, . Feasibility and cost-effectiveness of stroke prevention through community screening for atrial fibrillation using iPhone ECG in pharmacies. The SEARCH-AF study. Thromb Haemost. 2014 Jun;111(6):1167–76. doi: 10.1160/th14-03-0231. PMID: 24687081. Exclusion Code: X4.24687081
201 Lu D, Zhang Q, Liu Q, . Bleeding risks with novel oral anticoagulants during catheter ablation of atrial fibrillation: a systematic review and network meta-analysis. J Interv Card Electrophysiol. 2015 Nov;44(2):105–11. doi: 10.1007/s10840-015-0053-x. PMID: 26342485. Exclusion Code: X4.26342485
202 Luik A, Radzewitz A, Kieser M, . Cryoballoon Versus Open Irrigated Radiofrequency Ablation in Patients With Paroxysmal Atrial Fibrillation: The Prospective, Randomized, Controlled, Noninferiority FreezeAF Study. Circulation. 2015 Oct 6;132(14):1311–9. doi: 10.1161/circulationaha.115.016871. PMID: 26283655. Exclusion Code: X4.26283655
203 Luzi M, Capucci A, Pasquale G, . [The BRIDGE study]. G Ital Cardiol (Rome). 2016;17(1):1–5. doi: 10.1714/2140.23178. PMID: CN-01168203. Exclusion Code: X1.26901252
204 Malek F. Rivaroxaban use in prevention of stroke in patients with non-valvular atrial fibrillation in clinical practice, results of observational studies and our experience. Vnitr Lek. 2017;62(10):814–9. PMID: CN-01330031. Exclusion Code: X1.
205 Mantha S, Ansell J. An indirect comparison of dabigatran, rivaroxaban and apixaban for atrial fibrillation. Thromb Haemost. 2012 Sep;108(3):476–84. doi: 10.1160/th12-02-0093. PMID: 22740145. Exclusion Code: X4.22740145
206 Marijon E, Le Heuzey JY, Connolly S, . Causes of death and influencing factors in patients with atrial fibrillation: a competing-risk analysis from the randomized evaluation of long-term anticoagulant therapy study. Circulation. 2013 Nov 2;128(20):2192–201. doi: 10.1161/circulationaha.112.000491. PMID: 24016454. Exclusion Code: X4.24016454
207 Martinez C, Katholing A, Freedman SB. Adverse prognosis of incidentally detected ambulatory atrial fibrillation. A cohort study. Thromb Haemost. 2014 Aug;112(2):276–86. doi: 10.1160/th4-04-0383. PMID: 24953051. Exclusion Code: X7.24953051
208 McCahon D, Fitzmaurice DA, Baker J, . Atrial fibrillation: Is screening effective in identifying patients at risk of stroke? Br J Haematol. 2014;165:10–1. doi: 10.1111/bjh.12802. PMID: CN-01053067. Exclusion Code: X9.
209 McClennen S, Zimetbaum PJ, Ho KK, . Holter monitoring: are two days better than one (Structured abstract). Am J Cardiol. 2000;86(5):562–4. PMID: NHSEED-22000001438. Exclusion Code: X7.11009281
210 Mearns ES, White CM, Kohn CG, . Quality of vitamin K antagonist control and outcomes in atrial fibrillation patients: a meta-analysis and meta-regression (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):14. PMID: DARE-12014045454. Exclusion Code: X4.
211 Mercaldi CJ, Ciarametaro M, Hahn B, . Cost efficiency of anticoagulation with warfarin to prevent stroke in medicare beneficiaries with nonvalvular atrial fibrillation. Stroke. 2011 Jan;42(1):112–8. doi: 10.1161/strokeaha.110.592907. PMID: 21148442. Exclusion Code: X7.21148442
212 Miller CS, Grandi SM, Shimony A, . Meta-analysis of efficacy and safety of new oral anticoagulants (dabigatran, rivaroxaban, apixaban) versus warfarin in patients with atrial fibrillation (Structured abstract). Am J Cardiol. 2012;110(3):453–60. PMID: DARE-12012036643. Exclusion Code: X4.22537354
213 Minguet J, Sims H, Smith K, . The factor xa inhibitor edoxaban for the prevention of stroke and systemic embolism in patients with atrial fibrillation. Expert Rev Clin Pharmacol. 2017;10(1):5–15. doi: 10.1080/17512433.2016.1258301. PMID: CN-01338057. Exclusion Code: X7.27817212
214 Mitchell SA, Simon TA, Raza S, . The efficacy and safety of oral anticoagulants in warfarin-suitable patients with nonvalvular atrial fibrillation: systematic review and meta-analysis (Provisional abstract). Clin Appl Thromb Hemost. 2013;19(6):619–31. PMID: DARE-12013028996. Exclusion Code: X4.23698729
215 Monte S, Macchia A, Pellegrini F, . Antithrombotic treatment is strongly underused despite reducing overall mortality among high-risk elderly patients hospitalized with atrial fibrillation. Eur Heart J. 2006 Sep;27(18):2217–23. doi: 10.1093/eurheartj/ehl208. PMID: 16935869. Exclusion Code: X7.16935869
216 Moran Patrick S, Teljeur C, Ryan M, . Systematic screening for the detection of atrial fibrillation. Cochrane Database of Systematic Reviews. 2016(6)doi: 10.1002/14651858.CD009586.pub3. PMID: CD009586. Exclusion Code: X7.
217 Moran PS, Flattery MJ, Teljeur C, . Effectiveness of systematic screening for the detection of atrial fibrillation. Cochrane Database Syst Rev. 2013(4):Cd009586. doi: 10.1002/14651858.CD009586.pub2. PMID: 23633374. Exclusion Code: X7.23633374
218 Morilla MA, Tumulak CD, Gulay CB, . A meta-analysis on the efficacy of dabigatran versus warfarin among patients with atrial fibrillation (Provisional abstract). Philipp J Intern Med. 2012;50(4):1–4. PMID: DARE-12013058012. Exclusion Code: X4.
219 Morimoto T, Crawford B, Wada K, . Comparative efficacy and safety of novel oral anticoagulants in patients with atrial fibrillation: A network meta-analysis with the adjustment for the possible bias from open label studies. J Cardiol. 2015 Dec;66(6):466–74. doi: 10.1016/j.jjcc.2015.05.018. PMID: 26162944. Exclusion Code: X4.26162944
220 Mortimer CL, Cottrell WN, Comino NJ. Automatic drug use audit in primary care-a pilot evaluation of warfarin use for patients with atrial fibrillation. Aust Fam Physician. 2005 Sep;34(9):798–800. PMID: 16184218. Exclusion Code: X3.16184218
221 Naganuma M, Shiga T, Sato K, . Clinical outcome in Japanese elderly patients with non-valvular atrial fibrillation taking warfarin: a single-center observational study. Thromb Res. 2012 Jul;130(1):21–6. doi: 10.1016/j.thromres.2011.11.005. PMID: 22137743. Exclusion Code: X4.22137743
222 Nagler M, Bachmann LM, Schmid P, . Patient self-management of oral anticoagulation with vitamin K antagonists in everyday practice: efficacy and safety in a nationwide long-term prospective cohort study. PLoS One. 2014;9(4):e95761. doi: 10.1371/journal.pone.0095761. PMID: 24748062. Exclusion Code: X4.24748062
223 Nair A, Hazell W, Sutton T, . Antithrombotic therapy in atrial fibrillation: an assessment of compliance with guidelines. N Z Med J. 2005 Jan 28;118(1208):U1258. PMID: 15682210. Exclusion Code: X2.15682210
224 Nguyen TN, Cumming RG, Hilmer SN. Atrial fibrillation in older inpatients: are there any differences in clinical characteristics and pharmacological treatment between the frail and the non-frail? Intern Med J. 2016 Jan;46(1):86–95. doi: 10.1111/imj.12912. PMID: 26388116. Exclusion Code: X4.26388116
225 Nielsen PB, Lane DA, Rasmussen LH, . Renal function and non-vitamin K oral anticoagulants in comparison with warfarin on safety and efficacy outcomes in atrial fibrillation patients: a systemic review and meta-regression analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):epub. PMID: DARE-12014069697. Exclusion Code: X4.
226 Nieuwlaat R, Prins MH, Le Heuzey JY, . Prognosis, disease progression, and treatment of atrial fibrillation patients during 1 year: follow-up of the Euro Heart Survey on atrial fibrillation. Eur Heart J. 2008 May;29(9):1181–9. doi: 10.1093/eurheartj/ehn139. PMID: 18397874. Exclusion Code: X4.18397874
227 Ninios I, Bogossian H, Zarse M, . Prevalence, clinical correlates and treatment of permanent atrial fibrillation among the elderly: insights from the first prospective population-based study in rural Greece. J Thromb Thrombolysis. 2010 Jul;30(1):90–6. doi: 10.1007/s11239-009-0422-3. PMID: 19921100. Exclusion Code: X4.19921100
228 Nogueras C, Miralles R, Roig A, . Polypharmacy as part of comprehensive geriatric assessment: disclosure of false diagnosis of atrial fibrillation by drug revision. J Am Geriatr Soc. 2007 Sep;55(9):1476–8. doi: 10.1111/j.1532-5415.2007.01305.x. PMID: 17767695. Exclusion Code: X7.17767695
229 Noseworthy PA, Yao X, Shah ND, . Comparative effectiveness and safety of non-vitamin K antagonist oral anticoagulants versus warfarin in patients with atrial fibrillation and valvular heart disease. Int J Cardiol. 2016 Apr 15;209:181–3. doi: 10.1016/j.ijcard.2016.02.005. PMID: 26896618. Exclusion Code: X2.26896618
230 Ntaios G, Manios E, Synetou M, . Prevalence of atrial fibrillation in Greece: the Arcadia Rural Study on Atrial Fibrillation. Acta Cardiol. 2012 Feb;67(1):65–9. doi: 10.2143/ac.67.1.2146567. PMID: 22455091. Exclusion Code: X4.22455091
231 Ntaios G, Papavasileiou V, Diener HC, . Nonvitamin-K-antagonist oral anticoagulants in patients with atrial fibrillation and previous stroke or transient ischemic attack: a systematic review and meta-analysis of randomized controlled trials (Structured abstract). Stroke. 2012;43(12):3298–304. PMID: DARE-12013002704. Exclusion Code: X4.23150654
232 Odutayo A, Wong CX, Hsiao AJ, . Atrial fibrillation and risks of cardiovascular disease, renal disease, and death: systematic review and meta-analysis. BMJ. 2016 Sep 06;354:i4482. doi: 10.1136/bmj.i4482. PMID: 27599725. Exclusion Code: X4.27599725
233 Ogilvie IM, Welner SA, Cowell W, . Ischaemic stroke and bleeding rates in ‘real-world’ atrial fibrillation patients (Structured abstract). Thromb Haemost. 2011;106(1):34–44. PMID: DARE-12011004843. Exclusion Code: X4.21614409
234 Ohara K, Inoue H, Nozawa T, . Accumulation of risk factors enhances the prothrombotic state in atrial fibrillation. Int J Cardiol. 2008 Jun 6;126(3):316–21. doi: 10.1016/j.ijcard.2007.06.020. PMID: 17689760. Exclusion Code: X5.17689760
235 Okcun B, Yigit Z, Yildiz A, . What should be the primary treatment in atrial fibrillation: ventricular rate control or sinus rhythm control with long-term anticoagulation? J Int Med Res. 2009 Mar–Apr;37(2):464–71. PMID: 19383241. Exclusion Code: X4.19383241
236 Okumura K, Hori M, Tanahashi N, . Special considerations for therapeutic choice of non-vitamin K antagonist oral anticoagulants for Japanese patients with nonvalvular atrial fibrillation. Clin Cardiol. 2017;40(2):126–31. doi: 10.1002/clc.22596. PMID: CN-01337693. Exclusion Code: X4.27716968
237 Okumura K, Inoue H, Atarashi H, . Validation of CHA(2)DS(2)-VASc and HAS-BLED scores in Japanese patients with nonvalvular atrial fibrillation: an analysis of the J-RHYTHM Registry. Circ J. 2014;78(7):1593–9. PMID: 24759791. Exclusion Code: X4.24759791
238 Oldgren J, Alings M, Darius H, . Risks for stroke, bleeding, and death in patients with atrial fibrillation receiving dabigatran or warfarin in relation to the CHADS2 score: a subgroup analysis of the RE-LY trial. Ann Intern Med. 2011 Nov 15;155(10):660–7, w204. doi: 10.7326/0003-4819-155-10-201111150-00004. PMID: 22084332. Exclusion Code: X4.22084332
239 Oldgren J, Hijazi Z, Lindback J, . Performance and validation of a novel biomarker-based stroke risk score for atrial fibrillation. Circulation. 2017;134(22):1697–707. doi: 10.1161/CIRCULATIONAHA.116.022802. PMID: CN-01290304. Exclusion Code: X3.
240 Olesen JB, Lip GY, Lindhardsen J, . Risks of thromboembolism and bleeding with thromboprophylaxis in patients with atrial fibrillation: A net clinical benefit analysis using a ‘real world’ nationwide cohort study. Thromb Haemost. 2011 Oct;106(4):739–49. doi: 10.1160/th11-05-0364. PMID: 21789337. Exclusion Code: X7.21789337
241 Ono A, Fujita T. Low-intensity anticoagulation for stroke prevention in elderly patients with atrial fibrillation: efficacy and safety in actual clinical practice. J Clin Neurosci. 2005 Nov;12(8):891–4. doi: 10.1016/j.jocn.2004.10.011. PMID: 16271478. Exclusion Code: X4.16271478
242 Origasa H, Noma H, Teramukai S. Estimating an ICER with NOAC versus warfarin in atrial fibrillation. Value Health. 2017;19(7):A867. PMID: CN-01250651. Exclusion Code: X5.
243 Oswald N. Anticoagulation to prevent stroke in atrial fibrillation. Cohort was younger than many patients with atrial fibrillation in primary care. BMJ. 2000 Nov 4;321(7269):1156. PMID: 11203223. Exclusion Code: X7.11203223
244 Pancholy SB, Sharma PS, Pancholy DS, . Meta-analysis of gender differences in residual stroke risk and major bleeding in patients with nonvalvular atrial fibrillation treated with oral anticoagulants (Provisional abstract). Am J Cardiol. 2014;113(3):485–90. PMID: DARE-12013071804. Exclusion Code: X4.24315113
245 Park H, Hildreth A, Thomson R, . Non-valvular atrial fibrillation and cognitive decline: a longitudinal cohort study. Age Ageing. 2007 Mar;36(2):157–63. doi: 10.1093/ageing/afl164. PMID: 17259637. Exclusion Code: X5.17259637
246 Parkash R, Wee V, Gardner MJ, . The impact of warfarin use on clinical outcomes in atrial fibrillation: a population-based study. Can J Cardiol. 2007 May 1;23(6):457–61. PMID: 17487290. Exclusion Code: X4.17487290
247 Passman R. Time in therapeutic range inwarfarin-treated patients is very good good enough? JAMA. 2017;316(8):872–3. doi: 10.1001/jamacardio.2016.0199. PMID: CN-01286287. Exclusion Code: X7.
248 Patti G, Lucerna M, Cavallari I, . Insulin-Requiring Versus Noninsulin-Requiring Diabetes and Thromboembolic Risk in Patients With Atrial Fibrillation: PREFER in AF. J Am Coll Cardiol. 2017;69(4):409–19. doi: 10.1016/j.jacc.2016.10.069. PMID: CN-01329702. Exclusion Code: X3.28126158
249 Penado S, Cano M, Acha O, . Stroke severity in patients with atrial fibrillation. Am J Med. 2002 May;112(7):572–4. PMID: 12015250. Exclusion Code: X2.12015250
250 Perez-Gomez F. Is computer-assisted, long-term warfarin therapy safe and efficacious for patients with nonrheumatic atrial fibrillation? Nat Clin Pract Cardiovasc Med. 2005 Feb;2(2):82–3. doi: 10.1038/ncpcardio0117. PMID: 16265377. Exclusion Code: X6.16265377
251 Perez-Gomez F, Alegria E, Berjon J, . Comparative effects of antiplatelet, anticoagulant, or combined therapy in patients with valvular and nonvalvular atrial fibrillation: a randomized multicenter study. J Am Coll Cardiol. 2004 Oct 9;44(8):1557–66. doi: 10.1016/j.jacc.2004.05.084. PMID: 15489085. Exclusion Code: X4.15489085
252 Perula-de-Torres LA, Martinez-Adell MA, Gonzalez-Blanco V, . Opportunistic detection of atrial fibrillation in subjects aged 65 years or older in primare care: a randomised clinical trial of efficacy. DOFA-AP study protocol. BMC Fam Pract. 2012;13:106. doi: 10.1186/1471-2296-13-106. PMID: 23130754. Exclusion Code: X2.23130754
253 Pfeilschifter W, Luger S, Brunkhorst R, . The gap between trial data and clinical practice - an analysis of case reports on bleeding complications occurring under dabigatran and rivaroxaban anticoagulation. Cerebrovasc Dis. 2013;36(2):115–9. doi: 10.1159/000352062. PMID: 24029592. Exclusion Code: X7.24029592
254 Plitt A, Ezekowitz M, Caterina R, . Cardioversion of atrial fibrillation in ENGAGE AF-TIMI 48. Clin Cardiol. 2016;39(6):345–6. doi: 10.1002/clc.22537. PMID: CN-01165738. Exclusion Code: X2.27028520
255 Poli D, Antonucci E, Grifoni E, . Bleeding risk during oral anticoagulation in atrial fibrillation patients older than 80 years. J Am Coll Cardiol. 2009 Sep 8;54(11):999–1002. doi: 10.1016/j.jacc.2009.05.046. PMID: 19729116. Exclusion Code: X4.19729116
256 Poli D, Antonucci E, Grifoni E, . Gender differences in stroke risk of atrial fibrillation patients on oral anticoagulant treatment. Thromb Haemost. 2009 May;101(5):938–42. PMID: 19404548. Exclusion Code: X4.19404548
257 Poli D, Antonucci E, Grifoni E, . Stroke risk in atrial fibrillation patients on warfarin. Predictive ability of risk stratification schemes for primary and secondary prevention. Thromb Haemost. 2009 Feb;101(2):367–72. PMID: 19190823. Exclusion Code: X4.19190823
258 Poli D, Antonucci E, Marcucci R, . The quality of anticoagulation on functional outcome and mortality for TIA/stroke in atrial fibrillation patients. Int J Cardiol. 2009 Feb 6;132(1):109–13. doi: 10.1016/j.ijcard.2007.10.041. PMID: 18180057. Exclusion Code: X4.18180057
259 Poli D, Antonucci E, Pengo V, . Comparison of HAS-BLED and HAS-BED Versus CHADS2 and CHA2DS2VASC Stroke and Bleeding Scores in Patients With Atrial Fibrillation. Am J Cardiol. 2017 Apr 1;119(7):1012–6. doi: 10.1016/j.amjcard.2016.12.007. PMID: 28237286. Exclusion Code: X2.28237286
260 Poli D, Antonucci E, Testa S, . The predictive ability of bleeding risk stratification models in very old patients on vitamin K antagonist treatment for venous thromboembolism: results of the prospective collaborative EPICA study. J Thromb Haemost. 2013 Jun;11(6):1053–8. doi: 10.1111/jth.12239. PMID: 23578305. Exclusion Code: X4.23578305
261 Poli D, Antonucci E, Testa S, . Bleeding risk in very old patients on vitamin K antagonist treatment: results of a prospective collaborative study on elderly patients followed by Italian Centres for Anticoagulation. Circulation. 2011 Aug 6;124(7):824–9. doi: 10.1161/circulationaha.110.007864. PMID: 21810658. Exclusion Code: X4.21810658
262 Poli D, Antonucci E, Zanazzi M, . Impact of glomerular filtration estimate on bleeding risk in very old patients treated with vitamin K antagonists. Results of EPICA study on the behalf of FCSA (Italian Federation of Anticoagulation Clinics). Thromb Haemost. 2012 Jun;107(6):1100–6. doi: 10.1160/th11-10-0721. PMID: 22535516. Exclusion Code: X4.22535516
263 Posada IS, Barriales V. Alternate-day dosing of aspirin in atrial fibrillation. LASAF Pilot Study Group. Am Heart J. 1999 Jul;138(1 Pt 1):137–43. PMID: 10385777. Exclusion Code: X12.10385777
264 Potpara TS, Polovina MM, Marinkovic JM, . A comparison of clinical characteristics and long-term prognosis in asymptomatic and symptomatic patients with first-diagnosed atrial fibrillation: the Belgrade Atrial Fibrillation Study. Int J Cardiol. 2013 Oct 2;168(5):4744–9. doi: 10.1016/j.ijcard.2013.07.234. PMID: 23958417. Exclusion Code: X4.23958417
265 Quinn GR, Severdija ON, Chang Y, . Wide Variation in Reported Rates of Stroke Across Cohorts of Patients With Atrial Fibrillation. Circulation. 2017 Jan 7;135(3):208–19. doi: 10.1161/circulationaha.116.024057. PMID: 27799272. Exclusion Code: X4.27799272
266 Rasmussen LH, Larsen TB, Graungaard T, . Primary and secondary prevention with new oral anticoagulant drugs for stroke prevention in atrial fibrillation: indirect comparison analysis. BMJ. 2012;345:e7097. doi: 10.1136/bmj.e7097. PMID: 23129490. Exclusion Code: X4.23129490
267 Reilly PA, Lehr T, Haertter S, . The effect of dabigatran plasma concentrations and patient characteristics on the frequency of ischemic stroke and major bleeding in atrial fibrillation patients: the RE-LY Trial (Randomized Evaluation of Long-Term Anticoagulation Therapy). J Am Coll Cardiol. 2014 Feb 4;63(4):321–8. doi: 10.1016/j.jacc.2013.07.104. PMID: 24076487. Exclusion Code: X4.24076487
268 Reynolds MR, Shah J, Essebag V, . Patterns and predictors of warfarin use in patients with new-onset atrial fibrillation from the FRACTAL Registry. Am J Cardiol. 2006 Feb 5;97(4):538–43. doi: 10.1016/j.amjcard.2005.09.086. PMID: 16461052. Exclusion Code: X5.16461052
269 Rietbrock S, Plumb JM, Gallagher AM, . How effective are dose-adjusted warfarin and aspirin for the prevention of stroke in patients with chronic atrial fibrillation? An analysis of the UK General Practice Research Database. Thromb Haemost. 2009 Mar;101(3):527–34. PMID: 19277415. Exclusion Code: X5.19277415
270 Rizzo MR, Sasso FC, Marfella R, . Autonomic dysfunction is associated with brief episodes of atrial fibrillation in type 2 diabetes. J Diabetes Complications. 2015 Jan–Feb;29(1):88–92. doi: 10.1016/j.jdiacomp.2014.09.002. PMID: 25266244. Exclusion Code: X4.25266244
271 Romanelli RJ, Nolting L, Dolginsky M, . Dabigatran Versus Warfarin for Atrial Fibrillation in Real-World Clinical Practice: A Systematic Review and Meta-Analysis. Circ Cardiovasc Qual Outcomes. 2016 Mar;9(2):126–34. doi: 10.1161/circoutcomes.115.002369. PMID: 26812933. Exclusion Code: X4.26812933
272 Rose G, Baxter PJ, Reid DD, . Prevalence and prognosis of electrocardiographic findings in middle-aged men. Br Heart J. 1978 Jun;40(6):636–43. PMID: 656238. Exclusion Code: X4.656238
273 Roskell NS, Lip GY, Noack H, . Treatments for stroke prevention in atrial fibrillation: a network meta-analysis and indirect comparisons versus dabigatran etexilate. Thromb Haemost. 2010 Dec;104(6):1106–15. doi: 10.1160/th10-10-0642. PMID: 20967400. Exclusion Code: X11.20967400
274 Roy B, Desai RV, Mujib M, . Effect of warfarin on outcomes in septuagenarian patients with atrial fibrillation. Am J Cardiol. 2012 Feb 1;109(3):370–7. doi: 10.1016/j.amjcard.2011.09.023. PMID: 22118824. Exclusion Code: X7.22118824
275 Rozzini R, Sabatini T, Bellelli G, . Anticoagulation of older patients. Age Ageing. 2000 Sep;29(5):457–8; author reply 8-9. PMID: 11108422. Exclusion Code: X7.11108422
276 Rozzini R, Sabatini T, Trabucchi M. Risk assessment and anticoagulation in atrial fibrillation in the elderly: malpractice or accuracy? Stroke. 1999 Oct;30(10):2239–40. PMID: 10512996. Exclusion Code: X7.10512996
277 Ruff CT, Giugliano RP, Braunwald E, . Comparison of the efficacy and safety of new oral anticoagulants with warfarin in patients with atrial fibrillation: a meta-analysis of randomised trials (Structured abstract). Lancet. 2014;383(9921):955–62. PMID: DARE-12013069847. Exclusion Code: X4.24315724
278 Ruiz Ortiz M, Romo E, Mesa D, . Oral anticoagulation in nonvalvular atrial fibrillation in clinical practice: impact of CHADS(2) score on outcome. Cardiology. 2010;115(3):200–4. doi: 10.1159/000284450. PMID: 20160440. Exclusion Code: X4.20160440
279 Ruiz Ortiz M, Romo E, Mesa D, . Outcomes and safety of antithrombotic treatment in patients aged 80 years or older with nonvalvular atrial fibrillation. Am J Cardiol. 2011 May 5;107(10):1489–93. doi: 10.1016/j.amjcard.2011.01.025. PMID: 21420049. Exclusion Code: X4.21420049
280 Ruiz-Ortiz M, Romo E, Mesa D, . Effectiveness of oral anticoagulation in nonvalvular atrial fibrillation according to CHA(2)DS(2)-VASc score in patients with low-moderate embolic risk. Rev Esp Cardiol (Engl Ed). 2012 Apr;65(4):382–3. doi: 10.1016/j.recesp.2011.05.021. PMID: 21840108. Exclusion Code: X4.21840108
281 Runev NM, Dimitrov SM. Management of stroke prevention in Bulgarian patients with non-valvular atrial fibrillation (BUL-AF Survey). Int J Cardiol. 2015;187(1):683–5. doi: 10.1016/j.ijcard.2015.03.420. PMID: CN-01075331. Exclusion Code: X7.25910470
282 Sahay S, Nombela-Franco L, Rodes-Cabau J, . Efficacy and safety of left atrial appendage closure versus medical treatment in atrial fibrillation: a network meta-analysis from randomised trials. Heart. 2016 Sep 1doi: 10.1136/heartjnl-2016-309782. PMID: 27587437. Exclusion Code: X11.27587437
283 Salazar Carlos A, del Aguila D, Cordova Erika G. Direct thrombin inhibitors versus vitamin K antagonists for preventing cerebral or systemic embolism in people with non-valvular atrial fibrillation. Cochrane Database of Systematic Reviews. 2014(3)doi: 10.1002/14651858.CD009893.pub2. PMID: CD009893. Exclusion Code: X4.
284 Sanchez-Barba B, Navarrete-Reyes AP, Avila-Funes JA. Are geriatric syndromes associated with reluctance to initiate oral anticoagulation therapy in elderly adults with nonvalvular atrial fibrillation? J Am Geriatr Soc. 2013 Dec;61(12):2236–7. doi: 10.1111/jgs.12582. PMID: 24329827. Exclusion Code: X7.24329827
285 Sandhu RK, Bakal JA, Ezekowitz JA, . Risk stratification schemes, anticoagulation use and outcomes: the risk-treatment paradox in patients with newly diagnosed non-valvular atrial fibrillation. Heart. 2011 Dec;97(24):2046–50. doi: 10.1136/heartjnl-2011-300901. PMID: 22076011. Exclusion Code: X7.22076011
286 Sandhu RK, Connolly SJ, Hohnloser S, . Does the degree of left ventricular dysfunction or symptom status influence the risk of stroke or systemic embolism among patients with atrial fibrillation and heart failure?-Results from the ACTIVE study. Circulation. 2013;128(22 suppl. 1) PMID: CN-01062466. Exclusion Code: X2.
287 Sanofi. Atrial Fibrillation Clopidogrel Trial With Irbesartan for Prevention of Vascular Events (ACTIVE A). Bethesda, MD: National Library of Medicine (US); 2017. Exclusion Code: X4.
288 Sardar P, Chatterjee S, Chaudhari S, . New oral anticoagulants in elderly adults: evidence from a meta-analysis of randomized trials. J Am Geriatr Soc. 2014 May;62(5):857–64. doi: 10.1111/jgs.12799. PMID: 24786913. Exclusion Code: X2.24786913
289 Sarvananthan S, Punjabi PP. In atrial fibrillation, dabigatran had similar efficacy to warfarin but caused less bleeding in higher GFR. Ann Intern Med. 2014;161(4):Jc7. doi: 10.7326/0003-4819-161-4-201408190-02007. PMID: CN-01014106. Exclusion Code: X4.
290 Scardi S, Mazzone C, Pandullo C, . Mortality and cause of death in patients with chronic non-rheumatic atrial fibrillation after a two-year follow-up. G Ital Cardiol. 1999 Jun;29(6):637–46. PMID: 10396667. Exclusion Code: X4.10396667
291 Schauer DP, Moomaw CJ, Wess M, . Psychosocial risk factors for adverse outcomes in patients with nonvalvular atrial fibrillation receiving warfarin. J Gen Intern Med. 2005 Dec;20(12):1114–9. doi: 10.1111/j.1525-1497.2005.0242.x. PMID: 16423100. Exclusion Code: X7.16423100
292 Schmiedl S, Rottenkolber M, Szymanski J, . Bleeding complications and liver injuries during phenprocoumon treatment: a multicentre prospective observational study in internal medicine departments. Dtsch Arztebl Int. 2013 Apr;110(14):244–52. doi: 10.3238/arztebl.2013.0244. PMID: 23616817. Exclusion Code: X3.23616817
293 Schneeweiss S, Gagne JJ, Patrick AR, . Comparative efficacy and safety of new oral anticoagulants in patients with atrial fibrillation. Circ Cardiovasc Qual Outcomes. 2012 Jul 1;5(4):480–6. doi: 10.1161/circoutcomes.112.965988. PMID: 22787066. Exclusion Code: X4.22787066
294 Schumann SA, Ewigman B. Stroke prevention: age alone does not rule out warfarin. J Fam Pract. 2007 Nov;56(11):902–6. PMID: 17976336. Exclusion Code: X7.17976336
295 Schwartz JB. Dabigatran Compared With Rivaroxaban vs Warfarin. JAMA Intern Med. 2017 May 1;177(5):741–2. doi: 10.1001/jamainternmed.2017.0554. PMID: 28460097. Exclusion Code: X7.28460097
296 Scott KA, Amirehsani KA. Dabigatran etexilate: an alternative to warfarin for patients with nonvalvular atrial fibrillation (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):epub. PMID: DARE-12014048325. Exclusion Code: X4.
297 Sherman D. Reducing stroke risk in atrial fibrillation patients. Cleve Clin J Med. 1991 May–Jun;58(3):203–4. PMID: 1893548. Exclusion Code: X7.1893548
298 Shireman TI, Mahnken JD, Howard PA, . Development of a contemporary bleeding risk model for elderly warfarin recipients. Chest. 2006 Nov;130(5):1390–6. doi: 10.1378/chest.130.5.1390. PMID: 17099015. Exclusion Code: X4.17099015
299 Simon TA, Jakouloff D, Mitchell SA, . Heterogeneity in published evidence for stroke prevention in patients with atrial fibrillation: A systematic review. Pharmacoepidemiol Drug Saf. 2012;21:247–8. doi: 10.1002/pds.3324. PMID: CN-01004059. Exclusion Code: X4.
300 Singer DE, Chang Y, Fang MC, . The net clinical benefit of warfarin anticoagulation in atrial fibrillation. Ann Intern Med. 2009 Sep 1;151(5):297–305. PMID: 19721017. Exclusion Code: X4.19721017
301 Singer DE, Hughes RA, Gress DR, . The effect of aspirin on the risk of stroke in patients with nonrheumatic atrial fibrillation: The BAATAF Study. Am Heart J. 1992 Dec;124(6):1567–73. PMID: 1462916. Exclusion Code: X4.1462916
302 Siu CW, Lip GY, Lam KF, . Risk of stroke and intracranial hemorrhage in 9727 Chinese with atrial fibrillation in Hong Kong. Heart Rhythm. 2014 Aug;11(8):1401–8. doi: 10.1016/j.hrthm.2014.04.021. PMID: 24747420. Exclusion Code: X7.24747420
303 Siu CW, Pong V, Zhang X, . Risk of ischemic stroke after new-onset atrial fibrillation in patients with hyperthyroidism. Heart Rhythm. 2009 Feb;6(2):169–73. doi: 10.1016/j.hrthm.2008.10.023. PMID: 19187905. Exclusion Code: X6.19187905
304 Siu CW, Tse HF. Net clinical benefit of warfarin therapy in elderly Chinese patients with atrial fibrillation. Circ Arrhythm Electrophysiol. 2014 Apr;7(2):300–6. doi: 10.1161/circep.113.000858. PMID: 24610776. Exclusion Code: X7.24610776
305 Skjoth F, Larsen TB, Rasmussen LH, . Efficacy and safety of edoxaban in comparison with dabigatran, rivaroxaban and apixaban for stroke prevention in atrial fibrillation: An indirect comparison analysis. Thromb Haemost. 2014;111(5):981–8. doi: 10.1160/TH14-02-0118. PMID: CN-00988202. Exclusion Code: X4.24577485
306 Sobieraj DM, White CM, Alikhanov S, . The impact of antiplatelet and anticoagulant therapies on gastrointestinal symptoms in patients with atrial fibrillation: a systematic review (Provisional abstract). Ann Pharmacother. 2012;46(9):1220–31. PMID: DARE-12012043698. Exclusion Code: X4.22932307
307 Solomon MD, Yang J, Sung SH, . Incidence and timing of potentially high-risk arrhythmias detected through long term continuous ambulatory electrocardiographic monitoring. BMC Cardiovasc Disord. 2016 Feb 17;16:35. doi: 10.1186/s12872-016-0210-x. PMID: 26883019. Exclusion Code: X2.26883019
308 Somerville S, Somerville J, Croft P, . Atrial fibrillation: a comparison of methods to identify cases in general practice. Br J Gen Pract. 2000 Sep;50(458):727–9. PMID: 11050790. Exclusion Code: X4.11050790
309 Staszewski J, Staszewska M, Kotowicz J, . Cerebrovascular incidents differ in patients with permanent and paroxysmal atrial fibrillation. Cerebrovasc Dis. 2006;22(5-6):446–9. doi: 10.1159/000095288. PMID: 16931883. Exclusion Code: X2.16931883
310 Steinberg BA, Hasselblad V, Atwater BD, . Dabigatran for periprocedural anticoagulation following radiofrequency ablation for atrial fibrillation: a meta-analysis of observational studies. J Interv Card Electrophysiol. 2013 Sep;37(3):213–21. doi: 10.1007/s10840-013-9813-7. PMID: 23881249. Exclusion Code: X4.23881249
311 Steinberg BA, Peterson ED, Kim S, . Use and outcomes associated with bridging during anticoagulation interruptions in patients with atrial fibrillation: findings from the Outcomes Registry for Better Informed Treatment of Atrial Fibrillation (ORBIT-AF). Circulation. 2015 Feb 3;131(5):488–94. doi: 10.1161/circulationaha.114.011777. PMID: 25499873. Exclusion Code: X3.25499873
312 Steinhubl SR, Mehta RR, Ebner GS, . Rationale and design of a home-based trial using wearable sensors to detect asymptomatic atrial fibrillation in a targeted population: The mHealth Screening to Prevent Strokes (mSToPS) trial. Am Heart J. 2016;175:77–85. doi: 10.1016/j.ahj.2016.02.011. PMID: CN-01142287. Exclusion Code: X5.27179726
313 Stenestrand U, Lindback J, Wallentin L. Anticoagulation therapy in atrial fibrillation in combination with acute myocardial infarction influences long-term outcome: a prospective cohort study from the Register of Information and Knowledge About Swedish Heart Intensive Care Admissions (RIKS-HIA). Circulation. 2005 Nov 2;112(21):3225–31. doi: 10.1161/circulationaha.105.552984. PMID: 16301355. Exclusion Code: X2.16301355
314 Stergiou GS, Karpettas N, Protogerou A, . Diagnostic accuracy of a home blood pressure monitor to detect atrial fibrillation. J Hum Hypertens. 2009 Oct;23(10):654–8. doi: 10.1038/jhh.2009.5. PMID: 19279661. Exclusion Code: X4.19279661
315 Stiffman MN. Risk of stroke in patients with atrial fibrillation. J Fam Pract. 1998 Jul;47(1):10–1. PMID: 9673595. Exclusion Code: X7.9673595
316 Suarez-Pinilla M, Fernandez-Rodriguez A, Benavente-Fernandez L, . Vitamin K antagonist-associated intracerebral hemorrhage: lessons from a devastating disease in the dawn of the new oral anticoagulants. J Stroke Cerebrovasc Dis. 2014 Apr;23(4):732–42. doi: 10.1016/j.jstrokecerebrovasdis.2013.06.034. PMID: 23954605. Exclusion Code: X6.23954605
317 Sudlow M, Rodgers H, Kenny RA, . Identification of patients with atrial fibrillation in general practice: a study of screening methods. BMJ. 1998 Aug 1;317(7154):327–8. PMID: 9685281. Exclusion Code: X5.9685281
318 Suzuki M, Fukamizu S, Oyama J, . Rationale and design of the efficacy of rivaroxaban on renal function in patients with non-valvular atrial fibrillation and chronic kidney disease: The X-NOAC study. Int J Cardiol. 2015 Jun 1;188:52–3. doi: 10.1016/j.ijcard.2015.04.037. PMID: 25889327. Exclusion Code: X4.25889327
319 Suzuki S, Otsuka T, Sagara K, . Nine-Year Trend of Anticoagulation Use, Thromboembolic Events, and Major Bleeding in Patients With Non-Valvular Atrial Fibrillation- Shinken Database Analysis. Circ J. 2016;80(3):639–49. doi: 10.1253/circj.CJ-15-1237. PMID: 26794283. Exclusion Code: X4.26794283
320 Svennberg E, Engdahl J, Al-Khalili F, . Mass Screening for Untreated Atrial Fibrillation: The STROKESTOP Study. Circulation. 2015 Jun 3;131(25):2176–84. doi: 10.1161/circulationaha.114.014343. PMID: 25910800. Exclusion Code: X5.25910800
321 Taillandier S, Olesen JB, Clementy N, . Prognosis in patients with atrial fibrillation and CHA2DS2-VASc Score = 0 in a community-based cohort study. J Cardiovasc Electrophysiol. 2012 Jul;23(7):708–13. doi: 10.1111/j.1540-8167.2011.02257.x. PMID: 22268375. Exclusion Code: X7.22268375
322 Tawfik A, Bielecki JM, Krahn M, . Systematic review and network meta-analysis of stroke prevention treatments in patients with atrial fibrillation. Clin Pharmacol. 2016;8:93–107. doi: 10.2147/cpaa.s105165. PMID: 27570467. Exclusion Code: X11.27570467
323 Testa L, Agnifili M, Latini RA, . Adjusted indirect comparison of new oral anticoagulants for stroke prevention in atrial fibrillation. QJM. 2012 Oct;105(10):949–57. doi: 10.1093/qjmed/hcs114. PMID: 22771555. Exclusion Code: X4.22771555
324 Testa L, Agnifili M, Latini RA, . Adjusted indirect comparison of new oral anticoagulants for stroke prevention in atrial fibrillation (Structured abstract). QJM. 2012;105(10):949–57. PMID: DARE-12012048316. Exclusion Code: X4.22771555
325 Thibault B, Talajic M, Dubuc M, . Thromboembolic events occur despite sinus rhythm maintenance in patients treated for atrial fibrillation: The Canadian Trial of Atrial Fibrillation experience. Can J Cardiol. 2004 Feb;20(2):195–9. PMID: 15010743. Exclusion Code: X3.15010743
326 Thom H, Lu G. Rapid and automated test for connectedness of evidence networks in network meta analysis. Value Health. 2015;18(7):A727. PMID: CN-01126861. Exclusion Code: X3.
327 Thomson R. How can epidemiological studies help us to prevent stroke? The example of atrial fibrillation. Age Ageing. 2002 Nov;31 Suppl 3:9–16. PMID: 12450922. Exclusion Code: X7.12450922
328 Thomson R, Eccles M, Wood R, . A cautionary note on data sources for evidence-based clinical decisions: warfarin and stroke prevention. Med Decis Making. 2007 Jul–Aug;27(4):438–47. doi: 10.1177/0272989x07302166. PMID: 17641140. Exclusion Code: X3.17641140
329 Tsoukas GO, Blais C, Gagnon R, . The impact of pharmacotherapy on long-term survival and risk of re-hospitalization for stroke after hospitalization for atrial fibrillation. Can J Cardiol. 2014;30(10 suppl. 1):S132–s3. PMID: CN-01023554. Exclusion Code: X7.
330 Tu RH, Zhong GQ, Zeng ZY, . A meta-analysis on efficacy of anti-platelet agents and anticoagulants for preventing stroke in patients with nonvalvular atrial fibrillation (Provisional abstract). Chinese Journal of Cardiology. 2011;39(3):262–7. PMID: DARE-12012000421. Exclusion Code: X1.21609534
331 Turakhia MP, Ullal AJ, Hoang DD, . Feasibility of extended ambulatory electrocardiogram monitoring to identify silent atrial fibrillation in high-risk patients: the Screening Study for Undiagnosed Atrial Fibrillation (STUDY-AF). Clin Cardiol. 2015 May;38(5):285–92. doi: 10.1002/clc.22387. PMID: 25873476. Exclusion Code: X2.25873476
332 Uchino K, Hernandez AV. Dabigatran association with higher risk of acute coronary events: meta-analysis of noninferiority randomized controlled trials. Arch Intern Med. 2012 Mar 2;172(5):397–402. doi: 10.1001/archinternmed.2011.1666. PMID: 22231617. Exclusion Code: X4.22231617
333 Uittenbogaart SB, Verbiest-van Gurp N, Erkens PM, . Detecting and Diagnosing Atrial Fibrillation (D2AF): study protocol for a cluster randomised controlled trial. Trials. 2015;16:478. doi: 10.1186/s13063-015-1006-5. PMID: 26499449. Exclusion Code: X5.26499449
334 Viitaniemi M, Eskola K, Kurunmaki H, . Anticoagulant treatment of patients with atrial fibrillation in primary health care. Scand J Prim Health Care. 1999 Mar;17(1):59–63. PMID: 10229996. Exclusion Code: X4.10229996
335 Villines T, Peacock W. Safety of direct oral anticoagulants: insights from postmarketing studies. Am J Med. 2017;129(11 Supplement):S41–s6. doi: 10.1016/j.amjmed.2016.06.004. PMID: CN-01247709. Exclusion Code: X4.
336 Violi F, Davi G, Proietti M, . Ankle-Brachial Index and cardiovascular events in atrial fibrillation: the ARAPACIS study. Thromb Haemost. 2016;115(4):856–63. doi: 10.1160/TH15-07-0612. PMID: CN-01159711. Exclusion Code: X3.26740316
337 Voller H, Glatz J, Taborski U, . Self-management of oral anticoagulation in nonvalvular atrial fibrillation (SMAAF study). Z Kardiol. 2005 Mar;94(3):182–6. doi: 10.1007/s00392-005-0199-0. PMID: 15747040. Exclusion Code: X4.15747040
338 Vora AN, Alexander JH, Lopes RD. Dabigatran Compared With Rivaroxaban vs Warfarin. JAMA Intern Med. 2017 May 1;177(5):742–3. doi: 10.1001/jamainternmed.2017.0561. PMID: 28460098. Exclusion Code: X7.28460098
339 Wagstaff AJ, Overvad TF, Lip GY, . Is female sex a risk factor for stroke and thromboembolism in patients with atrial fibrillation? A systematic review and meta-analysis. QJM. 2014 Dec;107(12):955–67. doi: 10.1093/qjmed/hcu054. PMID: 24633256. Exclusion Code: X4.24633256
340 Waldo AL, Becker RC, Tapson VF, . Hospitalized patients with atrial fibrillation and a high risk of stroke are not being provided with adequate anticoagulation. J Am Coll Cardiol. 2005 Nov 1;46(9):1729–36. doi: 10.1016/j.jacc.2005.06.077. PMID: 16256877. Exclusion Code: X7.16256877
341 Walfridsson H, Johansson B, Englund A, . Effects of AZD0837, a novel direct thrombin inhibitor, on the electrophysiological properties of the human heart: a randomized, double-blind, parallel-group, placebo-controlled study. Clin Drug Investig. 2010;30(7):461–71. doi: 10.2165/11536300-000000000-00000. PMID: 20528001. Exclusion Code: X2.20528001
342 Wandell P, Carlsson AC, Holzmann M, . Association between antithrombotic treatment and hemorrhagic stroke in patients with atrial fibrillation-a cohort study in primary care. Eur J Clin Pharmacol. 2017 Feb;73(2):215–21. doi: 10.1007/s00228-016-2152-8. PMID: 27826643. Exclusion Code: X7.27826643
343 Wandell P, Carlsson AC, Sundquist K, . Effect of cardiovascular drug classes on all-cause mortality among atrial fibrillation patients treated in primary care in Sweden: a cohort study. Eur J Clin Pharmacol. 2013 Feb;69(2):279–87. doi: 10.1007/s00228-012-1395-2. PMID: 22990327. Exclusion Code: X7.22990327
344 Wang TH, Bhatt DL, Fox KA, . An analysis of mortality rates with dual-antiplatelet therapy in the primary prevention population of the CHARISMA trial. Eur Heart J. 2007 Sep;28(18):2200–7. doi: 10.1093/eurheartj/ehm274. PMID: 17673448. Exclusion Code: X4.17673448
345 Wang TJ, Massaro JM, Levy D, . A risk score for predicting stroke or death in individuals with new-onset atrial fibrillation in the community: the Framingham Heart Study. JAMA. 2003 Aug 7;290(8):1049–56. doi: 10.1001/jama.290.8.1049. PMID: 12941677. Exclusion Code: X3.12941677
346 Warkentin AE, Donadini MP, Spencer FA, . Bleeding risk in randomized controlled trials comparing warfarin and aspirin: a systematic review and meta-analysis (Structured abstract). J Thromb Haemost. 2012;10(4):512–20. PMID: DARE-12012020168. Exclusion Code: X4.22257078
347 Wasserlauf G, Grandi SM, Filion KB, . Meta-analysis of rivaroxaban and bleeding risk (Structured abstract). Am J Cardiol. 2013;112(3):454–60. PMID: DARE-12013025396. Exclusion Code: X4.23642380
348 Wheeldon NM. Atrial fibrillation and anticoagulant therapy. Eur Heart J. 1995 Mar;16(3):302–12. PMID: 7789371. Exclusion Code: X7.7789371
349 Wheeldon NM, Tayler DI, Anagnostou E, . Screening for atrial fibrillation in primary care. Heart. 1998 Jan;79(1):50–5. PMID: 9505919. Exclusion Code: X4.9505919
350 White RH, McBurnie MA, Manolio T, . Oral anticoagulation in patients with atrial fibrillation: adherence with guidelines in an elderly cohort. Am J Med. 1999 Feb;106(2):165–71. PMID: 10230745. Exclusion Code: X3.10230745
351 Wieloch M, Sjalander A, Frykman V, . Anticoagulation control in Sweden: reports of time in therapeutic range, major bleeding, and thrombo-embolic complications from the national quality registry AuriculA. Eur Heart J. 2011 Sep;32(18):2282–9. doi: 10.1093/eurheartj/ehr134. PMID: 21616951. Exclusion Code: X4.21616951
352 Wiesel J, Abraham S, Messineo FC. Screening for asymptomatic atrial fibrillation while monitoring the blood pressure at home: trial of regular versus irregular pulse for prevention of stroke (TRIPPS 2.0). Am J Cardiol. 2013 Jun 1;111(11):1598–601. doi: 10.1016/j.amjcard.2013.01.331. PMID: 23499278. Exclusion Code: X4.23499278
353 Woodhouse L, Appleton J, Dineen R, . Comparisons of outcomes in patients with atrial fibrillation or requiring carotid endarterectomy: results from the triple antiplatelets for reducing dependency after ischaemic stroke (TARDIS) trial. European Stroke Journal. 2016;1(Suppl 1):678. PMID: CN-01164948. Exclusion Code: X2.
354 Wright J, Bibby J, Eastham J, . Multifaceted implementation of stroke prevention guidelines in primary care: cluster-randomised evaluation of clinical and cost effectiveness. Qual Saf Health Care. 2007 Feb;16(1):51–9. doi: 10.1136/qshc.2006.019778. PMID: 17301206. Exclusion Code: X4.17301206
355 Wu J, Wang J, Jiang S, . The efficacy and safety of low intensity warfarin therapy in Chinese elderly atrial fibrillation patients with high CHADS2 risk score. Int J Cardiol. 2013 Sep 0;167(6):3067–8. doi: 10.1016/j.ijcard.2012.11.078. PMID: 23200268. Exclusion Code: X4.23200268
356 Wyse DG. Bleeding while starting anticoagulation for thromboembolism prophylaxis in elderly patients with atrial fibrillation: from bad to worse. Circulation. 2007 May 9;115(21):2684–6. doi: 10.1161/circulationaha.107.704122. PMID: 17533193. Exclusion Code: X7.17533193
357 Yamashita T, Koretsune Y, Yang Y, . Edoxaban vs. Warfarin in east asian patients with atrial fibrillation - An ENGAGE AF-TIMI 48 subanalysis. Circ J. 2016;80(4):860–9. doi: 10.1253/circj.CJ-15-1082. PMID: CN-01141783. Exclusion Code: X4.26888149
358 Yamashita Y, Hamatani Y, Esato M, . Clinical Characteristics and Outcomes in Extreme Elderly (Age >/= 85 Years) Japanese Patients With Atrial Fibrillation: The Fushimi AF Registry. Chest. 2016 Feb;149(2):401–12. doi: 10.1378/chest.15-1095. PMID: 26181726. Exclusion Code: X4.26181726
359 Yamashita Y, Takagi D, Hamatani Y, . Clinical characteristics and outcomes of dialysis patients with atrial fibrillation: the Fushimi AF Registry. Heart Vessels. 2017;31(12):2025–34. doi: 10.1007/s00380-016-0818-x. PMID: CN-01288574. Exclusion Code: X2.
360 Yang YM, Shao XH, Zhu J, . Risk factors and incidence of stroke and MACE in Chinese atrial fibrillation patients presenting to emergency departments: a national wide database analysis. Int J Cardiol. 2014 May 1;173(2):242–7. doi: 10.1016/j.ijcard.2014.02.040. PMID: 24630382. Exclusion Code: X6.24630382
361 Yang YM, Shao XH, Zhu J, . One-Year Outcomes of Emergency Department Patients With Atrial Fibrillation: A Prospective, Multicenter Registry in China. Angiology. 2015 Sep;66(8):745–52. doi: 10.1177/0003319714553936. PMID: 25344528. Exclusion Code: X6.25344528
362 Yoon CW, Kim SJ, Bang OY, . Premorbid warfarin use and lower D-dimer levels are associated with a spontaneous early improvement in an atrial fibrillation-related stroke. J Thromb Haemost. 2012 Nov;10(11):2394–6. doi: 10.1111/j.1538-7836.2012.04909.x. PMID: 22925077. Exclusion Code: X2.22925077
363 Yu HC, Tsai YF, Chen MC, . Underuse of antithrombotic therapy caused high incidence of ischemic stroke in patients with atrial fibrillation. Int J Stroke. 2012 Feb;7(2):112–7. doi: 10.1111/j.1747-4949.2011.00667.x. PMID: 22103748. Exclusion Code: X7.22103748
364 Zhao YJ, Lim WS. Dabigatran Compared With Rivaroxaban vs Warfarin. JAMA Intern Med. 2017 May 01;177(5):742. doi: 10.1001/jamainternmed.2017.0564. PMID: 28460099. Exclusion Code: X7.28460099
365 Ziadeh M, Burcu M, Oehrlein E, . Novel oral anticoagulants and risk of gastrointestinal bleeding: a systematic review. Pharmacoepidemiol Drug Saf. 2017;25:571. doi: 10.1002/pds.4070. PMID: CN-01293654. Exclusion Code: X4.
366 Zolfaghari S Jr, Harenberg J, Marx S, . Indirect comparisons of the new oral anticoagulants in patients with non-valvular atrial fibrillation. Blood. 2012;120(21) PMID: CN-01008485. Exclusion Code: X4.
367 Zubaid M, Rashed WA, Alsheikh-Ali AA, . Management and 1-year outcomes of patients with atrial fibrillation in the Middle East: Gulf survey of atrial fibrillation events. Angiology. 2015 May;66(5):464–71. doi: 10.1177/0003319714536980. PMID: 24904179. Exclusion Code: X4.24904179