# Appendix B Detailed Methods

## Appendix B1 Original Search Strategies

PubMed, 7/12/16

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Atrial Fibrillation”[Mesh] OR atrial fibril*[tiab] OR atrium fibrillation*[tiab] OR a-fib[tiab] OR atrial flutter*[tiab]) | 60865 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Electrocardiography”[Mesh] OR electrocardiography[tiab] OR EKG[tiab] OR ECG[tiab]) | 209997 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 13398 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Mass Screening”[Mesh] OR screen*[tiab]) | 591510 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) | 314 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “Controlled Clinical Trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 642006 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 and #6) | 22 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | 1902550 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 and #8) | 128 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) | 140 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) Filters: Humans | 138 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) Filters: Humans; English | 132 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) Filters: Humans; English; Adult: 19+ years | 126 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Anticoagulants”[Mesh] OR anticoagulant*[tiab] OR “Warfarin”[Mesh] OR warfarin OR noac* OR (“Dabigatran”[Mesh] or Dabigatran OR Pradaxa) OR apixaban OR Eliquis OR “Rivaroxaban”[Mesh] OR Rivaroxaban[tiab] OR Xarelto[tiab]) | 103597 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #14) | 10286 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Factor Xa Inhibitors”[Mesh] OR “factor xa”[tiab]) | 7468 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #16) | 839 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Antithrombins”[Mesh] OR antithrombin*[tiab] OR thrombin inhibit*[tiab]) | 22731 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #18) | 1348 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Aspirin”[Mesh] OR aspirin[tiab] OR anti-platelet*[tiab] OR antiplatelet*[tiab] OR Plavix[tiab] OR ASA[tiab] OR “acetylsalicylic acid”[tiab] OR “Aspirin, Dipyridamole Drug Combination”[Mesh] OR Aggrenox[tiab] OR “Dipyridamole”[Mesh] OR Dipyridamole[tiab] OR “clopidogrel”[Supplementary Concept] OR clopidogrel[tiab]) | 104013 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #20) | 2998 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 or #17 or #19 or #21) | 11039 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#22 and #6) | 798 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#22 and #8) | 2431 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 180177 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#22 and #25) | 438 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#22 and #25) Filters: Publication date from 2011/01/01 to 2016/12/31 | 294 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 | Search (#23 or #24 or #27) | 3191
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#23 or #24 or #27) Filters: Humans | 3060 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#23 or #24 or #27) Filters: Humans; English | 2785 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#23 or #24 or #27) Filters: Humans; English; Adult: 19+ years | 2378 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#30 not #13) | 2358 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)

PubMed, 5/22/17

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Atrial Fibrillation”[Mesh] OR atrial fibril*[tiab] OR atrium fibrillation*[tiab] OR a-fib[tiab] OR atrial flutter*[tiab]) | 65870 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Electrocardiography”[Mesh] OR electrocardiography[tiab] OR EKG[tiab] OR ECG[tiab])) | 215045 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 14014 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh] OR screen*[tiab])) | 629166 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) | 352 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “Controlled Clinical Trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 671738 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 and #6) | 27 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | 2020073 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 and #8) | 138 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) | 155 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) Filters: Humans | 150 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) Filters: Humans; English | 144 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) Filters: Humans; English; Adult: 19+ years | 137 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 or #9) Filters: Publication date from 2016/01/01 to 2017/12/31; Humans; English; Adult: 19+ years | 8 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Anticoagulants”[Mesh] OR anticoagulant*[tiab] OR “Warfarin”[Mesh] OR warfarin OR noac* OR (“Dabigatran”[Mesh] or Dabigatran OR Pradaxa) OR apixaban OR Eliquis OR “Rivaroxaban”[Mesh] OR Rivaroxaban[tiab] OR Xarelto[tiab]) | 108637 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #15) | 11590 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Factor Xa Inhibitors”[Mesh] OR “factor xa”[tiab])) | 7957 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #17) | 1003 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Antithrombins”[Mesh] OR antithrombin*[tiab] OR thrombin inhibit*[tiab])) | 23617 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #19) | 1571 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Aspirin”[Mesh] OR aspirin[tiab] OR anti-platelet*[tiab] OR antiplatelet*[tiab] OR Plavix[tiab] OR ASA[tiab] OR “acetylsalicylic acid”[tiab] OR “Aspirin, Dipyridamole Drug Combination”[Mesh] OR Aggrenox[tiab] OR “Dipyridamole”[Mesh] OR Dipyridamole[tiab] OR “clopidogrel”[Supplementary Concept] OR clopidogrel[tiab])) | 108308 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #21) | 3234 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#16 or #18 or #20 or #22) | 12388 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#23 and #6) | 864 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#23 and #8) | 2756 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields])) | 204884 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#23 and #26) | 527 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 | Search (#24 or #25 or #27) | 3749 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#24 or #25 or #27) Filters: Humans | 3579 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#24 or #25 or #27) Filters: Humans; English | 3260 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#24 or #25 or #27) Filters: Humans; English; Adult: 19+ years | 2731 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#24 or #25 or #27) Filters: Publication date from 2016/01/01 to 2017/12/31; Humans; English; Adult: 19+ years | 260 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 | Search (#32 NOT #14) | 259 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)

Cochrane Library, 7/12/16

ID | Search | Hits
#1 | [mh “Atrial Fibrillation”] or (“atrial fibril*” or “atrium fibrillation*” or a-fib or afib or “atrial flutter*”) | 7088
#2 | [mh Electrocardiography] or electrocardiography or EKG or ECG | 13719
#3 | #1 and #2 | 1171
#4 | [mh “Mass Screening”] or screen* | 37027
#5 | #3 and #4 | 115
#6 | (((randomized or randomised) and controlled and trial) or (controlled and trial) or “Controlled Clinical Trial” or “Randomized Controlled Trial” or [mh “Single-Blind Method”] or [mh “Double-Blind Method”] or [mh “Random Allocation”]) | 675537
#7 | #5 and #6 Publication Year from 2011 to 2016 | 72
#8 | [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-up Studies”] or “prospective cohort” or [mh “prospective studies”] or (prospective* and cohort and (study or studies)) | 139074
#9 | #5 and #8 | 35
#10 | [mh Anticoagulants] or anticoagulant* or [mh Warfarin] or warfarin or noac* or [mh Dabigatran] or Dabigatran or Pradaxa or apixaban or Eliquis or [mh Rivaroxaban] or Rivaroxaban or Xarelto | 9813
#11 | #1 and #10 | 1591
#12 | [mh “Factor Xa Inhibitors”] or “factor xa” | 782
#13 | #1 and #12 | 160
#14 | [mh Antithrombins] or antithrombin* or “thrombin inhibit*” | 2295
#15 | #1 and #14 | 215
#16 | [mh Aspirin] or aspirin or “anti-platelet*” or antiplatelet* or Plavix or ASA or “acetylsalicylic acid” or [mh “Aspirin, Dipyridamole Drug Combination”] or Aggrenox or [mh Dipyridamole] or Dipyridamole or clopidogrel | 23614
#17 | #1 and #16 | 754
#18 | #11 or #13 or #15 or #17 | 1809
#19 | #18 Publication Year from 2011 to 2016, in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 192
#20 | #18 and (#6 or #8) | 1374
#21 | #20 not #19 | 1227
#22 | #21 Publication Year from 2011 to 2016 | 701

Cochrane Library, 5/23/17

ID | Search | Hits
#1 | [mh “Atrial Fibrillation”] or (“atrial fibril*” or “atrium fibrillation*” or a-fib or afib or “atrial flutter*”) | 8442
#2 | [mh Electrocardiography] or electrocardiography or EKG or ECG | 14832
#3 | #1 and #2 | 1354
#4 | [mh “Mass Screening”] or screen* | 42666
#5 | #3 and #4 | 149
#6 | (((randomized or randomised) and controlled and trial) or (controlled and trial) or “Controlled Clinical Trial” or “Randomized Controlled Trial” or [mh “Single-Blind Method”] or [mh “Double-Blind Method”] or [mh “Random Allocation”]) | 767332
#7 | #5 and #6 Publication Year from 2016 to 2017 | 48
#8 | [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-up Studies”] or “prospective cohort” or [mh “prospective studies”] or (prospective* and cohort and (study or studies)) | 149954
#9 | #5 and #8 | 42
#10 | [mh Anticoagulants] or anticoagulant* or [mh Warfarin] or warfarin or noac* or [mh Dabigatran] or Dabigatran or Pradaxa or apixaban or Eliquis or [mh Rivaroxaban] or Rivaroxaban or Xarelto | 11249
#11 | #1 and #10 | 2038
#12 | [mh “Factor Xa Inhibitors”] or “factor xa” | 954
#13 | #1 and #12 | 229
#14 | [mh Antithrombins] or antithrombin* or “thrombin inhibit*” | 2505
#15 | #1 and #14 | 260
#16 | [mh Aspirin] or aspirin or “anti-platelet*” or antiplatelet* or Plavix or ASA or “acetylsalicylic acid” or [mh “Aspirin, Dipyridamole Drug Combination”] or Aggrenox or [mh Dipyridamole] or Dipyridamole or clopidogrel | 25992
#17 | #1 and #16 | 938
#18 | #11 or #13 or #15 or #17 | 2297
#19 | #18 Publication Year from 2016 to 2017, in Cochrane Reviews (Reviews and Protocols) | 59
#20 | #18 and (#6 or #8) | 1834
#21 | #20 not #19 | 1775
#22 | #21 Publication Year from 2016 to 2017 | 418

### Gray Literature Searches, July 15-22, 2016 ClinicalTrials.gov Searches Advanced Search

Limit to

Adults

Last Updated 01/01/2011 – 12/31/2016

[underlined: Screening]

CONDITION box: atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

INTERVENTION box: electrocardiography OR EKG OR ECG

Translates to in CT.gov:

atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter* | electrocardiography OR EKG OR ECG | Adult | Studies updated from 01/01/2011 to 12/31/2016

81 studies, all imported

[underlined: Treatment]

CONDITION box: atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

INTERVENTION box: anticoagulant* OR "Warfarin" OR warfarin OR noac* OR Dabigatran OR Pradaxa OR apixaban OR Eliquis OR Rivaroxaban OR Xarelto OR "factor xa" OR antithrombin* OR thrombin inhibit* OR aspirin OR anti-platelet* OR antiplatelet* OR Plavix OR ASA OR "acetylsalicylic acid" OR Aggrenox OR Dipyridamole OR clopidogrel

232 studies, 230 imported

REDONE WITH SENIORS:

[underlined: Screening:]

atrial fibril* OR atrial fibrillation OR atrium fibrillation* OR a-fib OR atrial flutter* | electrocardiography OR EKG OR ECG | Adult, Senior | Studies updated from 01/01/2011 to 12/31/2016

85 results, all imported

[underlined: Treatment:]

atrial fibril* OR atrial fibrillation OR atrium fibrillation* OR a-fib OR atrial flutter* | anticoagulant* OR "Warfarin" OR warfarin OR noac* OR Dabigatran OR Pradaxa OR apixaban OR Eliquis OR Rivaroxaban OR Xarelto OR "factor xa" OR antithrombin* OR thrombin inhibit* OR aspirin OR anti-platelet* OR antiplatelet* OR Plavix OR ASA OR "acetylsalicylic acid" OR Aggrenox OR Dipyridamole OR clopidogrel | Adult, Senior | Studies updated from 01/01/2011 to 12/31/2016

239 results, 237 imported. 2 were duplicates with the screening search.

WHO ICRTRP Advanced searches, July 15-22, 2016

[underlined: Screening]

Recruitment status: ALL

Date of registration is between 01/01/2011 – 31/12/2016

Condition box: atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

Intervention box: electrocardiography OR EKG OR ECG

0 results.

Tried searching the intervention terms in Title box: electrocardiography OR EKG OR ECG

Condition box: atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

1 result, imported

[underlined: Treatment:]

In Title box:

anticoagulant* OR "Warfarin" OR warfarin OR noac* OR Dabigatran OR Pradaxa OR apixaban OR Eliquis OR Rivaroxaban OR Xarelto OR "factor xa" OR antithrombin* OR thrombin inhibit* OR aspirin OR anti-platelet* OR antiplatelet* OR Plavix OR ASA OR "acetylsalicylic acid" OR Aggrenox OR Dipyridamole OR clopidogrel

In Condition box:

atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

19 results, 9 imported

### Gray Literature Searches, May 24, 2017 ClinicalTrials.gov Searches Advanced Search

Limit to

Adults

Last Updated 01/01/2016 – 12/31/2017

[underlined: Screening]

CONDITION box: atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

INTERVENTION box: electrocardiography OR EKG OR ECG

Translates to in ClinicalTrials.gov

atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter* | electrocardiography OR EKG OR ECG | Adult, Senior | Studies updated from 01/01/2016 to 12/31/2017

22 studies, all imported

[underlined: Treatment]

CONDITION box: atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

INTERVENTION box: anticoagulant* OR "Warfarin" OR warfarin OR noac* OR Dabigatran OR Pradaxa OR apixaban OR Eliquis OR Rivaroxaban OR Xarelto OR "factor xa" OR antithrombin* OR thrombin inhibit* OR aspirin OR anti-platelet* OR antiplatelet* OR Plavix OR ASA OR "acetylsalicylic acid" OR Aggrenox OR Dipyridamole OR clopidogrel

Translates to in ClinicalTrials.gov

atrial fibril* OR atrial fibrillation OR atrium fibrillation* OR a-fib OR atrial flutter* | anticoagulant* OR "Warfarin" OR warfarin OR noac* OR Dabigatran OR Pradaxa OR apixaban OR Eliquis OR Rivaroxaban OR Xarelto OR "factor xa" OR antithrombin* OR thrombin inhibit* OR aspirin OR anti-platelet* OR antiplatelet* OR Plavix OR ASA OR "acetylsalicylic acid" OR Aggrenox OR Dipyridamole OR clopidogrel | Adult, Senior | Studies updated from 01/01/2016 to 12/31/2017

71 results, 70 imported

### WHO ICRTRP Advanced searches, May 24, 2017

Advanced search, Recruitment status: ALL

Date of registration is between 01/01/2016 – 12/31/2017

[underlined: Screening:]

Condition box: atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

Intervention box: electrocardiography OR EKG OR ECG

21 results, all imported

Also performed the search with the intervention terms in Title box: electrocardiography OR EKG OR ECG

Condition box: atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

6 results, 1 imported

[underlined: Treatment]

In Title box:

anticoagulant* OR "Warfarin" OR warfarin OR noac* OR Dabigatran OR Pradaxa OR apixaban OR Eliquis OR Rivaroxaban OR Xarelto OR "factor xa" OR antithrombin* OR thrombin inhibit* OR aspirin OR anti-platelet* OR antiplatelet* OR Plavix OR ASA OR "acetylsalicylic acid" OR Aggrenox OR Dipyridamole OR clopidogrel

In Condition box:

atrial fibril* OR atrium fibrillation* OR a-fib OR atrial flutter*

74 results, all imported

## Appendix B2 Eligibility Criteria

| Include | Exclude
Condition definition | Atrial fibrillation (paroxysmal or persistent) | Other cardiac arrhythmias, nonarrhythmia-related CVD (e.g., coronary heart disease, hypertension)
Populations | KQs 1–3: Unselected or explicitly asymptomatic older adults (age 65 years or older); older adults selected for increased risk of nonvalvular atrial fibrillation (e.g., those with obesity, smoking, alcohol use, hypertension); studies of mixed populations of asymptomatic and symptomatic persons are eligible if results are reported separately for asymptomatic persons or less than 10% of the sample is symptomatic. KQs 4, 5: Older adults with atrial fibrillation. To approximate screen-detected persons with atrial fibrillation, we will aim to stratify analyses based on whether participants are asymptomatic/screen-detected vs. symptomatic (if possible); however, knowing that most studies enroll mixed populations or do not clearly enroll screen-detected or asymptomatic populations, we will not exclude studies based on whether participants were screen detected. To approximate “screening” vs. “disease management” populations, we will limit our analyses to studies of individuals not selected because of known heart disease, heart failure, and/or previous stroke or transient ischemic attack | KQs 1–3: Symptomatic adults; adults with known (history of) atrial fibrillation; children, adolescents, and adults age 65 years or older; adults at high(est) risk for atrial fibrillation (including but not limited to those with mitral valve disease or repair/replacement); and adults with history of stroke or transient ischemic attack KQs 4, 5: Adults needing antiplatelet or anticoagulation medications for conditions other than atrial fibrillation; adults with atrial fibrillation and known heart disease, heart failure, and/or previous stroke or transient ischemic attack
Screening test or intervention | KQs 1–3: Systematic ECG screening using any approach (e.g., in-office single-application 12-lead ECG, continuous ECG, intermittent use of handheld ECG); systematic screening with both pulse palpation and ECG for all participants KQs 4, 5: Medical treatment with antiplatelet agents (aspirin) or anticoagulants (apixaban, dabigatran, edoxaban, rivaroxaban, warfarin). Results will be stratified by type of medication. | KQs 1–3: Physical examination (including pulse palpation); blood pressure monitoring; pulse oximetry; all other technologies (e.g., consumer devices, such as smartphones); studies that only use ECG for participants with irregular pulse (as opposed to all participants) KQs 4, 5: Nonpharmacologic treatment to prevent stroke (e.g., implantable devices), treatment or management of atrial fibrillation for reasons other than prevention of stroke (e.g., rate or rhythm control, cardioversion, ablation), combinations of treatment (e.g., aspirin plus warfarin)
Comparisons | KQs 1–3: Screened vs. nonscreened groups, systematic screening vs. opportunistic screening (as defined by the primary study), systematic screening vs. usual care (which may include pulse palpation, automated blood pressure measurement, or cardiac auscultation during the course of a physical examination, or examination for another reason, with subsequent ECG if an irregular heart beat or pulse is noted) KQs 4, 5: No treatment | All KQs: No comparison, nonconcordant historical control KQs 4, 5: Active treatment (i.e., antiplatelet or anticoagulation medications)
Outcomes | KQ 1: All-cause mortality, stroke, and stroke-related morbidity or mortality KQ 2: Comparative/relative yield (i.e., number of persons diagnosed with atrial fibrillation in one group vs. another [unscreened/differently screened] group) KQ 3: Anxiety, labeling, harms of subsequent procedures or interventions initiated as a result of screening (e.g., subsequent ablation with complications) KQ 4: All-cause mortality, cardioembolic stroke, and cardioembolic stroke-related morbidity or mortality KQ 5: Any harms requiring unexpected or unwanted medical attention (e.g., hemorrhagic stroke, major bleeding, allergic reaction) | KQs 3, 5: Nonserious events (e.g., bleeding not requiring or resulting in medical attention)
Study designs | All KQs: Randomized, controlled trials and controlled clinical trials KQs 2, 3: Large prospective cohort studies are also eligible KQ 4: Systematic reviews^a^ of trials are also eligible KQ 5: Systematic reviews^a^ of trials, systematic reviews^a^ of observational studies, and large prospective cohort studies are also eligible | All other designs, narrative reviews, case reports, case series, editorials, letters, cross-sectional studies, case-control studies, and retrospective cohort studies
Setting | KQs 1–3: Studies performed in primary care settings KQs 4, 5: Studies performed in primary care or specialty settings | KQs 1–3: Studies performed in specialty settings, studies of patients undergoing preoperative evaluation, and inpatient settings KQs 4, 5: Studies conducted primarily in inpatient settings
Country | Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Program) | Studies conducted in countries that are not categorized as “Very High” on the 2014 Human Development Index
Language | English | Non-English
Study quality | Good or fair | Poor (according to design-specific USPSTF criteria)

a We assessed the relevance of systematic reviews (as described in the Methods) to address KQs 4 and 5 to determine their eligibility.

Abbreviations: CVD=cardiovascular disease; ECG=electrocardiogram; KQ=key question; USPSTF=U.S. Preventive Services Task Force.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

### Definition of Ratings Based on Above Criteria

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor:: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Sources: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^81^; Harris et al, 2001.^82^

### Systematic Reviews Criteria

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

### Definition of Ratings Based on Above Criteria

Good:: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
Fair:: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
Poor:: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

Sources: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^81^; Harris et al, 2001.^82^