# Appendix A Additional Background, Summary of Guidelines From Other Groups, and Contextual Questions

## Prevalence

On the basis of 1990s data from 1.89 million adult members of a health maintenance organization in California, the AnTicoagulation and Risk factors In Atrial fibrillation (ATRIA) study reported a prevalence of diagnosed AF among the general population of 0.95 percent, increasing with age (Appendix A Table 1).^1^ The ATRIA study also identified differences in AF prevalence based on race. Although African American and white patients between 50 and 59 years of age patients had similar rates of AF, higher rates were reported among white patients in older age groups: 1.8 percent versus 1.3 percent in patients ages 60 to 69 years, 5.2 percent versus 4.4 percent in patients ages 70 to 79 years, and 9.9 percent versus 7.7 percent among those age 80 years or older.^1^

Appendix A Table 1 Prevalence of Atrial Fibrillation by Age and Sex in the ATRIA Study^1^

Age Band (years) | Prevalence in Women (%) | Prevalence in Men (%)
<55 | 0.1 | 0.2
55–59 | 0.4 | 0.9
60–64 | 1.0 | 1.7
65–69 | 1.7 | 3.0
70–74 | 3.4 | 5.0
75–79 | 5.0 | 7.3
80–84 | 7.2 | 10.3
≥85 | 9.1 | 11.1

Abbreviation: ATRIA=AnTicoagulation and Risk factors In Atrial fibrillation.

Appendix A Table 2 Validated Risk Prediction Tools for Stroke Risk

Risk Factor Category | Stroke Risk Tool
Risk Factor Category | CHADS_2_^2^ | CHA_2_DS_2_-VASc^3^ | R_2_CHADS_2_^4^ | QStroke^5^ | ATRIA^a,6^
Risk Factor Category | Scoring/Points
Congestive heart failure | 1 (recent) | 1 (or LV dysfunction) | 1 (recent) | Y/N | 1
Hypertension | 1 (history of) | 1 | 1 (history of) | Continuous (SBP) | 1
Age (years) | 1 (75+) | 1 (65–74) 2 (75+) | 1 (75+) | Range, 25–84 | 6/9 (85+) 5/7 (75–84) 3/7 (65–74) 0/8 (<65)
Diabetes mellitus | 1 | 1 | 1 | Y/N (T1DM, T2DM) | 1
Stroke/TIA/TE | 2 | 2 | 2
Renal dysfunction | | | 2 (creatinine clearance <60 mL/min) | | 1 (proteinuria) 1 (eGFR <45 mL/min/1.73 m^2^ or ESRD)
Sex | | 1 (female) | | Separate models for M/F | 1 (female)
Vascular disease | | 1 (prior MI, PAD, or aortic plaque)
Valvular heart disease | | | | Y/N
Family history CHD | | | | Y/N
TC:HDLC ratio | | | | Continuous
Atrial fibrillation | | | | Y/N
Rheumatoid arthritis | | | | Y/N
BMI | | | | Continuous
Smoking status | | | | 5 categories
Ethnicity | | | | 9 categories
Deprivation | | | | Continuous (TDI score)

a Scored for age categories with/without prior stroke.

Abbreviations: ATRIA=AnTicoagulation and Risk factors In Atrial fibrillation; BMI=body mass index; CHADS_2_= Congestive heart failure, Hypertension, Age≥75 years, Diabetes mellitus, Prior stroke or TIA or thromboembolism; CHA_2_DS_2_-VASc=Congestive heart failure (or left ventricular systolic dysfunction), Hypertension, Age≥75 years, Diabetes mellitus, Prior stroke or TIA or thromboembolism, Vascular disease, Age 65–74 years, Sex category; CHD=coronary heart disease; eGFR=estimated glomerular filtration rate; ESRD=end stage renal disease; HDLC=high density lipoprotein cholesterol; LV=left ventricular; m^2^=square meters; M/F=male/female; MI=myocardial infarction; min=minute; mL=milliliters; PAD=peripheral artery disease; R_2_CHADS_2_=Renal Dysfunction, Congestive Heart Failure, Hypertension, Age, Diabetes, Stroke/Transient Ischemic Attack; SBP=systolic blood pressure; T1DM=type 1 diabetes mellitus; T2DM=type 2 diabetes mellitus; TC=total cholesterol; TDI=Townsend deprivation index; TE=thromboembolism; TIA=transient ischemic attack; Y/N=yes/no.

Appendix A Table 3 Validated Risk Prediction Tools for Bleeding Risk

Risk Factor Category | Bleeding Risk Tool
Risk Factor Category | HAS-BLED^a,7^ | HEMORR_2_HAGES^8^ | ATRIA^9^
Risk Factor Category | Scoring/Points
Hypertension | 1 | 1 (uncontrolled) | 1
Age (years) | 1 (65+ or frail) | 1 (75+) | 2 (75+)
Stroke | 1 | 1
Hepatic and/or renal dysfunction | 1 or 2 | 1 | 3 (severe renal disease)
Ethanol abuse | 1 | 1
Anemia | | 1 | 3
Bleeding-associated factors | 1 (bleeding tendency or predisposition) | 1 (reduced platelet count/function) 2 (rebleeding risk) | 1 (prior hemorrhage)
Malignancy | | 1
Genetic factors (CYP2C9 SNP) | | 1
Excessive fall risk | | 1
Labile INRs (if on warfarin) | 1
Drugs (e.g., anti-platelet or NSAIDs) | 1

a 2013 review by the AHRQ Effective Health Care Program found that, based on limited evidence, the HAS-BLED tool best discriminates the bleeding risk in patients with AF;^10^ recent guidelines from the United Kingdom, Europe, and Canada also recommend its use for the stratification of bleeding risk in AF patients before treatment decisions.^11–13^

Abbreviations: ATRIA=AnTicoagulation and Risk factors In Atrial fibrillation; CYP2C9 SNP=Gene variant (single nucleotide polymorphism) affecting drug metabolism; HAS-BLED=Hypertension, Abnormal renal and liver function, Stroke, Bleeding, Labile international normalized ratios, Elderly, Drugs or alcohol; HEMORR_2_HAGES=Hepatic or renal disease, ethanol abuse, Malignancy, Older age, Reduced platelet count or function, Rebleeding risk, Hypertension, Anemia, Genetic factors, Excessive fall risk, Stroke; INR=International Normalized Ratio, assay used to determine clotting tendency; NSAID=non-steroidal anti-inflammatory drug.

Appendix A Table 4 Recent Recommendations (2010 or newer) on Primary Prevention of Stroke (Including Screening and/or Treatment) in Patients With Atrial Fibrillation

Society or Professional Organization, Year Scope | Screening | Anticoagulation^a^ | Antiplatelet^a^
AF-SCREEN, 2017^14^ Screening for AF | Age >65 years, opportunistic pulse then ECG, single-lead ECG, or patient-activated twice-daily intermittent screening for 2 weeks (for age ≥75 years or those at high stroke risk), | OAC^b^ | Not recommended
WHF, 2017^15^ Management of AF | Age ≥65 years, opportunistic pulse palpation, with ECG as appropriate | VKA or NOAC^b^ | Not recommended
EHRA, 2016-7^16,^ ^17^ Screening for AF | Support the ESC 2016 recommendations; age ≥65 years, opportunistic screening by pulse taking or ECG rhythm strip; systematic ECG screening may be considered in patients ≥75 years or those at high stroke risk | VKA or NOAC^b^ | Not recommended
ESC, 2016^18^ Management of AF | Age ≥65 years, opportunistic screening by pulse taking or ECG rhythm strip; systematic ECG screening may be considered in patients ≥75 years or those at high stroke risk | VKA or NOAC^b^ | Not recommended
EPCCS, 2016^19^ Prevention of stroke in AF | Age ≥65 years, opportunistic case finding with pulse palpation at least yearly, with ECG as appropriate (alternative approach could use modified sphygmomanometers or single-lead ECG devices if they have been subject to validation with 12-lead ECG) | VKA or NOAC^b^ | Not recommended
UK NSC, 2014^21^ Screening for AF | Age ≥65 years, screening not recommended | Not addressed | Not addressed
NICE, 2014^13^ Management of AF | Not directly addressed, pulse palpation for symptoms and ECG when AF is suspected because of irregular pulse (symptomatic or not) | VKA or NOAC^b^ | Not recommended
AHA/ACC/HRS, 2014^22^ Management of AF | Not addressed | VKA or NOAC^b^ | Low stroke risk only^c^
AHA/ASA 2014^23^ Prevention of stroke | Age ≥65 years, pulse with ECG as appropriate | VKA or NOAC^b^ | Low stroke risk only^c^
AAN, 2014^24^ Prevention of stroke in NVAF | Not addressed | VKA or NOAC^d^ | Low stroke risk only^c^
CCS, 2014^25^ Stroke prevention in AF | Not addressed | NOAC > VKA^f^ | Low stroke risk only
CADTH, 2013^26^ Antithrombotic agents in AF | Not addressed | VKA or NOAC^e^ | Not addressed
SIGN, 2013^27^ Antithrombotic indications | Not addressed | VKA or NOAC^f,^ ^g^ | Limited to persons refusing VKA/NOAC
ACCP, 2012^28^ Antithrombotic therapy for AF | Not addressed | NOAC > VKA^f^ | Low stroke risk^c^ or patients refusing VKA/NOAC
AHA/ASA, 2012^29^ Antithrombotic agents in NVAF | Not addressed | VKA or NOAC | Low stroke risk only
RCPE, 2012^30^ Management of AF | Age ≥65 years, pulse with ECG as appropriate | VKA or NOAC^g^ | Not recommended
ACCF/AHA 2010^31^ CV risk in asymptomatic adults | Consider resting ECG in adults with HTN or DM (not specific to AF) | Not addressed | Not addressed
CSN, 2010^32^ Prevention of stroke | Not addressed | VKA or NOAC^f^ | Low stroke risk only^h^

a All treatment recommendations are for patients found to be appropriate candidates for treatment based on risk stratification

b Recommended for patients with CHA_2_DS_2_-VASc score ≥2, variable recommendations for score=1

c Consider for patients with CHA_2_DS_2_-VASc score=1

d Recommended for elderly patients (older than 75 years of age) with no history of recent unprovoked bleeding, variable for patients with dementia or occasional falls

e NOAC for patients with a CHADS_2_ score ≥1 who are unable to achieve adequate anticoagulation with warfarin

f Recommended for patients ≥ age 65 or with CHADS_2_ score ≥1

g Recommended for patients with CHA_2_DS_2_-VASc score ≥1

h Recommended for patients with CHADS_2_ score ≥1

Abbreviations: AAN=American Academy of Neurology; ACC=American College of Cardiology; ACCF=American College of Cardiology Foundation; ACCP=American College of Chest Physicians; AF=atrial fibrillation; AF-SCREEN=acronym not defined; AHA=American Heart Association; ASA=American Stroke Association; CADTH=Canadian Agency for Drugs and Technologies in Health; CCS=Canadian Cardiovascular Society; CSN=Canadian Stroke Network; CV=cardiovascular; DM=diabetes mellitus; ECG=electrocardiogram; EHRA=European Heart Rhythm Association; EPCCS=European Primary Care Cardiovascular Society; ESC=European Society of Cardiology; HRS=Heart Rhythm Society; HTN=hypertension; NICE=National Institute for Health and Care Excellence; NOAC=novel oral anticoagulants; NSC=National Screening Committee; NVAF=non-valvular atrial fibrillation; OAC=oral anticoagulant; RCPE=Royal College of Physicians of Edinburgh; SIGN=Scottish Intercollegiate Guidelines Network; UK=United Kingdom; VKA=vitamin K antagonists; WHF=World Heart Federation.

## CQ 1 What is the prevalence of previously unrecognized or undiagnosed atrial fibrillation among asymptomatic adults, by age (groups), in primary care and community settings?

We identified 19 studies that reported on the prevalence of previously undiagnosed atrial fibrillation (AF) among adults. Appendix A Table 5 [CQ1] summarizes the study populations, detection method used, and findings from these studies. Ten studies were conducted among population-based samples or participants recruited from community settings, and nine studies were conducted among participants recruited from primary care clinical settings. A variety of approaches to detecting AF were used in these studies. Six studies used one-time single-lead ECG via handheld devices for intervals between 10 and 30 seconds.^33–38^ Nine studies used a single, resting 12-lead ECG.^39–47^ The remaining studies used intermittent^48,^ ^49^ or continuous^50^ single-lead ECG over a period of 2 weeks or a combination approach of a single-lead ECG with a followup confirmatory 12-lead ECG.^51^ Studies that included both younger and older adults did not provide results stratified by age. The pooled prevalence of previously undiagnosed AF among clinic-based populations is 1.23 percent (95% CI, 0.85% to 1.77%; I^2^=85%; 9 studies; 21,919 participants, Appendix A Figure 1), and the pooled prevalence among community-based populations is 1.29 percent (95% CI, 0.82% to 2.03%; I^2^=98%; 10 studies; 74,003 participants; Appendix A Figure 1). These data provide an estimate of the total burden of undiagnosed AF but do not offer evidence about differences in detection of undiagnosed AF between routine screening and usual care. This is addressed in KQ 2 of this review.

Appendix A Table 5 Summary of Studies Published Since 2000 Reporting the Prevalence of Previously Undiagnosed Atrial Fibrillation (CQ1)

ID; Author, Year; Trial Name (if applicable) | Study Design | Sample Size | Country | Study Population | Method of Detection | Previously Undiagnosed Atrial Fibrillation Prevalence (95% CI)
Population or Community-Based Samples
Chan et al, 2016^33^ | Uncontrolled trial | 8,797 | Hong Kong | Population-based sample of adults age 18 years or older. Mean age 64.7 (SD 13.4) 71.5% men 38.2% HTN 14.8% DM 0.7 % heart failure 2.2 coronary heart disease 2.7 cardiothoracic surgery | One-time single-lead ECG for 30-second interval using handheld device with smartphone application (AliveCor device). Detection based on presence of full 30-second interval of AF. | 1.1% (NR)
Svennberg et al, 2015, STROKESTOP^48^ | Uncontrolled trial | 7,173 | Sweden | Population-based sample of 75- and 76-year-old adults. % men NR No clinical characteristics reported for the overall study population. | 12-lead ECG at index visit followed by intermittent single-lead ECG with handheld device twice daily and whenever palpitations occurred over 2 weeks. Detection based on AF or atrial flutter at index visit, during intermittent monitoring or in subsequent followup Holter monitoring or 12-lead ECGs. | 3.0% (95% CI, 2.7% to 3.5%) (218 cases total, 37 diagnosed at the index visit; 140 diagnosed with intermittent ECG, and 41 required Holter monitor or other repeat 12-lead ECG; 8 cases were atrial flutter)
Lowres et al, 2014, SEARCH-AF^37^ | Uncontrolled trial | 1,000 | Australia | Community-based sample of adults age 65 years or older recruited from community pharmacies. Mean age 76 (SD 7) 44% men | Pulse palpation and one-time single lead via handheld device connected to smartphone. Criteria for detection NR. | 1.0% (95% CI, 0.5% to 1.8%) (Of the 10 cases of new AF, 2 had paroxysmal AF that reverted to sinus rhythm by the time of confirmation with 12-lead ECG)
Engdahl et al, 2013^49^ | Uncontrolled trial | 767 | Sweden | Population based sample of 75- and 76-year-old adults. 43% men 4% heart failure 53% hypertension 11% diabetes 10% stroke/TIA | Stepwise screening approach, initial 12-lead ECG, if normal and CHADS_2_ equal to 2 or more (i.e., 1 risk factor besides age) then intermittent single-lead ECG via handheld device twice daily for 2 weeks (55% of study population qualified for this second step). Detection based on 30-second interval of AF or two separate intervals at least 10 seconds. | 5.2% (3.8 to 7.7) (40 cases total, 10 cases identified on initial 12-lead ECG, 30 cases identified on intermittent monitoring)
Frewen et al, 2013, TILDA^44^ | Cohort study | 4,890 | Ireland | Population-based sample of community-dwelling adults age 50 years or older from a longitudinal study on ageing. Mean age NR 54% men | 12-lead ECG (lasting 10 minutes). Detection of AF by two independent clinicians according to European Society of Cardiology guidelines, with adjudication by a cardiologist. | 0.9% (NR)
Claes et al, 2012^38^ | Uncontrolled trial | 10,758 | Belgium | Community-based sample of adults 40 years or older recruited through media advertisements. Mean age 59 (SD, 11) 38% men | One-time single-lead ECG via a handheld device. Detection based on RR intervals, absence of p waves, and variable atrial cycle length. | 1.5% (NR)
Schnabel et al, 2012^40^ | Cohort study | 5,000 | Germany | Population-based sample of adults between ages 35 and 74 years. Mean age 52 (SD 11) 49.9% men 45.4% hypertension 6.0% diabetes 17.7% heart failure 1.5% stroke | 12-lead ECG; detection based on confirmed AF by two independent cardiologists. | 0.5% (NR)
Meschia et al, 2010^41^ | Cohort study | 29,861 | USA | Racially and ethnically diverse population-based sample of adults age 45 years or older. Median age 74 (IQR 69 to 79) 45% men 11% stroke 59% hypertension 221% diabetes | 12-lead ECG or 7-lead ECG obtained during in-home visit and interpreted centrally. Detection based on presence of AF on ECG. | 0.6% (NR)
Doliwa et al, 2009^34^ | Diagnostic accuracy study | 606 | Sweden | Community-based sample of adults age 18 years or older. 49% were age 60 or older 64% men | One-time single-lead ECG via handheld device for 10-second interval. Detection criteria NR. | 1.0% (NR)
Furberg et al, 1994^45^ | Cohort study | 5,151 | USA | Population recruited from Medicare eligibility lists of adults age 65 or older from four U.S. communities. Mean age 73 (NR) 43% men 94.7% white | One time, 12-lead ECG, interpreted centrally. | 1.5% (NR)
Clinic-Based Samples
Bury et al, 2015^51^ | Uncontrolled trial | 566 | Ireland | Convenience sample of patients age 70 or older from 25 general practices. Mean age 78 (SD NR) 40% men 48.2% hypertension 10.6% diabetes 22.5% coronary heart disease 2.6% stroke 3.1% other heart surgery or cardiac procedures | One-time 3-lead ECG using the ECG component of an automated external defibrillator followed by confirmatory 12-lead ECG. Criteria for detection NR but included both AF and atrial flutter. | 2.1% (NR) (2 of 12 cases were atrial flutter)
Kaasenbrood, 2016^35^ | Uncontrolled trial | 3,269 | The Nether-lands | Patients age 60 or older recruited from 10 general practices at the time of yearly flu vaccination. Mean age 69.4 (SD 8.9) 49.0% men | One-time single lead ECG via handheld device for 60 seconds. Detection based on positive signal confirmed by cardiologist(s). | 1.1% (NR)
Turakhia et al, 2015, STUDY-AF^50^ | Uncontrolled trial | 75 | USA | Single Veteran’s Health Administration clinic-based sample of adults age 55 years or older with 2 or more AF risk factors including CHD, heart failure, hypertension, diabetes, and sleep apnea. Mean age 69 (SD 8.0) 100% men 95% with hypertension 17% with heart failure 77% with coronary artery disease 56% with diabetes | Continuous single-lead ECG via a wearable patch-based device for 2 weeks. AF based on presence of 30 seconds or more interval of AF. | 5.3% (NR)
Clua-Espuny et al, 2013^42^ | Cross-sectional study | 1,043 | Spain | Patients recruited from primary care clinics. Mean age 78.9 (SD 7.3) % men NR | ECG in clinic setting, further details NR. Detection based on cardiologist confirmation of AF. | 2.2% (NR)
Deif et al, 2012^39^ | Uncontrolled trial | 2,802 | Australia | Ambulatory adults age 40 or older undergoing preoperative evaluation for minor procedures or elective surgery. Mean age 65 (SD 13) 50% men | “Routine” ECG; detection criteria NR. | 0.4% (NR) all participants 0.7% (NR) in participants age 65 years or older
Fitzmaurice et al, 2007; SAFE study^43^ | Cluster RCT | 9,137 | UK | Patients age 65 or older from 50 general practices. Mean age 75.3 (SD 7.2) 42.8% men | Practices were allocated to screening or control, and screening practices were subsequently allocated to systematic (invitation to attend screening clinic with 12-lead ECG) or opportunistic screening (pulse check at usual care visits with referral to screening clinic if abnormal). Detection based on AF on 12-lead ECG. | 1.6% (in practices allocated to screening) 1.0% (in practices allocated to control)
Morgan et al, 2002^36^ | Parallel group RCT with two active comparators | 3,001 | UK | Patients ages 65 to 100 from four general practices. Mean age 75 (SD NR) 41% men | Systematic pulse and single-lead (II) ECG vs. opportunistic screening (reminder placed on patient chart to perform pulse screening). Detection based on AF on confirmatory ECG (in systematically screened arm). | Yield of new AF cases in systematically screened arm: 0.8% (NR) (systematically screened) 0.5% (NR) (opportunistically screened)
Wheeldon et al, 1998^47^ | Uncontrolled trial | 1,207 | UK | Patients age 65 or older from four general practices. Mean age NR % Men NR | Single 12-lead ECG in clinic setting. Detection based on interpretation by cardiologist. | 0.4% (NR)
Hill et al, 1987^46^ | Uncontrolled trial | 819 | UK | Symptomless patients age 65 or older from a single general practice. Mean age | Single 12-lead ECG in clinic setting. Detection based on interpretation by two physicians. | 1.2% (NR)

Abbreviations: AF=atrial fibrillation; CHD=coronary heart disease; CI=confidence interval; DM=diabetes mellitus; ECG=electrocardiogram; HTN=hypertension; ID=identification number; IQR=interquartile range; NR=not reported; RCT=randomized, controlled trial; RR= relative risk; SAFE=Screening for AF in the elderly; SD=standard deviation; STUDY-AF=Screening Study for Undiagnosed Atrial Fibrillation; TIA=transient ischemic attack; TILDA= The Irish Longitudinal Study on Ageing; UK=United Kingdom; USA=United States of America.

Appendix A Figure 1 Meta-Analysis of Studies Assessing Proportion of Participants With Undiagnosed Atrial Fibrillation

Abbreviations: AF=atrial fibrillation; CI=confidence interval; ECG=electrocardiogram; N=number; NR=not reported.

Appendix A Figure 1 displays a forest plot assessing the proportion of participants with undiagnosed AF, stratified by clinic-based vs. community-based population. The pooled prevalence of previously undiagnosed AF among clinic-based populations is 1.23% (95% CI, 0.85% to 1.77%; I2=85%; 9 studies; 21,919 participants), and the pooled prevalence among community-based populations is 1.29% (95% CI, 0.82% to 2.03%; I2=98%; 10 studies; 74,003 participants). These data provide an estimate of the total burden of undiagnosed AF but do not offer evidence about differences in detection of undiagnosed AF between routine screening and usual care.

## CQ 2 What is the stroke risk in asymptomatic older adults with previously unrecognized or undiagnosed atrial fibrillation?

### Incidence of Stroke for Incidentally Detected AF

Limited evidence was found regarding the incidence of stroke in asymptomatic older adults with unrecognized or undiagnosed AF conducted among the general population. Martinez et al. identified 5,555 persons with incidentally detected AF (and reportedly asymptomatic based on review of Read Medical Codes and ICD codes) through hospital and general practice databases.^52^ These were not screen detected as far as the article reports but rather seem to have been detected in the course of usual care. Just over half were treated with oral anticoagulant therapy with or without antiplatelet therapy. The cohort included people with a history of CAD without MI (10.6%), MI (4.2%), and stroke or TIA (9.2%). Mean CHA_2_DS_2_-VASc score was 2.5 (SD, 1.5, and 73% had a score of 2 or greater) and mean CHADS_2_ score was 1.3 (1.1). Limitations of the study include that patients were not screen detected and that using Read Medical Codes and ICD codes has limitations regarding the ability to identify asymptomatic people and to accurately identify previously undiagnosed AF. The study reported stroke incidence rates per 1,000 person-years over a maximum of 3 years by age group for those with incidentally detected AF as follows:

- Ages 18 to 49 years: 0 (95% CI, 0 to 6.5)
- Ages 50 to 64 years: 9.1 (95% CI, 5.9 to 13.4)
- Ages 65 to 74 years: 16.5 (95% CI, 13.1 to 20.6)
- Ages 75 to 84 years: 29.6 (95% CI, 25.1 to 34.7)

The study also provided data for a matched comparison group of people without AF (but not comparing asymptomatic vs. symptomatic people). Stoke incidence rates per 1,000 were 19.4 (17.1 to 21.9) for those with incidentally detected AF (all ages) and 8.4 (7.7 to 9.1) for the matched controls without AF.

### Predicted Stroke Risk

Fitzmaurice et al. compared CHADS_2_ scores among persons with newly diagnosed AF (149 cases) identified through either opportunistic screening or systematic screening in the SAFE study (described in KQ 2).^53^ The proportion with scores greater than or equal to 1 was similar (82.7% [95% CI, 72.6 to 89.6] opportunistic screening group; 78.4% [95% CI, 67.7 to 86.2] systematically screened group; p=0.51). The proportion with scores of 2 or more was slightly lower in the opportunistic arm, but the difference was not statistically significant (29.3% [95% CI, 20.2 to 40.4] opportunistic arm vs. 43.2% [95% CI, 32.6 to 54.6] in the systematic screening arm; p=0.077). Eight of the 19 studies described in CQ 1 provided data on the mean predicted risk of stroke among persons with previously unrecognized or undiagnosed AF;^33,^ ^35,^ ^37,^ ^39,^ ^49–51^ findings are summarized in Appendix A Table 6 (CQ 2). The range of mean CHADS_2_ scores was 1.8 to 2.2 (3 studies), and the range of mean CHA_2_DS_2_-VASc scores was 3.1 to 3.8 (7 studies), ranges that would typically be associated with initiation of anticoagulation (in the absence of contraindications).

### Relative Risk of Stroke in Asymptomatic AF vs. Symptomatic AF

Four cohort studies provide information related to the relative risk of stroke among persons with asymptomatic AF compared with persons with symptomatic AF. Study details and limitations are summarized in Appendix A Table 7. These studies were conducted among different patient populations using different approaches to ascertain AF, and some reported a higher absolute incidence of stroke among persons with asymptomatic AF compared with persons with symptomatic AF. Adjusted analyses in two of the four studies showed no statistically significant difference between those with asymptomatic and symptomatic AF. Although some of the studies adjusted for known differences in baseline characteristics, the potential for residual confounding in these studies is high because asymptomatic and symptomatic persons differed on baseline characteristics across all studies for which this information was available. Some studies did not consider important risk factors for stroke in their adjusted analyses (e.g., CHA_2_DS_2_-VASc score or its components, smoking). Further, although some information about rates of anticoagulation treatment among persons with asymptomatic AF was provided, differences in treatment to prevent stroke between groups cannot be ruled out. The risk of selection bias in most of these studies is high, because many identified patients were from cardiology or AF registries, and may not be representative of patients seen in primary care. Over 60 percent of participants in two of the studies had heart disease at baseline, and one study did not report baseline descriptive information (published as abstract only). Risk of ascertainment bias for determining symptom status (i.e., whether people were asymptomatic) is also a concern because the studies typically reported limited information about methods for ascertainment, and they relied on retrospective chart reviews or claims to determine whether patients were asymptomatic. Only one clearly distinguished fully asymptomatic (no current or past symptoms of AF) patients (Boriani et al, 2015) from patients who are currently asymptomatic, indicating a more appropriately detailed ascertainment of symptom status;^54^ it reported no difference in outcomes for symptomatic and asymptomatic patients in adjusted analyses.

Appendix A Table 6 Mean Predicted Stroke Risk Among Persons With Previously Unrecognized Atrial Fibrillation (CQ2)

Author, Year | n Previously Undiagnosed AF/ N Total Study Sample | Risk Instrument/ Mean (SD) Predicted Stroke Risk
Chan et al. (2016)^33^ | 101/8,797 | CHA_2_DS_2_-VASc 3.1 (1.3)
Bury et al. (2015)^51^ | 12/566 | CHA_2_DS_2_-VASc (median) 4
Kaasenbrood et al. (2015)^35^ | 37/3,269 | CHA_2_DS_2_-VASc 3.4 (1.9)
Turakhia et al. (2015)^50^ | 4/75 | CHA_2_DS_2_-VASc ≥2 in all 4 participants
Engdahl et al. (2013)^49^ | 10/767 | CHADS_2_ 1.8 (NR)
Dief et al. (2012)^39^ | 10/1,459 | Among persons age 65 or older CHADS_2_ 2.2 (1.5) CHA_2_DS_2_-VASc 3.8 (SD 2.0)
Svennberg et al. (2015)^48^ | 218/7,173 | CHA_2_DS_2_-VASc 3.5 (1.2)
Lowres et al. (2013)^37^ | 15/1,000 | CHADS_2_ 1.9 (1.1) CHA_2_DS_2_-VASc 3.7 (1.1)

Abbreviations: AF=atrial fibrillation; CHA_2_DS_2_-VASc=Congestive heart failure, Hypertension, Age ≥75 years [doubled], Diabetes mellitus, prior Stroke or TIA or thromboembolism [doubled], Vascular disease, Age 65-74 years, Sex category; CQ=contextual question; n=number of patients; N=number of patients in sample; NR=not reported; SD=standard deviation.

Appendix A Table 7 Stroke Incidence in People With Asymptomatic, Previously Unrecognized AF vs. People With Symptomatic AF, Reported by Observational Studies

Author, Year Country | Study Population and Setting | Stroke Incidence | Study Limitations
Potpara, 2013^55^ Serbia | 146 asymptomatic patients with initial AF diagnosis between 1997 and 2007 diagnosed with 12-lead ECG during period medical exam based on registry of patients with AF. (Total cohort=1,100 individuals with AF) 47.9% were placed on aspirin and 40.4% were placed on oral anticoagulants after diagnosis | 14 (9.6%) vs. 44 (5.6%) with ischemic stroke during mean followup of 9.9 years Adjusted HR 1.8 (95% CI, 1.0 to 3.4, p=0.051) compared with individuals in cohort with symptomatic AF (adjustment for age, sex, and treatment at baseline) | -High potential for confounding (e.g., no adjustment for smoking status and other relevant imbalances between symptomatic and asymptomatic individuals at baseline) -Limited information regarding ascertainment of AF symptoms -60% had prior heart disease, so not applicable to general population
Tsang, 2011^56^ US | 1,152 asymptomatic adults (mean age 74 years) with ECG-confirmed diagnosis of first AF between 1980 and 2000 in Olmsted County, Minnesota, based on medical record review (Total cohort=4,618) | Number (%) of events NR for either group. Compared with persons with symptomatic AF, persons with asymptomatic AF were three times more likely to have sustained an ischemic stroke prior to their diagnosis after adjustment for age, sex, and other stroke risk factors (p<0.0001) | -Data published in abstract format only, limiting assessment of risk of bias -No information to assess whether groups were similar at baseline or what specific stroke risk factors were included in analysis (it reported adjusting for age, sex, and “multiple other stroke risk factors”). -Methods of ascertaining symptom status NR (other than stating that medical records were used)
Siontis, 2016^57^ US | 161 asymptomatic adults (mean age 69.2) from among 1,000 randomly selected patients from a total cohort of 3,344 adults with incident AF between 2000 and 2010 in Olmsted County, Minnesota | Total of 59 strokes (among the 1,000). Persons with asymptomatic AF had higher incidence of stroke over median followup of 5.6 years compared with persons with typical AF (adjusted HR 2.6, 95% CI 1.10 to 6.11, adjusted for CHA_2_DS_2_-VASc score, age, BMI, smoking status, COPD, eGFR, dementia, malignancy, warfarin use and time in therapeutic range) | -Potential for residual confounding due to unmeasured differences in baseline characteristics among persons with typical, atypical, and asymptomatic AF as these groups were clearly different on numerous measured baseline characteristics -Symptom status ascertained retrospectively by medical records review (by trained abstractors looking for information about palpitations, atypical symptoms, etc.)
Boriani, 2015^54^ Europe | 1,237 persons with asymptomatic AF (mean age 72; 520/1,237 with “fully asymptomatic” AF, indicating absence of current and previous symptoms) in a AF registry from those presenting to cardiology practices from 9 countries. Most asymptomatic patients had valvular heart disease (64.5%), chronic heart failure (44.3%), or CAD (40.1%). (Total cohort=3,119 in the EORP-AF) | Mean followup about 1 year 112/1064 (10.5%) vs. 80/1409 (5.7%) events for a composite incidence of stroke/TIA/peripheral embolism or death higher in asymptomatic AF compared to symptomatic AF at 1 year (p < 0.0001) in unadjusted analyses. Multivariate analyses found no significant association with symptom status for mortality or for the composite of stroke/TIA/peripheral embolism or death^a^ | -High potential for residual confounding; asymptomatic patients were more likely to be older, male, and had a higher proportion of related comorbidities, including history of thromboembolic complications and stroke -Analyses did not focus on the 520 “fully asymptomatic” persons for the comparisons reported -Limited applicability to the key questions of this review because most participants had known heart disease

a Outcomes compared the 1,237 currently asymptomatic people (but not the fully asymptomatic) with symptomatic people.

Abbreviations: AF=atrial fibrillation; BMI=body mass index; CAD=coronary artery disease; CI=confidence interval; COPD=chronic obstructive pulmonary disease; CVD=cardiovascular disease; ECG= electrocardiogram; eGFR=estimated glomerular filtration rate; EORP=EurObservational Research Programme – Atrial Fibrillation; HR=hazard ratio; NR=not reported; TIA=transient ischemic attack; US=United States.

## 3a. What are the recommendations on use of rate or rhythm control for the treatment of atrial fibrillation in asymptomatic adults age 65 years or older?

We found no recommendations that specifically address the use of rhythm control for asymptomatic adults (it is recommended for selected patients with symptoms); some guidelines recommend rate control to achieve a resting heart rate under 110 beats per minute (bpm) for asymptomatic patients because prolonged rapid ventricular rates increase the risk of cardiomyopathy.^58,^ ^59^ There has been an ongoing debate on the use of rate versus rhythm control strategies for patients with AF. However, rate control is now generally preferred for multiple reasons: several clinical trials have not found either rate or rhythm control to be clearly superior for benefits, rate control medications are familiar to a larger number of providers, and evidence shows an increased risk of adverse events with antiarrhythmic agents.^60–62^

According to the AHA/ACC/HRS guidelines, for rate control, beta-blockers are the most commonly used agents, followed by nondihydropyridine calcium channel blockers (e.g., diltiazem), digoxin, and amiodarone.^63^ Rhythm control strategies aiming to restore and maintain sinus rhythm include electrical cardioversion, pharmacological cardioversion using antiarrhythmic agents, and surgical or catheter ablation, used either singly or in combination. A meta-analysis of eight RCTs^64^ (7,499 AF patients, mean age 68 years) by Caldeira et al. concluded there were no differences in a variety of outcomes between rate and rhythm control strategies: all-cause mortality (RR, 0.95; 95% CI, 0.68 to 1.05; 8 studies), cardiovascular mortality (RR, 0.99; 95% CI, 0.97 to 1.13, 7 trials), arrhythmic and sudden death (RR, 1.12; 95% CI, 0.91 to 1.38; 5 trials), ischemic stroke (RR, 0.89; 95% CI, 0.52 to 1.53; 4 trials), systemic embolism (RR, 0.89; 95% CI, 0.69 to 1.14; 6 trials), and major bleeding (RR, 1.10; 95% CI, 0.89 to 1.36; 5 trials). Sensitivity analysis including studies with more than 50 percent of participants having heart failure demonstrated fewer systemic embolic events with rate control strategies (RR, 0.43; 95% CI, 0.21 to 0.89; 3 trials). For patients with mean age ≥65 years (5 trials), there were no differences between treatment strategies for all of the previously mentioned outcomes, with the exception of arrhythmic and sudden deaths, which were not reported. For these analyses, two studies–AFFIRM (n=4060) and AF-CHF (n=1376)–provided most of the data (weight, 95.3%). AFFIRM,^65^ the largest of the RCTs to compare rate versus rhythm control, enrolled 4,060 patients age 65 years or older with AF and risk factors for stroke or death. After 5 years of observation following randomization to either rate or rhythm control strategies, the study found no difference in mortality between the groups (HR, 1.15; 95% CI, 0.99 to 1.34). Visual inspection of the Kaplan-Meier curves, however, suggests an apparent separation of the two groups that appears to widen over time (trending toward favoring a possible benefit for rate control). In a re-analysis of AFFIRM using propensity-matched scoring for participants ages 70 to 80 years, mortality was greater in the rhythm control arm (HR, 1.30; 95% CI, 1.06 to 1.59).^66^

Guidelines for treatment of AF recommend initial rate control strategies for most symptomatic patients with a stepwise approach to rhythm control strategies in those patients who have persistent symptoms or are unable to be treated using rate control alone.^63,^ ^67,^ ^68^ The AHA/ACC/HRS recommendations are based largely on the results of two RCTs, which demonstrate the lack of superiority of one strategy over the other,^61,^ ^69^ as well as an increase in hospitalizations for rhythm control strategies.^60^ The NICE guidelines include a systematic review and meta-analysis of eight RCTs, which drew similar conclusions to the meta-analysis by Caldeira et al. The NICE guidelines acknowledge moderate-quality evidence supporting the mortality and bleeding outcomes but low- or very low-quality evidence for other outcomes comparing rate versus rhythm control.

While no guideline made a specific recommendation for asymptomatic adults age 65 years or older, the mean age of participants across trials was 61 to 72 years. The AHA/ACC/HRS guideline includes a single recommendation for a lenient rate-control strategy (resting heart rate <110 bpm) when patients remain asymptomatic and left ventricular systolic function is preserved, which is based on a single study (RACE II).^69^ RACE II compared strict (<80 bpm resting HR) versus lenient (<110 bpm) rate control strategies in patients with permanent AF (for up to 12 months prior to enrollment). Forty-three percent of the study population was asymptomatic at baseline (defined as no palpitations, dyspnea, or fatigue), although it is not clear how many were never symptomatic (i.e., how many did not have symptoms around the time of their diagnosis or prior to it). RACE II concluded noninferiority between the two strategies for prevention of major cardiac events.^70^

The AHA/ACC guidelines recommend rhythm-control strategies for AF patients with persistent symptoms and with select factors such as inadequate rate control, younger age, tachycardia-mediated cardiomyopathy, first AF episode, AF precipitated by an acute illness, and patient preference.^63^ Because AF can progress from paroxysmal to persistent, resulting in electrical and structural remodeling that becomes irreversible over time, the guidelines note that when considering a rhythm control strategy, early intervention may be most beneficial to prevent AF progression.

According to a Cochrane review by Mead et al, electrical cardioversion did not result in any greater reduction in mortality than rate control strategies (OR, 0.83; 95% CI, 0.48 to 1.43; 3 trials, 927 patients) and may increase the risk of stroke (OR, 1.9; 95% CI, 0.99 to 3.64; 3 trials).^71^ However, physical function, physical role function, and vitality were better in the cardioversion group. The mean age of participants across the three trials was 60 to 68 years. Other studies report that some patients spontaneously revert to AF within weeks or months, and up to 25 percent will revert within 1 year, which may explain the possible increase in risk of stroke because many patients who are cardioverted often cease taking anticoagulation or antiplatelet agents used to prevent stroke.^72,^ ^73^ The AHA/ACC guidelines recommend direct current cardioversion as an option when pursuing a rhythm-control strategy for symptomatic patients and those refractory to pharmacological therapies; they do not make a specific recommendation for asymptomatic patients.^63^

Although the ESC acknowledges the efficacy of pharmacologic cardioversion using antiarrhythmic agents, they also note the elevated adverse event and mortality rates associated with using these agents.^67^ Accordingly, they recommend antiarrhythmic drug therapy only in patients with resistant symptoms due to recurrent AF. The AHA/ACC guidelines note that antiarrhythmic drug efficacy is modest, and AF recurrences are common. Lafuente-Lafuente et. al. concluded in a meta-analysis of 59 studies (21,305 patients) that several classes of antiarrhythmic agents were moderately effective at maintaining sinus rhythm after conversion of AF (OR, 0.19 to 0.77; number-needed-to-treat (NNT), 3 to 16), but most agents increased adverse events and mortality (OR, 2.23 to 2.39; number needed to harm 109 to 169).^74^

Concerning catheter ablation, the ESC notes that large trials of ablation therapy are pending and that the risks associated with the procedure need to be carefully weighed against potential for symptomatic benefit.^67^ Although the guideline authors note that catheter ablation is more effective than antiarrhythmic drug therapy, its use as first-line therapy should currently be limited to those with paroxysmal AF preferring interventional treatment and who have a low-risk profile for procedure-associated complications. The AHA recommends AV nodal ablation only sparingly noting that the procedure leads to pacemaker dependency, and is therefore usually reserved for elderly patients.^63^ Guidelines from both organizations recommend catheter ablation as a second line treatment in patients who are candidates for first line treatment with antiarrhythmic agents who experience failure or intolerance with these agents.^75^ Two recent Cochrane reviews address the question of catheter ablation for AF. However, neither review addressed the use of ablation techniques in screen-detected, asymptomatic patients. Chen et al. assessed the benefits and harms of catheter ablation versus medical therapy for patients with either paroxysmal or persistent AF (32 RCTs, 3,560 patients).^76^ They concluded that compared with medical therapy, ablation had a better effect for inhibiting AF recurrence (RR, 0.27; 95% CI, 0.18 to 0.41; 7 trials, 767 patients), and they found no differences between treatments for mortality (RR, 0.50; 95% CI, 0.04 to 5.65), fatal and nonfatal embolic complications (RR, 1.01; 95% CI, 0.18 to 5.68), or thrombo-embolic-specific mortality (RR, 3.04; 95% CI, 0.13 to 73.43). Significant heterogeneity was noted for the comparison of ablation versus medical therapies, and overall, RCTs were small in size and poor quality. Nyong et al. assessed the use of both surgical and catheter ablation in patients with nonparoxysmal AF (3 RCTs, 261 patients with mean age of 60 years).^77^ They concluded that radio-frequency catheter ablation was superior to antiarrhythmic agents for achieving freedom from atrial arrhythmias (RR, 1.84; 95% CI, 1.17 to 2.88), reducing further cardioversion (RR, 0.62; 95% CI, 0.47 to 0.82) and reducing cardiac-related hospitalization (RR, 0.27; 95% CI, 0.10 to 0.72). Trials were rated as low or unclear risk of bias, and strength of evidence for these findings was low (hospitalizations) to moderate. Additionally, they identified three ongoing studies comparing catheter ablation to either rate control, electrical cardioversion, or both rate and rhythm control drug treatments. They identified no comparative studies of surgical ablation.

## 3b How often are such treatments used in the United States in asymptomatic adults age 65 years or older?

We did not find any data that specifically address how often these treatments are used in asymptomatic adults. The existing data do not describe symptom status of the treated patients. One retrospective administrative claims analysis (using claims from January 1, 2008 through September 30, 2010) of 48,814 patients with a diagnosis of AF reported that 38,502 (79%) received treatment.^78^ Of those treated, the majority received rate control medications (67% received beta blockers) and rhythm control medications were used in the initial regimens for 12 percent (and 24% received rhythm control medications at any time). Direct current cardioversion was used in the initial treatment for 8.5 percent (and 18% at any time). Catheter ablation was used in 5 percent of patients and was typically not a first line treatment.

The National Disease and Therapeutic Index is a survey of about 3,000 office-based physicians that collects diagnosis and treatment information on all patient visits over a randomly selected 2-day period in each calendar year. National estimates for treatments by diagnoses are calculated using survey drug mentions as a surrogate for actual drug treatments. Between October 1999 and September 2003, mention of digoxin treatment for patients with AF declined from 29 percent to 17 percent, while mentions of beta blockers rose from about 8 percent to 11 percent and mentions of calcium channel blockers remained stable around 8 percent.^79^ When stratified by age, mention of digoxin was more common among patients age 60 years or older (24% vs. 17%), while the use of beta blockers was slightly more common among patients younger than 60 years (13% vs. 10%). Among patients age 60 years or older, 11 percent of visits mentioned use of an anti-arrhythmic agent. Amiodarone was the most commonly cited agent among this age group (5.6%), followed by sotalol, class 1c, and 1a agents. No information was reported from this survey about symptomatic versus asymptomatic treatment. Based on the National Hospital Discharge Survey (NHDS), rates of catheter ablation to treat AF have risen by 15 percent per year between 1990 (0.06% of patients with AF) and 2005 (0.79%). Across all age groups, the rate of increase was similar, including patients older than 80 years (0.00% in 1990 vs. 0.26% in 2005). Overall, 0.42 percent of hospitalized patients (1,144/269,471) identified in NHDS underwent catheter ablation, corresponding to a national estimate of 133,000 ablations in 32 million hospitalizations over the 15-year period.^80^