# References

1 Chou R, High Value Care Task Force of the American College of P. Cardiac screening with electrocardiography, stress echocardiography, or myocardial perfusion imaging: advice for high-value care from the American College of Physicians. Ann Intern Med. 2015 Mar 17;162(6):438-47. doi: 10.7326/M14-1225. PMID: 25775317.25775317
2 Wolk MJ, Bailey SR, Doherty JU, . ACCF/AHA/ASE/ASNC/HFSA/HRS/SCAI/SCCT/SCMR/STS 2013 multimodality appropriate use criteria for the detection and risk assessment of stable ischemic heart disease: a report of the American College of Cardiology Foundation Appropriate Use Criteria Task Force, American Heart Association, American Society of Echocardiography, American Society of Nuclear Cardiology, Heart Failure Society of America, Heart Rhythm Society, Society for Cardiovascular Angiography and Interventions, Society of Cardiovascular Computed Tomography, Society for Cardiovascular Magnetic Resonance, and Society of Thoracic Surgeons. J Am Coll Cardiol. 2014 Feb 4;63(4):380-406. doi: 10.1016/j.jacc.2013.11.009. PMID: 24355759.24355759
3 American Academy of Family Physicians. Annual EKGs for Low-risk Patients. 2012. http://www.aafp.org/patient-care/clinical-recommendations/all/cw-ekg.html. Accessed 18 Nov, 2015.
4 Lim LS, Haq N, Mahmood S, . Atherosclerotic cardiovascular disease screening in adults: American College of Preventive Medicine position statement on preventive practice. Am J Prev Med. 2011 Mar;40(3):381 e1-10. doi: 10.1016/j.amepre.2010.11.021. PMID: 21335273.21335273
5 Greenland P, Alpert JS, Beller GA, . 2010 ACCF/AHA guideline for assessment of cardiovascular risk in asymptomatic adults: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2010 Dec 14;56(25):e50-103. doi: 10.1016/j.jacc.2010.09.001. PMID: 21144964.21144964
6 Lauer M, Froelicher ES, Williams M, . Exercise testing in asymptomatic adults: a statement for professionals from the American Heart Association Council on Clinical Cardiology, Subcommittee on Exercise, Cardiac Rehabilitation, and Prevention. Circulation. 2005 Aug 2;112(5):771-6. doi: 10.1161/CIRCULATIONAHA.105.166543. PMID: 15998671.15998671
7 National Heart, Lung, and Blood Institute. 2013 Report on the Assessment of Cardiovascular Risk: Full Work Group Report Supplement: National Heart, Lung, and Blood Institute; 2013.
8 Goff DC, Jr., Lloyd-Jones DM, Bennett G, . 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014 Jul 01;63(25 Pt B):2935-59. doi: 10.1016/j.jacc.2013.11.005. PMID: 24239921.24239921
9 D’Agostino RB, Sr., Vasan RS, Pencina MJ, . General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008 Feb 12;117(6):743-53. doi: 10.1161/CIRCULATIONAHA.107.699579. PMID: 18212285.18212285
10 Anderson TJ, Gregoire J, Hegele RA, . 2012 update of the Canadian Cardio vascular Society guid elines for the diagnosis and treatment of dyslipidemia for the prevention of cardiovascular disease in the adult. Can J Cardiol. 2013 Feb;29(2):151-67. doi: 10.1016/j.cjca.2012.11.032. PMID: 23351925.23351925
11 Hippis ley-Cox J, Co upland C, Vinogradova Y, . Predicting cardiovascular risk in England and Wales: prospective derivation and validation of QRISK2. BMJ. 2008 Jun 28;336(7659):1475-82. doi: 10.1136/bmj.39609.449676.25. PMID: 18573856.18573856
12 National Institute for Health and Care Excellence. Lipid Modification: cardiovascular risk assessment and the modification of blood lipids for the primary and secondary prevention of cardiovascular disease. United Kingdom: National Institute for Health and Care Excellence; 2014.
13 Ridker PM, Paynter NP, Rifai N, . C-reactive protein and parental history improve global cardiovascular risk prediction: the Reynolds Risk Score for men. Circulation. 2008 Nov 25;118(22):2243-51, 4p following 51. doi: 10.1161/CIRCULATIONAHA.108.814251. PMID: 18997194.18997194
14 Ridker PM, Buring JE, Rifai N, . Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA. 2007 Feb 14;297(6):611-9. doi: 10.1001/jama.297.6.611. PMID: 17299196.17299196
15 Woodward M, Brindle P, Tunstall-Pedoe H, . Adding social deprivation and family history to cardiovascular risk assessment: the ASSIGN score from the Scottish Heart Health Extended Cohort (SHHEC). Heart. 2007 Feb;93(2):172-6. doi: 10.1136/hrt.2006.108167. PMID: 17090561.17090561
16 Scottish Intercollegiate Guidelines Network. Risk estimation and the prevention of cardiovascular disease: a national clinical guideline. Edinburgh: Scottish Intercollegiate Guidelines Network; 2007.
17 Chambless LE, Folsom AR, Sharrett AR, . Coronary heart disease risk prediction in the Atherosclerosis Risk in Communities (ARIC) study. J Clin Epidemiol. 2003 Sep;56(9):880-90. PMID: 14505774.14505774
18 Conroy RM, Pyorala K, Fitzgerald AP, . Estimation of ten-year risk of fatal cardiovascular disease in Europe: the SCORE project. Eur Heart J. 2003 Jun;24(11):987-1003. PMID: 12788299.12788299
19 Perk J, De Backer G, Gohlke H, . European Guidelines on cardiovascular disease prevention in clinical practice (version 2012). The Fifth Joint Task Force of the European Society of Cardiology and Other Societies on Cardiovascular Disease Prevention in Clinical Practice (constituted by representatives of nine societies and by invited ex perts). Eur Heart J. 2012 Jul;33(13):1635-701. doi: 10.1093/eurheartj/ehs092. PMID: 22555213.22555213
20 Assmann G, Cullen P, Schulte H. Simple scoring scheme for calculating the risk of acute coronary events based on the 10-year follow-up of the prospective card iovascular Munster (PROCAM) study. Circulation. 2002 Jan 22;105(3):310-5. PMID: 11804985.11804985
21 National Cholesterol Education Program Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults. Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002 Dec 17;106(25):3143-421. PMID: 12485966.12485966
22 Anderson KM, Odell PM, Wilson PW, . Cardiovasular disease risk profiles. Am Heart J. 1991 Jan;121(1 Pt 2):293-8. PMID: 1985385.1985385
23 Anderson KM, Wilson PW, Odell PM, . An updated coronary risk profile. A statement for health professionals. Circulation. 1991 Jan;83(1):356-62. PMID: 1984895.1984895
24 Wilson PW, D’Agostino RB, Levy D, . Prediction of coronary heart disease using risk factor categories. Circulation. 1998 May 12;97(18):1837-47. PMID: 9603539.9603539
25 Wolf PA, D’Agostino RB, Belanger AJ, . Probability of stroke: a risk profile from the Framingham Study. Stroke. 1991 Mar;22(3):312-8. PMID: 2003301.2003301
26 U. S. Preventive Services Task Force. Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: Preventive Medication. Rockville, MD: U. S. Preventive Services Task Force; November 2016. https://www.uspreventiveservicestaskforce.org/Page/Document/RecommendationStatementFinal/aspirinto-prevent-cardiovascular-disease-and-cancer
27 Vandvik PO, Lincoff AM, Gore JM, . Primary and secondary prevention of cardiovascular disease: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012 Feb;141(2 Suppl):e637S-68S. doi: 10.1378/chest.11-2306. PMID: 22315274.22315274
28 Goldstein LB, Bushnell CD, Adams RJ, . Guidelines for the primary prevention of stroke: a guideline for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2011 Feb;42(2):517-84. doi: 10.1161/STR.0b013e3181fcb238. PMID: 21127304.21127304
29 Pignone M, Alberts MJ, Colwell JA, . Aspirin for primary prevention of cardiovascular events in people with diabetes: a position statement of the American Diabetes Association, a scientific statement of the American Heart Association, and an expert consensus document of the American College of Cardiology Foundation. Diabetes Care. 2010 Jun;33(6):1395-402. doi: 10.2337/dc10-0555. PMID: 20508233.20508233
30 U. S. Preventive Services Task Force. Final Update Summary: Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: Preventive Medication. Rockville, MD: U.S. Preventive Services Task Force; November 2016. https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/statin-use-in-adults-preventive-medication1
31 Stone NJ, Robinson JG, Lichtenstein AH, . 2013 ACC/AHA guideline on the treatment of blood cholesterol to reduce atherosclerotic cardiovascular risk in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Circulation. 2014 Jun 24;129(25 Supp 12):S1-45. doi: 10.1161/01.cir.0000437738.63853.7a. PMID: 24222016.24222016
32 National Institute for Health and Care Excellence. Cardiovascular disease: risk assessment and reduction, including lipid modification. United Kingdom: National Institute for Health and Care Excellence; 2016. https://www.nice.org.uk/Guidance/CG181. Accessed May 30, 2017.
33 Mosca L, Benjamin EJ, Berra K, . Effectiveness-based guidelines for the prevention of cardiovascular disease in women--2011 update: a guideline from the american heart association. Circulation. 2011 Mar 22;123(11):1243-62. doi: 10.1161/CIR.0b013e31820faaf8. PMID: 21325087.21325087
34 Siscovick DS, Barringer TA, Fretts AM, . Omega-3 Polyunsaturated Fatty Acid (Fish Oil) Supplementation and the Prevention of Clinical Cardiovascular Disease: A Science Advisory From the American Heart Association. Circulation. 2017 Apr 11;135(15):e867-e84. doi: 10.1161/CIR.0000000000000482. PMID: 28289069.28289069
35 National Institute for Health and Care Excellence. Do Not Do Recommendation. United Kingdom: National Institute for Health and Care Excellence; 2017. https://www.nice.org.uk/donotdo/do-not-offer-omega-3-fatty-acid-compounds-for-the-prevention-of-cvd-to-any-of-the-following-people-who-are-being-treated-for-primary-prevention-people-who-are-being-treated-for-secondary-prevention-people-with-ckd-people-with-type-1-diabetes-people-with-t. A ccessed May 31, 2017.
36 George MG, Tong X, Sonnenfeld N, . Recommended use of aspirin and other antiplatelet medications among adults--National Ambulatory Medical Care Survey and National Hospital Ambulatory Medical Care Survey, United States, 2005-2008. MMWR Suppl. 2012 Jun 15;61(2):11-8. PMID: 22695458.22695458
37 Mainous AG, Tanner RJ, Shorr RI, . Use of aspirin for primary and secondary cardiovascular disease prevention in the United States, 2011-2012. J Am Heart Assoc. 2014 Jul 14;3(4) doi: 10.1161/JAHA.114.000989. PMID: 25023071.25023071
38 Malayala SV, Raza A. Compliance with USPSTF recommendations on aspirin for prevention of cardiovascular disease in men. Int J Clin Pract. 2016 Nov;70(11):898-906. doi: 10.1111/ijcp.12869. PMID: 27619938.27619938
39 Fiscella K, Winters PC, Mendoza M, . Do clinicians recommend aspirin to patients for primary prevention of cardiovascular disease? J Gen Intern Med. 2015 Feb;30(2):155-60. doi: 10.1007/s11606-014-2985-8. PMID: 25092016.25092016
40 Kumar A, Fonarow GC, Eagle KA, . Regional and practice variation in adherence to guideline recommendations for secondary and primary prevention among outpatients with atherothrombosis or risk factors in the United States: a report from the REA CH Reg is t ry. Crit Pa thw Card iol. 2009 Sep;8(3):104-11. doi: 10.1097/HPC.0b013e3181b8395d. PMID: 19726929.19726929
41 Noto TJ, Jr., Johnson LW, Krone R, . Cardiac catheterization 1990: a report of the Registry of the Society for Cardiac Angiography and Interventions (SCA&I). Cathet Cardiovasc Diagn. 1991 Oct;24(2):75-83. PMID: 1742788.1742788
42 Patel MR, Peterson ED, Dai D, . Low diagnostic yield of elective coronary angiography. N Engl J Med. 2010 Mar 11;362(10):886-95. doi: 10.1056/NEJMoa0907272. PMID: 20220183.20220183
43 Schulman-Marcus J, Feldman DN, Rao SV, . Characteristics of Patients Undergoing Cardiac Catheterization Before Noncardiac Surgery: A Report From the National Cardiovascular Data Registry Cath PCI Registry. JAMA Intern Med. 2016 May 01;176(5):611-8. doi: 10.1001/jamainternmed.2016.0259. PMID: 27018942.27018942
44 McFalls EO, Ward HB, Moritz TE, . Coronary-artery revascularization before elective major vascular surgery. New En gland Jou rn al o f Med icine. 2004 Dec 30;351(27):2795-804. doi: 10.1056/NEJMoa041905. PMID: WOS:000226004300004.
45 Chang SM, Nabi F, Xu J, . Value of CACS compared with ETT and myocardial perfusion imaging for predicting long-term cardiac outcome in asymptomatic and symptomatic patients at low risk for coronary d is eas e: clin ical imp licat io n s in a mu lt imo d alit y imag in g wo rld. JACC Cardiovasc Imaging. 2015 Feb;8(2):134-44. doi: 10.1016/j.jcmg.2014.11.008. PMID: 25677886.25677886
46 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20(3 Suppl):21-35. PMID: 11306229.11306229
47 Lievre MM, Moulin P, Thivolet C, . Detection of silent myocardial ischemia in asymptomatic patients with diabetes: results of a randomized trial and meta-analysis assessing the effectiveness of systematic screening. Trials. 2011;12:23. doi: 10.1186/1745-6215-12-23. PMID: 21269454.21226970
48 Turrini F, Scarlini S, Mannucci C, . Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients? The DADDY-D trial. Screening diabetic patients for unknown coronary disease. Eur J Intern Med. 2015 Jul;26(6):407-13. doi: 10.1016/j.ejim.2015.05.006. PMID: 26058988.26058988
49 Turrini F, Messora R, Giovanardi P, . Screening asymptomatic patients with diabetes for unknown coronary artery disease: does it reduce risk? An open-label randomized trial comparing a strategy based on exercise testing aimed at revascularization with management based on pharmacological/behavioural treatment of traditional risk factors. DADDY-D Trial (Does coronary Atherosclerosis Deserve to be Diagnosed and treated early in Diabetics?). Trials; 2009. p. 119.20030830
50 Ishikawa J, Ishikawa S, Kario K. Prolonged corrected QT interval is predictive of future stroke events even in subjects without ECG-diagnosed left ventricular hypertrophy. Hypertension. 2015 Mar;65(3):554-60. doi: 10.1161/hypertensionaha.114.04722. PMID: 25534703.25534703
51 Tereshchenko LG, Henrikson CA, Sotoodehnia N, . Electrocardiographic deep terminal negativity of the P wave in V(1) and risk of sudden cardiac death: the Atherosclerosis Risk in Communities (ARIC) study. J Am Heart Assoc. 2014 Dec;3(6):e001387. doi: 10.1161/jaha.114.001387. PMID: 25416036.25416036
52 Jorgensen PG, Jensen JS, Marott JL, . Electrocardiographic changes improve risk prediction in asymptomatic persons age 65 years or above without cardiovascular disease. J Am Coll Cardiol. 2014 Sep 2;64(9):898-906. doi: 10.1016/j.jacc.2014.05.050. PMID: 25169175.25169175
53 Badheka AO, Patel NJ, Grover PM, . ST-T wave abnormality in lead aVR and reclassification of cardiovascular risk (from the National Health and Nutrition Ex amination Survey-III). Am J Cardiol. 2013 Sep 15;112(6):805-10. doi: 10.1016/j.amjcard.2013.04.058. PMID: 23764245.23764245
54 Badheka AO, Patel N, Tuliani TA, . Electrocardiographic abnormalities and reclassification of cardiovascular risk: insights from NHANES-III. Am J Med. 2013 Apr;126(4):319-26.e2. doi: 10.1016/j.amjmed.2012.10.020. PMID: 23415052.23415052
55 Auer R, Bauer DC, Marques-Vidal P, . Association of major and minor ECG abnormalities with coronary heart disease events. JAMA. 2012 Apr 11;307(14):1497-505. doi: 10.1001/jama.2012.434. PMID: 22496264.22496264
56 Cournot M, Taraszkiewicz D, Cambou JP, . Additional prognostic value of physical examination, exercise testing, and arterial ultrasonography for coronary risk assessment in primary prevention. Am Heart J. 2009 Nov;158(5):845-51. doi: 10.1016/j.ahj.2009.08.017. PMID: 19853707.19853707
57 Shah AJ, Vaccarino V, Janssens AC, . An electrocardiogram-based risk equation for incident cardiovascular disease from the National Health and Nutrition Examination Survey. JAMA Cardiol. 2016 Aug 3doi: 10.1001/jamacardio.2016.2173. PMID: 27487404.27487404
58 Denes P, Larson JC, Lloyd-Jones DM, . Major and minor ECG abnormalities in asymptomatic women and risk of cardiovascular events and mortality. JAMA. 2007 Mar 7;297(9):978-85. doi: 10.1001/jama.297.9.978. PMID: 17341712.17341712
59 Aktas MK, Ozduran V, Pothier CE, . Global risk scores and exercise testing for predicting all-cause mortality in a preventive medicine program. JAMA. 2004 Sep 22;292(12):1462-8. doi: 10.1001/jama.292.12.1462. PMID: 15383517.15383517
60 Cournot M, Taraszkiewicz D, Galinier M, . Is exercise testing useful to improve the prediction of coronary events in asymptomatic subjects? Eur J Cardiovasc Prev Rehabil. 2006 Feb;13(1):37-44. PMID: 16449862.16449862
61 Strom Moller C, Zethelius B, Sundstrom J, . Persistent ischaemic ECG abnormalities on repeated ECG examination have important prognostic value for cardiovascular disease beyond established risk factors: a population-based study in middle-aged men with up to 32 years of follow-up. Heart. 2007 Sep;93(9):1104-10. doi: 10.1136/hrt.2006.109116. PMID: 17483125.17483125
62 Erikssen G, Bodegard J, Bjornholt JV, . Exercise testing of healthy men in a new perspective: from diagnosis to prognosis. Eur Heart J. 2004 Jun;25(11):978-86. doi: 10.1016/j.ehj.2004.04.009. PMID: 15172470.15172470
63 Folsom AR, Chambless LE, Duncan BB, . Prediction of coronary heart disease in middle-aged adults with diabetes. Diabetes Care. 2003 Oct;26(10):2777-84. PMID: 14514579.14514579