# References

1 Moyer VA. Screening for coronary heart disease with electrocardiography: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012 Oct 2;157(7):512-8. doi: 10.7326/0003-4819-157-7-201210020-00514. PMID: 22847227.22847227
2 U. S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Statin use for the primary prevention of cardiovascular disease in adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2016 Nov 15;316(19):1997-2007. doi: 10.1001/jama.2016.15450. PMID: 27838723.27838723
3 World Health Organization. Global atlas on cardiovascular disease prevention and control. Geneva: World Health Organization; 2011.
4 World Health Organization. International Statistical Classfication of Diseases and Related Health Problems, 10th Revision (ICD-10). Geneva: World Health Organization; 1992.
5 Abbate R, Cioni G, Ricci I, . Thrombosis and acute coronary syndrome. Thromb Res. 2012 Mar;129(3):235-40. doi: 10.1016/j.thromres.2011.12.026. PMID: 22281070.22281070
6 Moreira DM, da Silva RL, Vieira JL, . Role of vascular inflammation in coronary artery disease: potential of anti-inflammatory drugs in the prevention of atherothrombosis. Inflammation and anti-inflammatory drugs in coronary artery disease. Am J Cardiovasc Drugs. 2015 Feb;15(1):1-11. doi: 10.1007/s40256-014-0094-z. PMID: 25369900.25369900
7 Bentzon JF, Otsuka F, Virmani R, . Mechanisms of plaque formation and rupture. Circ Res. 2014 Jun 6;114(12):1852-66. doi: 10.1161/CIRCRESAHA.114.302721. PMID: 24902970.24902970
8 Santos-Gallego CG, Picatoste B, Badimon JJ. Pathophysiology of acute coronary syndrome. Curr Atheroscler Rep. 2014 Apr;16(4):401. doi: 10.1007/s11883-014-0401-9. PMID: 24504549.24504549
9 Stone GW, Maehara A, Lansky AJ, . A prospective natural-history study of coronary atherosclerosis. N Engl J Med. 2011 Jan 20;364(3):226-35. doi: 10.1056/NEJMoa1002358. PMID: 21247313.21247313
10 Saab F, Mukherjee D, Gurm H, . Risk Factors in first presentation acute coronary syndromes (ACS): how do we move from population to individualized risk prediction? Angiology. 2009 Dec-2010 Jan;60(6):663-7. doi: 10.1177/0003319709333870. PMID: 19729368.19729368
11 D’Agostino RB, Sr., Grundy S, Sullivan LM, . Validation of the Framingham coronary heart disease prediction scores: results of a multiple ethnic groups investigation. JAMA. 2001 Jul 11;286(2):180-7. PMID: 11448281.11448281
12 Expert Panel on Detection Evaluation, Treatment of High Blood Cholesterol in Adults. Executive Summary of the Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III). JAMA. 2001 May 16;285(19):2486-97. PMID: 11368702.11368702
13 Mozaffarian D, Benjamin EJ, Go AS, . Heart disease and stroke statistics--2015 update: a report from the American Heart Association. Circulation. 2015 Jan 27;131(4):e29-322. doi: 10.1161/CIR.0000000000000152. PMID: 25520374.25520374
14 Vasan RS, Sullivan LM, Wilson PW, . Relative importance of borderline and elevated levels of coronary heart disease risk factors. Ann Intern Med. 2005 Mar 15;142(6):393-402. PMID: 15767617.15767617
15 Helfand M, Buckley DI, Freeman M, . Emerging risk factors for coronary heart disease: a summary of systematic reviews conducted for the U.S. Preventive Services Task Force. Ann Intern Med. 2009 Oct 06;151(7):496-507. PMID: 19805772.19805772
16 American Heart Association, American College of Cardiology. Pooled Cohort Equations Cardiovascular Risk Calculator. 2014. http://tools.acc.org/ASCVD-Risk-Estimator/. Accessed May 19, 2017.
17 Bibbins-Domingo K, U. S. Preventive Services Task Force. Aspirin use for the primary prevention of cardiovascular disease and colorectal cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2016 Jun 21;164(12):836-45. doi: 10.7326/M16-0577. PMID: 27064677.27064677
18 Ford ES, Will JC, Mercado CI, . Trends in predicted risk for atherosclerotic cardiovascular disease using the pooled cohort risk equations among US adults from 1999 to 2012. JAMA Intern Med. 2015 Feb;175(2):299-302. doi: 10.1001/jamainternmed.2014.6403. PMID: 25485596.25485596
19 Dehmer SP, Maciosek MV, Flottemesch TJ. Aspirin Use to Prevent Cardiovascular Disease and Cancer: A Decision Analysis. AHRQ Publication 15-05229-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2015.
20 Benjamin EJ, Blaha MJ, Chiuve SE, . Heart disease and stroke statistics-2017 update: a report from the American Heart Association. Circulation. 2017 Mar 07;135(10):e146-e603. doi: 10.1161/CIR.0000000000000485. PMID: 28122885.28122885
21 Fang J, Shaw KM, Keenan NL. Prevalence of coronary heart disease--United States, 2006-2010. MMWR Morb Mortal Wk ly Rep. 2011 Oct 14;60(40):1377-81. PMID: 21993341.21993341
22 Fang J, Shaw KM, George M. Prevalence of stroke--United States, 2006-2010. MMWR Morb Mortal Wk ly Rep. 2012 May 25;61(20):379-82. PMID: 22622094.22622094
23 Lowres N, Neubeck L, Redfern J, . Screening to identify unknown atrial fibrillation. A systematic review. Thromb Haemost. 2013 Aug;110(2):213-22. doi: 10.1160/th13-02-0165. PMID: 23595785.23595785
24 Cholesterol Treatment Trialists Collaboration, Baigent C, Blackwell L, . Efficacy and safety of more intensive lowering of LDL cholesterol: a meta-analysis of data from 170,000 participants in 26 randomised trials. Lancet. 2010 Nov 13;376(9753):1670-81. doi: 10.1016/S0140-6736(10)61350-5. PMID: 21067804.21067804
25 Heart Protection Study Collaborative Group. MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individua ls: a randomised placebo-controlled trial. Lancet. 2002 Jul 06;360(9326):7-22. doi: 10.1016/S0140-6736(02)09327-3. PMID: 12114036.12114036
26 LaRosa JC, Grundy SM, Waters DD, . Intensive lipid lowering with atorvastatin in patients with stable coronary disease. N Engl J Med. 2005 Apr 07;352(14):1425-35. doi: 10.1056/NEJMoa050461. PMID: 15755765.15755765
27 National Cholesterol Education Program Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults. Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002 Dec 17;106(25):3143-421. PMID: 12485966.12485966
28 Robinson JG, Wang S, Smith BJ, . Meta-analysis of the relationship between nonhigh-density lipoprotein cholesterol reduction and coronary heart disease risk. J Am Coll Cardiol. 2009 Jan 27;53(4):316-22. doi: 10.1016/j.jacc.2008.10.024. PMID: 19161879.19161879
29 Stone NJ, Robinson JG, Lichtenstein AH, . 2013 ACC/AHA guideline on the treatment of blood cholesterol to reduce atherosclerotic cardiovascular risk in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Circulation. 2014 Jun 24;129(25 Suppl 2):S1-45. doi: 10.1161/01.cir.0000437738.63853.7a. PMID: 24222016.24222016
30 Chou R, High Value Care Task Force of the American College of Physicians. Cardiac screening with electrocardiography, stress echocardiography, or myocardial perfusion imaging: advice for high-value care from the American College of Physicians. Ann Intern Med. 2015 Mar 17;162(6):438-47. doi: 10.7326/M14-1225. PMID: 25775317.25775317
31 American Academy of Family Physicians. Annual EKGs for Low-risk Patients. 2012. http://www.aafp.org/patient-care/clinical-recommendations/all/cw-ekg.html. Accessed 18 Nov, 2015.
32 Lim LS, Haq N, Mahmood S, . Atherosclerotic cardiovascular disease screening in adults: American College of Preventive Medicine position statement on preventive practice. Am J Prev Med. 2011 Mar;40(3):381 e1-10. doi: 10.1016/j.amepre.2010.11.021. PMID: 21335273.21335273
33 Anderson KM, Odell PM, Wilson PW, . Cardiovascular disease risk profiles. Am Heart J. 1991 Jan;121(1 Pt 2):293-8. PMID: 1985385.1985385
34 Anderson KM, Wilson PW, Odell PM, . An updated coronary risk profile. A statement for health professionals. Circulation. 1991 Jan;83(1):356-62. PMID: 1984895.1984895
35 American Academy of Family Physicians. Family physician interpretation of electrocardiograms. Leawood, KS: American Academy of Family Physicians; 2007.
36 American College of Sports Medicine. ACSM’s Guidelines for Exercise Testing and Prescription. 6th ed. Philadelphia: Lippincott Williams & Wilkins; 2000.
37 Wilson PW, D’Agostino RB, Levy D, . Prediction of coronary heart disease using risk factor categories. Circulation. 1998 May 12;97(18):1837-47. PMID: 9603539.9603539
38 D’Agostino RB, Sr., Vasan RS, Pencina MJ, . General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008 Feb 12;117(6):743-753. doi: 10.1161/CIRCULATIONAHA.107.699579. PMID: 18212285.18212285
39 National Heart, Lung, and Blood Institute. 2013 Report on the Assessment of Cardiovascular Risk: Full Work Group Report Supplement: National Heart, Lung, and Blood Institute; 2013.
40 Shillinglaw B, Viera AJ, Edwards T, . Use of global coronary heart disease risk assessment in practice: a cross-sectional survey of a sample of U.S. physicians. BMC Health Serv Res. 2012 Jan 24;12:20. doi: 10.1186/1472-6963-12-20. PMID: 22273080.22236336
41 Bhatia RS, Bouck Z, Ivers NM, . Electrocardiograms in Low-Risk Patients Undergoing An Annual Health Examination. JAMA Intern Med. 2017 Jul 10doi: 10.1001/jamainternmed.2017.2649. PMID: 28692719.28692719
42 Chou R, Arora B, Dana T, . Screening asymptomatic adults with resting or exercise electrocardiography: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2011 Sep 20;155(6):375-85. doi: 10.7326/0003-4819-155-6201109200-00006. PMID: 21930855.21930855
43 Moons KG, de Groot JA, Bouwmeester W, . Critical appraisal and data extraction for systematic reviews of prediction modelling studies: the CHARMS checklist. PLoS Med. 2014 Oct;11(10):e1001744. doi: 10.1371/journal.pmed.1001744. PMID: 25314315.25314315
44 West SL, Gartlehner G, Mansfield AJ, . Comparative Effectiveness Review Methods: Clinical Heterogeneity Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville, MD: Agency for Healthcare Research and Quality; September 2010. http://www.aafp.org/patient-care/clinical-recommendations/all/cw-ekg.htmlhttp://effectivehealthcare.ahrq.gov/
45 Owens DK, Lohr KN, Atkins D, . AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010 May;63(5):513-23. doi: 10.1016/j.jclinepi.2009.03.009. PMID: 19595577.19595577
46 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 Nov;68(11):1312-24. doi: 10.1016/j.jclinepi.2014.11.023. PMID: 25721570.25721570
47 Aktas MK, Ozduran V, Pothier CE, . Global risk scores and exercise testing for predicting all-cause mortality in a preventive medicine program. JAMA. 2004 Sep 22;292(12):1462-8. doi: 10.1001/jama.292.12.1462. PMID: 15383517.15383517
48 Cournot M, Taraszkiewicz D, Galinier M, . Is exercise testing useful to improve the prediction of coronary events in asymptomatic subjects? Eur J Cardiovasc Prev Rehabil. 2006 Feb;13(1):37-44. PMID: 16449862.16449862
49 Denes P, Larson JC, Lloyd-Jones DM, . Major and minor ECG abnormalities in asymptomatic women and risk of cardiovascular events and mortality. JAMA. 2007 Mar 7;297(9):978-85. doi: 10.1001/jama.297.9.978. PMID: 17341712.17341712
50 Hollenberg M, Zoltick JM, Go M, . Comparison of a quantitative treadmill exercise score with standard electrocardiographic criteria in screening asymptomatic young men for coronary artery disease. N Engl J Med. 1985 Sep 5;313(10):600-6. doi: 10.1056/NEJM198509053131003. PMID: 4022047.4022047
51 Myers J, Arena R, Franklin B, . Recommendations for clinical exercise laboratories: a scientific statement from the american heart association. Circulation. 2009 Jun 23;119(24):3144-61. doi: 10.1161/CIRCULATIONAHA.109.192520. PMID: 19487589.19487589
52 Lievre MM, Moulin P, Thivolet C, . Detection of silent myocardial ischemia in asymptomatic patients with diabetes: results of a randomized trial and meta-analysis assessing the effectiveness of systematic screening. Trials. 2011;12:23. doi: 10.1186/1745-6215-12-23. PMID: 21269454.21226970
53 Turrini F, Scarlini S, Mannucci C, . Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients? The DADDY-D trial. Screening diabetic patients for unknown coronary disease. Eur J Intern Med. 2015 Jul;26(6):407-13. doi: 10.1016/j.ejim.2015.05.006. PMID: 26058988.26058988
54 Chang SM, Nabi F, Xu J, . Value of CACS compared with ETT and myocardial perfusion imaging for predicting long-term cardiac outcome in asymptomatic and symptomatic patients at low risk for coronary disease: clinical implications in a multimodality imaging world. JACC Cardiovasc Imaging. 2015 Feb;8(2):134-44. doi: 10.1016/j.jcmg.2014.11.008. PMID: 25677886.25677886
55 Cournot M, Taraszkiewicz D, Cambou JP, . Additional prognostic value of physical examination, exercise testing, and arterial ultrasonography for coronary risk assessment in primary prevention. Am Heart J. 2009 Nov;158(5):845-51. doi: 10.1016/j.ahj.2009.08.017. PMID: 19853707.19853707
56 Erikssen G, Bodegard J, Bjornholt JV, . Exercise testing of healthy men in a new perspective: from diagnosis to prognosis. Eur Heart J. 2004 Jun;25(11):978-86. doi: 10.1016/j.ehj.2004.04.009. PMID: 15172470.15172470
57 Badheka AO, Patel N, Tuliani TA, . Electrocardiographic abnormalities and reclassification of cardiovascular risk: insights from NHANES-III. Am J Med. 2013 Apr;126(4):319-26.e2. doi: 10.1016/j.amjmed.2012.10.020. PMID: 23415052.23415052
58 Auer R, Bauer DC, Marques-Vidal P, . Association of major and minor ECG abnormalities with coronary heart disease events. JAMA. 2012 Apr 11;307(14):1497-505. doi: 10.1001/jama.2012.434. PMID: 22496264.22496264
59 Shah AJ, Vaccarino V, Janssens AC, . An electrocardiogram-based risk equation for incident cardiovascular disease from the National Health and Nutrition Examination Survey. JAMA Cardiol. 2016 Aug 3doi: 10.1001/jamacardio.2016.2173. PMID: 27487404.27487404
60 Jorgensen PG, Jensen JS, Marott JL, . Electrocardiographic changes improve risk prediction in asymptomatic persons age 65 years or above without cardiovascular disease. J Am Coll Cardiol. 2014 Sep 2;64(9):898-906. doi: 10.1016/j.jacc.2014.05.050. PMID: 25169175.25169175
61 Ishikawa J, Ishikawa S, Kario K. Prolonged corrected QT interval is predictive of future stroke events even in subjects without ECG-diagnosed left ventricular hypertrophy. Hypertension. 2015 Mar;65(3):554-60. doi: 10.1161/hypertensionaha.114.04722. PMID: 25534703.25534703
62 Tereshchenko LG, Henrikson CA, Sotoodehnia N, . Electrocardiographic deep terminal negativity of the P wave in V(1) and risk of sudden cardiac death: the Atherosclerosis Risk in Communities (ARIC) study. J Am Heart Assoc. 2014 Dec;3(6):e001387. doi: 10.1161/jaha.114.001387. PMID: 25416036.25416036
63 Badheka AO, Patel NJ, Grover PM, . ST-T wave abnormality in lead aVR and reclassification of cardiovascular risk (from the National Health and Nutrition Examination Survey-III). Am J Cardiol. 2013 Sep 15;112(6):805-10. doi: 10.1016/j.amjcard.2013.04.058. PMID: 23764245.23764245
64 Folsom AR, Chambless LE, Duncan BB, . Prediction of coronary heart disease in middle-aged adults with diabetes. Diabetes Care. 2003 Oct;26(10):2777-84. PMID: 14514579.14514579
65 Perk J, De Backer G, Gohlke H, . European Guidelines on cardiovascular disease prevention in clinical practice (version 2012). The Fifth Joint Task Force of the European Society of Cardiology and Other Societies on Cardiovascular Disease Prevention in Clinical Practice (constituted by representatives of nine societies and by invited experts). Eur Heart J. 2012 Jul;33(13):1635-701. doi: 10.1093/eurheartj/ehs092. PMID: 22555213.22555213
66 Paynter NP, Cook NR. A bias-corrected net reclassification improvement for clinical subgroups. Med Decis Making. 2013 Feb;33(2):154-62. doi: 10.1177/0272989X12461856. PMID: 23042826.23042826
67 Blumenthal RS, Becker DM, Yanek LR, . Detecting occult coronary disease in a high-risk asymptomatic population. Circulation. 2003 Feb 11;107(5):702-7. PMID: 12578872.12578872
68 Boyle RM, Adlakha HL, Mary DA. Diagnostic value of the maximal ST segment/heart rate slope in asymptomatic factory populations. J Electrocardiol. 1987 Oct;20 Suppl:128-134. PMID: 3320257.3320257
69 Davies B, Ashton WD, Rowlands DJ, . Association of conventional and exertional coronary heart disease risk factors in 5,000 apparently healthy men. Clin Cardiol. 1996 Apr;19(4):303-8. PMID: 8706370.8706370
70 Dunn RL, Matzen RN, VanderBrug-Medendorp S. Screening for the detection of coronary artery disease by using the exercise tolerance test in a preventive medicine population. Am J Prev Med. 1991 Sep-Oct;7(5):255-62. PMID: 1790029.1790029
71 Livschitz S, Sharabi Y, Yushin J, . Limited clinical value of exercise stress test for the screening of coronary artery disease in young, asymptomatic adult men. Am J Cardiol. 2000 Aug 15;86(4):462-4. PMID: 10946046.10946046
72 Massie BM, Szlachcic Y, Tubau JF, . Scintigraphic and electrocardiographic evidence of silent coronary artery disease in asymptomatic hypertension: a case-control study. J Am Coll Cardiol. 1993 Nov 15;22(6):1598-606. PMID: 8227826.8227826
73 Piepgrass SR, Uhl GS, Hickman JR, Jr., . Limitations of the exercise stress test in the detection of coronary artery disease in apparently healthy men. Aviat Space Environ Med. 1982 Apr;53(4):379-82. PMID: 7082255.7082255
74 Pilote L, Pashkow F, Thomas JD, . Clinical yield and cost of exercise treadmill testing to screen for coronary artery disease in asymptomatic adults. Am J Cardiol. 1998 Jan 15;81(2):219-24. PMID: 9591907.9591907
75 Fazel R, Krumholz HM, Wang Y, . Exposure to low-dose ionizing radiation from medical imaging procedures. N Engl J Med. 2009 Aug 27;361(9):849-57. doi: 10.1056/NEJMoa0901249. PMID: 19710483.19710483
76 Choosing Wisely. EKGs and exercise stress tests When you need them-and when you don’t. Philadelphia, PA: Choosing Wisely® is an initiative of the ABIM Foundation©. All rights reserved; 2017. http://www.choosingwisely.org/patient-resources/ekgs-and-exercise-stress-tests/. Accessed November 13, 2017.
77 Gordon NF, Kohl HW. Exercise testing and sudden cardiac death. J Cardiopulm Rehabil Prev. 1993;13:381-6.
78 American College of Sports Medicine. ACSM’s Guidelines for Exercise Testing and Prescription. 7th ed. Philadelphia: Lippincott Williams & Wilkins; 2006.
79 Han BH, Sutin D, Williamson JD, . Effect of statin treatment vs usual care on primary cardiovascular prevention among older adults: The ALLHAT-LLT Randomized Clinical Trial. JAMA Intern Med. 2017 May 22 doi: 10.1001/jamainternmed.2017. 1442. PMID: 28531241.28531241
80 Rados DV, Pinto LC, Leitao CB, . Screening for coronary artery disease in patients with type 2 diabetes: a meta-analysis and trial sequential analysis. BMJ Open. 2017 May 09;7(5):e015089. doi: 10.1136/bmjopen-2016-015089. PMID: 28490559.28490559