# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their considerable support, commitment, and contributions: Howard Tracer, MD, AHRQ Medical Officer, and Elisabeth Kato, MD, MRP, former AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers Joy Melnikow, MD, MPH, Amit Shah, MD, Fabrizio Turrini, MD, and Timothy Wilt, MD; federal partner reviewers at the National Institutes of Health; and RTI International—University of North Carolina EPC staff Carol Woodell, BSPH, Christiane Voisin, MSLS, Laurie Leadbetter, MSLS, Sharon Barrell, MA, and Loraine Monroe, publications specialist.