# 4 Discussion

## Summary of Evidence

Tables 8 and 9 provide a summary of findings in this evidence review. Table 8 is organized by KQ and provides a summary of the main findings along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability. For KQ 2, the summary of evidence for exercise ECG and resting ECG was separated. The overall strength of evidence was low or insufficient for each of the questions and outcomes evaluated. No RCTs of screening with resting ECG were found; RCTs of exercise ECG in asymptomatic participants found no improvement in health outcomes despite focusing on higher risk populations with diabetes, although they were limited by not reaching sample size targets. Scant direct evidence on harms of screening asymptomatic persons with ECG was found. Evidence on whether the addition of exercise ECG to traditional CVD risk factors results in accurate reclassification is lacking. Cohort studies found that the addition of multiple resting ECG abnormalities to traditional CVD risk factors accurately reclassifies persons, and improves discrimination and calibration, but evidence was limited by imprecision, quality, considerable heterogeneity, and inconsistent use of risk thresholds that align with clinical decisions and recommendations.

Table 8 Summary of Evidence for Screening With ECG

Key Question and Topic | No. of Studies, Study Design | N | Summary of Main Findings (Including Consistency and Precision) | Quality | Limitations (Including Reporting Bias) | Strength of Evidence | Applicability
1: Benefits of screening with ECG | 2 RCTs | 1,151 | Neither study found a statistically significant reduction in events, including their primary outcomes,^a^ all-cause mortality, cardiovascular-related mortality, Ml, heart failure, or stroke. Findings were consistent and imprecise. | 2 Fair | Neither trial reached sample size targets; stopped early because of trouble recruiting. Not clear that 3.5 years of follow up is sufficient. Masking of outcome assessors and amount of missing data NR in 1.^53^ Reporting bias not detected. | Low for no benefit of screening with exercise ECG Insufficient for resting ECG; no studies | Asymptomatic adults ages 50 to 75 years with diabetes undergoing exercise ECG; both trials enrolled high risk populations
2: Reclassification, calibration, and discrimination for exercise ECG | 5 cohort studies | 9,582 | Discrimination (k=3): small absolute improvement in AUC or C-statistics (0.02-0.03); none reported 95% CIs; 1 reported p=0.3 (no significant difference between models). Consistent; imprecise. Calibration or performance (k=4 total; k=2 FRS base model): all 4 used different metrics;^b^ none reported figures such as calibration plots;^c^ k=3 reported improvement with addition of exercise ECG variables; mixed results for the 2 with FRS base models. Inconsistent; imprecise. Reclassification (k=1 model development study, 988 participants): Total NRI 9.6% (p=0.007); intermediate risk group NRI 18.9% (p=0.01). Consistency unknown; imprecise. | 5 Fair | Confidence intervals for calibration or discrimination NR (k=5); mean duration of follow up <10 years^d^(k=4), reclassification NR (k=4); unknow n masking of outcome assessors (k=4); not reporting both discrimination and calibration (k=3); model development studies (k=2); unclear handling and amount of missing data (k=2); the 1 study reporting NRI was a model development study, used risk categories of <6% vs. 6-20% vs. >20% and may have included many symptomatic participants.^e^ Reporting bias not detected. | Discrimination: Low for small improvement Calibration: Insufficient Reclassification: Insufficient | Adults without a history of CVD; mean age of participants 50-58 years; range of females was 0-38%; race/ethnicity NR in most (k=4); mean baseline FRS score was 10.8-12.3 in studies reporting it (k=3); intermediate risk, on average
2: Reclassification, calibration, and discrimination for resting ECG | 9 cohort studies | 66,407 | Discrimination (k=7 total; k=4 FRS or PCE base model; k=4 multiple ECG changes): very small to small absolute improvement in AUC or C-statistics (0.001-0.05); Few (k=3) reported whether differences were statistically significant. Consistent; imprecise. | 8 Fair; 1 Good | Limited reporting on assessment of symptoms; unclear what proportion of participants were truly asymptomatic. | Discrimination: Low for very small to small improvement Calibration: Low for improvement | Adults without a history of CVD; mean age of participants 54-73; majority were women in all studies.
2: Reclassification, calibration, and discrimination for resting ECG (continued) | | | Calibration or performance (k=4 total; k=2 FRS + major/rtinor ECG changes; k=1 FRS + specific T wave change): none reported calibration plots; variety of metrics used; good calibration w ith addition of major/minor changes (k=2) or T wave amplitude in lead aVR (k=1) to FRS. Poor calibration with addition of major/minor changes to FRS variables (k=1 model development of older adults 70-79). Consistent among studies using published coefficients (k=3); imprecise. Reclassification (k=7 total with59,123 participants; k=3 FRS or PCE + multiple ECG changes; k=1 FRS + specific T wave change). Overall, total NRIs (event; nonevent) range from 3.6% (2.7%; 0.6%) to 30% (17%; 19%) for studies using FRS or PCE base models (95% CIs rarely reported [Figure 7]).^f^ Consistent in all showing improved NRI, but inconsistent for estimates of NRI and outcomes assessed; consistency unknown for specific risk categories because all studies used different risk categories; imprecise. | | Masking of outcome assessors NR (k=8), confidence intervals for calibration or discrimination NR (k=5), not reporting calibration (k=5), model development studies (k=4), amount of missing data NR (k=2), and mean duration of follow up less than 10 years (k=2). For reclassification, few studies (k=3) included a threshold between risk categories corresponding to the recommendations for preventive medications (i.e., 7.5% or 10% 10-year risk). | Reclassification: Low for improvement | Range of nonw hite participants in those that reported race/ethnicity (k=6) was 9-41%. Mean baseline risk ranging from low to high across studies
3: Harms of screening with ECG | 1 RCT | 520 | One patient out of 12 (8.3%) undergoing revascularization procedures after positive exercise treadmill tests in the DADDY-D trial had a nonfatal acute Ml 3 days after percutaneous revascularization and underwent a second percutaneous angioplasty.^g^ Consistency unknow n (single study); imprecise. | 1 Fair | Trial focused on assessing benefits; did not reach sample size target; not clear that mean of 3.6 years of follow up is sufficient; masking of outcome assessors NR and amount of missing data NR. Reporting bias not detected. | Insufficient | Asymptomatic adults ages 55 to 75 years with diabetes undergoing screening with exercise ECG

a For the primary composite outcomes. HRs were 1.00 (0.59 to 1.71) for a composite of death from all causes, nonfatal MI. nonfatal stroke, or heart failure requiring hospitalization or emergency service intervention. and 0.85 (0.39 to 1.84) for a composite of nonfatal MI or cardiac death.

b Metrics included likelihood ratio test; Akaike information criteria (AIC). Brier’s score, and Hosmer-Lemeshow χ^2^; global χ^2^; and numbers of predicted and observed events.

c One model development study provided a table of predicted and observed events for quintiles of risk.^56^

d The only study reporting longer followup covered 26 years, but it did not account for HDL in analyses.^56^

e 16.5% had atypical chest pain and participants were a subset of those having CACS and SPECT for “clinically indicated reasons.”^54^

f For multiple ECG changes (on resting 12-lead ECG). total NRIs (event NRIs; nonevent NRIs) for studies using any base model ranged from 1.9% (-0.2%; 0.6%) to 30% (17%; 19%).

g The DADDY-D trial reported that 20/262 participants (7.6%) in the screened group had positive ETTs. Of those 20, 17 underwent coronary angiography (6.5% of the 262). Angiography revealed critical stenosis (not defined) in 71% (12/17). and all patients with critical stenosis underwent revascularization procedures (7 percutaneous. 5 surgical). The DYNAMIT trial (included in KQ 1) reported the number of some subsequent tests but did not report whether any of the tests or interventions resulted in harms; adverse events that occurred during followup were not recorded.^52^ Sixty eight of the 316 participants (21.5%) in the screened group had a definitely abnormal or an uncertain screening test (exercise test or SPECT) result. Of those. 38 underwent coronary angiography (12% of the 316 in the screened group) and 9 subsequently underwent coronary angioplasty (7/9 received stents) and 3 had coronary artery bypass graft.

Abbreviations: AIC=Akaike information criteria; AUC=area under the curve; CACS=coronary artery calcium score; CI=confidence interval; CVD=cardiovascular disease; DADDY-D=Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients; DYNAMIT=Do YouNeed to Assess Myocardial Ischemia in Type-2 diabetes;ECG=electrocardiogram; FRS=Framingham Risk Score; HDL=high-density lipoprotein; HR=hazard ratio; k=number of studies; KQ=key question; MI=myocardial infarction;N=number; NR=not reported; NRI=net reclassification improvement; PCE=pooled cohort equations; RCT=randomized. controlled trial; SPECT=single-phot on emission computed tomography.

Table 9 Snapshot to Assess Net Benefit

Key Question | Exercise ECG | Resting ECG | Considerations
Benefits
KQ 1: Benefits of screening | k=2; n=1,151 No statistically significant difference in primary composite outcomes, all-cause mortality, CV-related mortality, Ml, heart failure, or stroke at 3.5 years | No evidence | Despite enrolling high-risk persons with diabetes, neither trial found benefit. But neither reached sample size targets; stopped early because of trouble recruiting. Findings were imprecise. Not clear that 3.5 years of followup is sufficient. Masking of outcome assessors and amount of missing data not reported in 1 trial.
KQ 2: Calibration | k=4; n=6,762 Mixed results (and all 4 used different metrics) | k=4; n=17,409 Improved calibration among studies using published coefficients of FRS (k=3). Poor calibration in 1 model development of older adults ages 70-79 years. | Preferred measures rarely reported. For resting ECG: none reported calibration plots; limited reported on assessment of symptoms; unclear what proportion of participants were truly asymptomatic; majority of the resting ECG studies did not report calibration (k=5 out of 9); imprecise.
KQ 2: Discrimination | k=3; n=7,251 Small improvement | k=7; n =44,699 Very small to small improvement | Overall, results were consistent but imprecise. For exercise ECG: 95% CIs were not reported (1 reported p=0.3, no significant difference between models). For resting ECG: k=4 FRS or PCE base model; few (k=3) reported whether differences were statistically significant.
KQ 2: Reclassification | k=1; n=988 Improvement (total NRI 9.6%, p=0.007; intermediate risk group NRI 18.9%, p=0.01) | k=7; n=59,123 Improvement for studies using FRS or PCE base models (k=4): total NRIs (event; nonevent) range from 3.6% (2.7%; 0.6%) to 30% (17%; 19%) | Heterogeneity and applicability of risk thresholds; 95% CIs rarely reported. For exercise ECG: 1 model development study that used risk categories of <6% vs. 6-20% vs. >20% and may have included many symptomatic participants. For resting ECG: consistent in all showing improved NRI but inconsistent for estimates of NRI and outcomes assessed; consistency unknow n for specific risk categories because all studies used different risk categories.
Harms
KQ 3: Screening | k=1; n=520 1/12 persons (8.3%) undergoing revascularization after positive exercise tests had a nonfatal acute Ml 3 days after the procedure | No evidence | Only 1 study eligible withl event reported. More information about potential harms is in the Discussion and contextual question 2.

Abbreviations: CI=confidence interval; CV=cardiovascular; ECG=electrocardiogram; ERS=Framingham Risk Score; KQ=key question; MI=myocardial infarction; NRI=net reclassification improvement; PCE=pooled cohort equations.

### Evidence for the Benefits and Harms of Screening With Resting or Exercise ECG

No eligible studies compared screening with resting ECG and no screening, and none evaluated the use of screening with ECG for the purpose of risk reclassification to inform decisions about whether to initiate preventive medications. Two RCTs (DYNAMIT and DADDY-D, total of 1,151 participants) evaluated screening with exercise ECG in asymptomatic adults ages 50 to 75 years with diabetes compared with no screening and found no statistically significant improvement in health outcomes, including their primary composite outcomes, all-cause mortality, CV-related mortality, MI, heart failure, or stroke. Findings from the two studies were consistent but imprecise. For the primary composite outcomes, HRs were 1.00 (95% CI, 0.59 to 1.71) for a composite of death from all causes, nonfatal MI, nonfatal stroke, or heart failure requiring hospitalization or emergency service intervention and 0.85 (95% CI, 0.39 to 1.84) for a composite of nonfatal MI or cardiac death. Some key limitations of the trials include not reaching sample size targets and stopping early because of trouble recruiting. Both trials followed participants for about 3.5 years, and longer followup may be needed to adequately evaluate screening with exercise ECG. The overall strength of evidence for whether screening with exercise ECG improves health outcomes was low (for no benefit) because of imprecision and risk of bias.

The participants in the included trials were higher risk groups that would be, in theory, more likely to benefit from screening with exercise ECG to identify silent ischemia. For example, in DYNAMIT, participants had diabetes plus two of the following additional risk factors: urinary albumin excretion above a threshold, hypertension, hyperlipidemia, history of PAD (14%), history of TIA (4 to 5%), tobacco consumption, or family history of premature CVD. However, even among these higher risk groups of asymptomatic diabetics, screening with exercise ECG (followed by referral to cardiology [DYNAMIT] or recommendation for coronary angiography [DADDY-D] for those with abnormal exercise ECGs) did not improve health outcomes.

Potential harms of screening asymptomatic adults with resting or exercise ECG include mortality, arrhythmia, CV events, injuries, anxiety, labeling, and harms of subsequent procedures or interventions initiated as a result of screening (e.g., subsequent angiography or revascularization procedures resulting in harm). Both DYNAMIT and DADDY-D reported numbers of subsequent tests and interventions after abnormal exercise tests, but just one (DADDY-D) reported whether any of the tests or interventions resulted in harms (1/12 [8.3%] undergoing percutaneous revascularization had a nonfatal acute MI 3 days later). Among asymptomatic diabetics, DADDY-D and DYNAMIT reported that 7.6 percent (20/262 screened) had abnormal ETTs and 21.5 percent (68/316 screened) had definitely abnormal or uncertain bicycle exercise or SPECT results, respectively. Most of those with abnormal screening tests underwent coronary angiography (DADDY-D: 17/262, 6.5%; DYNAMIT 38/316, 12%), and some had revascularization procedures (12/262, 4.6% and 12/316, 3.8%, respectively).

No other eligible studies reported rates of harms for asymptomatic adults. Studies without control groups were eligible if they were multicenter studies or registries that reported rates of harms from exercise ECG or subsequent procedures/interventions specifically for asymptomatic persons. A single site study of 377 asymptomatic military officers (mean age 37) at one station in the Midwestern United States reported that none had complications during exercise testing.^50^ Of the 377, 45 (11.9%) had abnormal exercise test results and 10 (2.7%) underwent coronary angiography. Of those, one was reported to have “mild CAD.” Many other studies have reported rates of angiography (but no information on harms) for asymptomatic persons after exercise ECG; rates have ranged from 0.6 percent to 13 percent, although most reported rates less than 3 percent.^47,48,50,67-74^ Rates of subsequent revascularization have also been reported by some, with those studies estimating lower rates than reported by DADDY-D and DYNAMIT. For example, two studies (with 3,554 and 1,051 participants, respectively) reported rates of 0.1 percent to 0.5 percent undergoing revascularization after screening exercise ECG.^47,48^ Little is known about the harms of revascularization procedures for adults without symptoms or a prior diagnosis of CVD (Appendix A). Regardless of symptom status, some tests that follow an abnormal ECG expose patients to radiation, including coronary angiography, computed tomography angiography, and myocardial perfusion imaging.^75^ Coronary angiography can expose patients to as much radiation as 600 to 800 chest X-rays.^76^

Studies that focused on symptomatic adults have reported rates of harms of exercise ECG and harms of subsequent procedures/interventions. The scientific statement from the AHA with recommendations for clinical exercise laboratories reports that the complication rate is usually considered to be approximately 1 in 10,000^51^ (0.01%). It references a review of eight studies estimating sudden cardiac death during exercise testing that reported rates from zero to 0.005 percent (5 per 100,000 tests).^51,77^ The statement also notes that survey data provide estimates of rates for complications: hospitalization including serious arrhythmias (0.2% or less), acute MI (0.04%), or sudden cardiac death during or immediately after an exercise test (0.01%).^51,78^

### Reclassification, Calibration, and Discrimination With the Addition of Resting or Exercise ECG to Traditional CVD Risk Factor Assessment

No consensus exists for the thresholds that should be considered clinically significant changes in discrimination (e.g., AUC, C-statistic), calibration, or reclassification (e.g., NRI). Changes in these measures are important to evaluate in the context of each other, but appropriate reclassification (NRI) has the most direct clinical meaning. Nevertheless, studies must use clinically meaningful risk categories (i.e., that correspond to clinical decisions, such as 7.5% or 10% 10-year risk) to allow for the potential clinical significance of NRI results to be assessed. Further, interpreting NRI is not simple because it is unfamiliar to many and it is calculated from four proportions. For more clear interpretation, focusing on the event NRI and nonevent NRI components may help. For example, nonevent NRI is the net downward reclassification (i.e., appropriate reclassification) among persons who did not have an event; it is calculated as the proportion of persons without an event who were appropriately reclassified into a lower risk group minus the proportion of those without an event who were inappropriately reclassified into a higher risk group.

For exercise ECG, although evidence from five cohort studies (9,582 participants) shows that the addition of exercise ECG results to traditional CVD risk factors results in small improvements in discrimination (absolute improvement in AUC or C-statistics 0.02 to 0.03), it is uncertain whether calibration or appropriate risk classification improves. Evidence was limited by imprecision and risk of bias for all outcomes and by inconsistency or unknown consistency for calibration and reclassification outcomes. Some important limitations of the evidence include that CIs for calibration or discrimination were not reported; mean duration of followup was less than 10 years in four of the five studies; reclassification was only reported by one study; unknown masking of outcome assessors in four studies; and not reporting both discrimination and calibration in three studies. The only study reporting reclassification was a model development study (i.e., used FRS variables but did not use published coefficients) that used risk categories of <6 percent, 6 to 20 percent, and >20 percent and may have included many symptomatic participants (because 16.5% had atypical chest pain and participants were a subset of those having CACS and SPECT for “clinically indicated reasons”).^54^ Also, we found an absence of evidence related to exercise ECG for healthy, low risk persons (e.g., mean age was 50 to 58 and mean baseline FRS score was 10.8 to 12.3 in studies reporting it).

For resting ECG, evidence from nine cohort studies (66,407 participants) shows that the addition of ECG findings to traditional CVD risk factors results in very small or small improvements in discrimination (absolute improvement in AUC or C-statistics 0.001 to 0.05) and in improvements for calibration and appropriate risk classification for prediction of all-cause mortality, CVD mortality, CHD events, or CVD events. Total NRIs (event; nonevent) range from 3.6 percent (2.7%; 0.6%) to 30 percent (17%; 19%) for studies using FRS or PCE base models (95% CIs were rarely reported). However, evidence was limited by imprecision and risk of bias for all outcomes and by incomplete and inconsistent reporting of discrimination, calibration, and reclassification measures. For reclassification, although evidence consistently showed improved NRI, the estimates of NRI and the outcomes assessed were inconsistent, and the consistency of findings is unknown for specific risk thresholds because all studies used different risk categories. The body of evidence also had considerable heterogeneity in baseline prediction models used, type of ECG abnormalities added to base models, and outcomes assessed (e.g., all-cause mortality, CVD mortality, CHD events). The reported discrimination of base models varied widely, ranging from inadequate to excellent (AUC or C-statistics from 0.58 to 0.85) likely because of the different outcomes, different patient populations, and different base models used. Only one study used the base model for risk prediction (i.e., the PCE) that the USPSTF and ACC/AHA currently recommend to inform clinical decisions about preventive medications.

An important limitation of the evidence was a lack of reporting on any assessment of symptoms; it is unclear what proportion of participants was truly asymptomatic in most of the studies of resting ECG. Perhaps the proportion with symptoms is likely to be relatively low given that the studies were population based and most of them excluded persons with a history of CVD, but it is uncertain whether enrolling even a small percentage of symptomatic participants could artificially inflate estimates of appropriate reclassification. Other important limitations included unknown masking of outcome assessors in eight studies, CIs for calibration or discrimination were not reported in five studies, calibration or overall performance was not reported in five studies, and not using established risk prediction models with published coefficients in four studies (i.e., model development studies).

For NRI, event and nonevent NRI components were often not reported as recommended. Although an overall positive value of NRI indicates net appropriate reclassification into appropriate risk strata, the clinical implications can be very different if the majority of patients are those with events being shifted into higher risk categories (event NRI) as opposed to those without events being shifted into lower risk categories (nonevent NRI). Although the addition of ECG abnormalities to conventional risk factors improves total NRI in both cases, one might lead to an increase in preventive medications, while the other suggests a possible reduction in the use of preventive medications.

For reclassification with resting ECG, few studies included a threshold between risk categories corresponding to the USPSTF recommendations for preventive medications (i.e., 7.5% or 10% 10-year risk). The potential for appropriate reclassification based on the addition of major and minor ECG changes to existing models (PCE or FRS) initially looks promising when viewing Figure 7 because studies reported increases in total appropriate reclassification (total NRI), appropriate reclassification of persons with events to higher risk categories (event NRI), and appropriate reclassification of persons without events to lower risk categories (nonevent NRI). However, several cautions should be noted: (1) no two studies evaluated the same model, risk category thresholds, and outcome. Therefore, none of the models that included ECG variables have been validated in more than one study; (2) no CIs were provided for most of that data; (3) NRI is highly dependent on risk category thresholds, which varied widely across these studies; (4) evaluating risk reclassification using four categories to determine NRI is potentially not clinically meaningful (or is less clinically meaningful than using fewer categories) and may artificially make the reclassification look better because each reclassification counts as a positive move for the NRI if someone with an event moves from any lower to any higher category regardless of whether the change would correspond to different treatment decisions (likewise for someone without an event who moves into any lower risk category); (5) a single study^59^ accounts for six of the nine rows in Figure 7. It reported NRI for three different base models for prediction of several mortality outcomes but did not evaluate prediction of CHD or CVD events because it used NHANES data that do not have that capability. The study is limited by using risk category thresholds of 1, 5, and 10 percent and not reporting the full reclassification table to allow determination of how much of the NRI was accounted for by reclassification that should change clinical decisions (e.g., from 5 to 9.9% to 10% or greater risk for persons with events) versus how much was accounted for by reclassification that would have no effect on clinical decisions and outcomes (e.g., from 1 to 4.9% to <1% for persons without events). The study^59^ is also the only study that evaluated adding an ECG risk equation to base models; (6) another study^58^ in Figure 7 is limited by only having 7.5 years of followup. It also focused on elderly participants ages 70 to 79 years and did not report event NRI or nonevent NRI (or the data to calculate those) for the addition of ECG changes to the FRS base model (those were reported for a model development part of the study and showed net inappropriate reclassification for persons who had events, event NRI -0.9%). It is uncertain whether risk reclassification could provide clinically useful information for this population given recent evidence on lack of benefit of statins for primary prevention in elderly persons of similar age^79^ and given the USPSTF I statement on initiation of aspirin for primary prevention in adults age 70 years or older.

## Limitations

This review did not evaluate the evidence on preventive medications (i.e., aspirin and lipid lowering therapy) that could be initiated based on risk reclassification or the evidence on benefits and harms of lifestyle counseling to reduce CV risk. Other systematic reviews for the USPSTF have evaluated that evidence. But one of the contextual questions (Appendix A) summarizes what medications (i.e., aspirin, lipid-lower ing therapy) are recommended for persons in various CVD risk categories. This review did not systematically review the benefits and harms of revascularization procedures; contextual question 2 (Appendix A) summarizes information on the harms and benefits of revascularization procedures for adults without symptoms or a prior diagnosis of CVD.

For KQ2 (reclassification, calibration, and discrimination), it was sometimes challenging to determine whether studies used published coefficients (e.g., used the FRS or PCE) or whether they were model development studies that used the FRS variables. Study authors were contacted to clarify the uncertainty, but some did not respond. Therefore, some studies could be misclassified (regarding model development vs. published coefficients). For KQ2, we used qualitative terms (e.g., very small, small, moderate) to describe the magnitude of changes in discriminat ion. These qualitative terms are meant only to be descriptive of specific numeric ranges and are not intended to indicate a corresponding clinically meaningful benefit for health outcomes. No consensus exists for the thresholds that should be considered clinically meaningful changes in the AUC/C-statistic or NRI.

For KQ 3 (harms of screening), for studies without control groups to be eligible for this review, studies were required to be multicenter studies or from large registries. This approach excluded a single center study of 377 asymptomatic military officers^50^; that study is described above in the Discussion. This review did not evaluate harms from ECG or subsequent procedures/interventions for symptomatic populations.

This review was limited to studies assessing resting ECG or exercise ECG. A previously published meta-analysis evaluated any screening test for coronary artery disease in persons with type 2 diabetes.^80^ It identified five trials (including DYNAMIT and DADDY-D) with a total of 3,315 participants. The trials that were not eligible for our review evaluated stress scintigraphy, coronary CT angiography, or stress echocardiography with exercise ECG. Pooled analyses found no statistically significant association with all-cause mortality (RR, 0.95; 95% CI, 0.66 to 1.35) or cardiac events (RR, 0.72; 95% CI, 0.49 to 1.06).

## Future Research Needs

To better understand whether risk classification is improved in a clinically useful way that is likely to improve health outcomes, risk prediction studies that evaluate the addition of ECG abnormalities to the PCE (as the base model) would be most useful because the PCE is the approach currently recommended by the USPSTF and ACC/AHA to assess 10-year risk and to inform decisions about preventive medications. Only one included study used the PCE as the base model. Studies of a constellation of resting ECG changes (e.g., major and minor changes based on the Minnesota code) show greater promise than those of single ECG changes and should likely be the focus of future research. Future risk studies should use clinically meaningful risk categories that correspond to recommendations about preventive medications to determine how many persons are appropriately reclassified in a manner that would lead to additional or fewer preventive medication treatments. Specifically, when considering the USPSTF recommendations for statins and aspirin, evaluating NRI related to the 10% 10-year risk threshold is of great interest. Future studies should evaluate asymptomatic populations (with some assessment of symptom status to avoid enrolling those with angina, atypical chest pain, or dyspnea, for example) and should exclude those with a history of CVD. Measures of discrimination, calibration, and reclassification (including total NRI, event NRI, and nonevent NRI) and their corresponding CIs should be reported.

## Conclusion

The overall strength of evidence was low or insufficient for each of the questions and outcomes evaluated. Controlled trials of screening with exercise ECG in asymptomatic diabetic patients found no improvement in health outcomes over about 3.5 years but were limited by not reaching sample size targets and stopping early because of trouble recruiting. No controlled trials evaluated screening with resting ECG for asymptomatic adults. Potential harms of exercise ECG include arrhythmias, acute MI, and sudden cardiac death. Potential harms of both exercise and resting ECG include harms of subsequent angiography or revascularization procedures after an abnormal test, but little evidence exists to determine their frequency in asymptomatic persons. Some evidence suggests that the addition of exercise ECG to traditional risk factors results in small improvements in discrimination, but it is uncertain whether calibration or appropriate risk classification improves. Cohort studies found that the addition of multiple resting ECG findings to traditional risk factors improves discrimination (small absolute improvement in AUC or Cstatistics), calibration, and appropriate risk classification, but evidence was limited by imprecision, quality, considerable heterogeneity, and unknown consistency for specific risk thresholds because studies used different risk categories.