# 3 Results

## Literature Search

In total, 4,595 unique records were identified and 524 full texts assessed for eligibility (Figure 2). In total, 507 articles were excluded for various reasons detailed in Appendix C, and 16 studies (described in 17 articles) of good or fair quality were included. Of the included studies, two were studies of the benefits of ECG screening (KQ 1); 14 were studies of reclassification, calibration, or discrimination; and one study was of harms of ECG screening (KQ 3, which was also included for KQ 1). Compared with the previous evidence review for the USPSTF,^42^ the current review includes three studies^47-49^ that were in both reviews and 13 studies that are only in the current review. The previous review included many additional studies reporting associations (e.g., adjusted hazard ratios) between ECG findings and outcomes that were not eligible for this review because they did not report discrimination, calibration, or reclassification. It also included two studies related to harms of exercise ECG that were not eligible for the current review (one was an uncontrolled single center report of military officers getting stress tests;^50^ the other described survey data on harms, focusing on symptomatic participants^51^); both studies are described in the discussion of this report. Details of quality assessments of included studies and studies excluded because of poor quality are provided in Appendix D.

Figure 2 Summary of Evidence Search and Selection Diagram

Note Note:: The sum of the number of studies per KQ exceeds the total number of studies because some studies were applicable to multiple KQs.

Abbreviations: ICTRP=International Clinical Trials Regis try Platform; KQ=key question; USPSTF=U.S. Preventive Services Task Force; WHO=World Health Organization.

Figure 2 is a flow chart that summarizes the search and selection of articles. Records identified through database searching included 4036 records by searching PubMed, 287 records by searching the Cochrane Library, and 121 records by searching ClinicalTrials.gov and WHO ICTRP. Records identified through other sources include 6 from grey literature (i.e., hand-searching, reference list review), 82 from the 2011 USPSTF systematic review of CVD risk assessment tools, and 63 from the previous evidence review. In total, 4595 titles and abstracts were screened for potential inclusion. Of these, 524 were deemed appropriate for full-text review to determine eligibility. After full-text review, 507 were excluded: 1 for non-English language, 111 for ineligible population, 112 for ineligible screening/intervention, 75 for ineligible comparison, 163 for ineligible outcome, 1 for ineligible setting, 43 for ineligible study design, and 1 for poor quality. Seventeen articles representing 16 studies were included in the systematic review: 2 studies for KQ1, 14 studies for KQ2, and 1 study for KQ3.

## Results

### KQ 1a Does the Addition of Screening With Resting or Exercise ECG Improve Health Outcomes Compared With Traditional CVD Risk Factor Assessment Alone in Asymptomatic Adults? 1b. Does Improvement in Health Outcomes Vary for Subgroups Defined by Baseline CVD Risk, Age, Sex, or Race/Ethnicity?

#### Summary

No eligible studies compared screening with resting ECG and no screening, and none evaluated the use of screening with ECG for the purpose of risk reclassification to inform decisions about preventive medications. Two RCTs (DYNAMIT and DADDY-D) with a total of 1,151 participants evaluated screening with exercise ECG in high risk, asymptomatic adults ages 50 to 75 years with diabetes. Both RCTs reported no statistically significant improvement in health outcomes, but were limited by not reaching sample size targets.

#### Detailed Results: Characteristics of Included Trials

We included two fair-quality RCTs: Do You Need to Assess Myocardial Ischemia in Type-2 diabetes (DYNAMIT)^52^ and Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients (DADDY-D).^53^ The characteristics of the included studies are summarized in Table 2. Both trials compared screening with exercise ECG with no screening exercise ECG.

Table 2 Characteristics of Included Randomized, Controlled Trialsfor KQ 1 and KQ 3

First Author, Year Trial Name | G1 (N) G2 (N) | Screening Approach | Source of Patients | Country | Years of Follow-up | Mean Age (SD) | % F | % Non-white | Mean CV Risk (SD) | Mean A1c (SD) | Mean BMI (SD) | %HTN %HF %TIA %PAD %PVD %Smokers | Quality
Lievre et al, 2011^52^ DYNAMIT | Screened (316) Not screened (315) | Exercise ECG, bicycle exercise test (or dipyridamole SPECT, 31%)^a^ | 45 hospitals, ambulatory patients who consulted a diabetes specialist | France | Mean 3.5 | 63.9 (5.1) | 45 | NR | NR | 8.6 (2.1) | 30.6 (5) | 88.8 0.5 4.6 14.1 NR 16.6^b^ | Fair
Turrini et al, 2015^53^ DADDY-D | Screened (262) Not screened (258) | Exercise ECG^c^ | 2 diabetes outpatient clinics | Italy | Mean 3.6 | 61.9 (5) | 20 | NR | 20 (9)^d^ | 7.7 (2) | 30.1 (6) | NR^e^ 0 (excluded) NR NR 6 38.7 | Fair

a SPECT was used in patients unable to perform the exercise test, with a submaximal negative exercise test, or with ECG abnormalities impairing the interpretation of the exercise test. Those with positive tests were referred to cardiologists, and all subsequent investigations and treatments were left at the cardiologist’s discretion.

b Tobacco consumption

c Maximal symptom-limited exercise treadmill test (ETT) preformed following American Heart Association guidelines. Submaximal tests were considered not diagnostic and did not lead to any further investigations. Coronary angiography was proposed to all patients with positive ETT; choices to perform stenting or surgery were determined according to the European Guidelines by two interventional cardiologists and a cardiac surgeon after reviewing coronary anatomy.

d Required CV risk score ≥10% for eligibility, risk determined according to Italian risk chart (includes gender, diabetic status, age. cigarette smoking status, systolic blood pressure, serum cholesterol).

e 74.3% on antihypertensive treatment; mean SBP 140.

Abbreviations: Alc=glycosylatedhemoglobin; BMI=body mass index; CV=cardiovascular; DADDY-D=Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients; DYNAMIT =Do You Need to Assess Myocardial Ischemia in Type-2 diabetes; ECG=electrocardiogram; ETT =exercise treadmill test; F=female; HF=heart failure; HTN=hypertension; KQ=key question; G=group; N=sample size; NR=not reported; PAD=peripheral artery disease; PVD=peripheral vascular disease; SBP=systolic blood pressure; SD=standard deviation; SPECT=Single Photon Emission Computed Tomography; TIA=transient ischemic attack.

The DYNAMIT study was a multicenter randomized trial that randomized 631 ambulatory patients who consulted a diabetes specialist to screening versus no screening.^52^ Those in the screening arm were referred for detection of silent ischemia using a bicycle exercise test or Dipyridamole Single Photon Emission Computed Tomography (SPECT). SPECT was used in patients unable to perform the exercise test, with a submaximal negative exercise test, or with ECG abnormalities impairing the interpretation of the exercise test (31% ultimately had SPECT). Those with positive exercise or SPECT tests were referred to cardiologists, and all subsequent investigations and treatments were left to the judgment of the cardiologists (i.e., no protocol for that part of the process related to angiography vs. no angiography; pragmatic approach). The DADDY-D trial randomized 520 participants from a single center (2 diabetes outpatient clinics) to screening or no screening.^53^ Participants were required to have a normal ECG to get into the study. Those in the screening arm underwent maximal symptom-limited exercise treadmill test (ETT). Submaximal tests were considered not diagnostic and did not lead to any further investigations. Coronary angiography was proposed to all patients with positive ETTs, and choices to perform stenting or surgery were reportedly determined according to the European Guidelines by two interventional cardiologists and a cardiac surgeon after reviewing coronary anatomy.

DYNAMIT was conducted in France, and the DADDY-D trial was conducted in Italy. Mean duration of followup for both trials was 3.5 to 3.6 years. Both enrolled ambulatory patients with a clinical diagnosis of type 2 diabetes. Mean hemoglobin A1cs were 8.6 (DYNAMIT) and 7.7 (DADDY-D), respectively. DYNAMIT enrolled patients ages 55 to 75 years; mean age was 64. DADDY-D enrolled patients ages 50 to 70 years; mean age was 62. Less than half of the participants (20—45%) were women in both trials. Neither trial reported information about race or ethnicity of participants. DADDY-D did not report baseline prevalence of hypertension (but 74% were on antihypertensive medications) or PAD; they were 89 percent and 14 percent for DYNAMIT, respectively. The prevalence of heart failure in both trials was less than 1 percent. Less than half of the participants (17—39%) in both trials were smokers.

Both trials were rated as fair quality. Neither trial reached the sample size targets. DYNAMIT was stopped early because of trouble recruiting and a lower than expected event rate (it randomized 631 of the planned 3,000). DADDY-D aimed for 364 per group but enrolled about 260 per group; because the target number of participants could not be achieved, the followup period was extended from two years to 3.5 years for those who had been enrolled (the authors reported a power of 77%). For DADDY-D, masking of outcome assessors was not reported and amount of attrition was unclear.

#### Results of Included Trials

The main results are shown in Figure 3 and Appendix E Table 1. Overall, neither study found a statistically significant reduction in any category of events for screening compared with no screening, including their primary composite outcomes, all-cause mortality, CV-related mortality, MI, heart failure, or stroke, although findings were imprecise.

Figure 3 Main Results of Included Randomized, Controlled Trials Reporting Health Outcomes (KQ 1)

DYNAMIT, primary composite outcome was defined as death from all causes, nonfatal MI, nonfatal stroke, or heart failure requiring hospitalization or emergency service intervention.

DADDY-D, primary composite outcome was defined as first cardiac event, specifically nonfatal MI or cardiac death.

DYNAMIT did not report data for CV-related deaths. For other CV events, the DYNAMIT trial reported no significant differences between arms for revascularization (18 vs. 21, p=0.61).

The DADDY-D trial reported 19 total deaths (6 cardiac and 13 noncardiac) and seven total strokes but did not report which group those occurred in.

Abbreviations: CV=cardiovascular; DYNAMIT=Do You Need to Assess Myocardial Ischemia in Type-2 diabetes; DADDYD=Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients; MI=myocardial infarction.

Figure 3 displays a forest plot reporting the relative risks of the primary composite outcomes of each study (all-cause mortality, cardiovascular-related mortality, myocardial infarction, heart failure, and stroke) for screening compared to no screening.

In the DYNAMIT trial, 28 participants in the screening group and 26 in the unscreened arm experienced at least one primary endpoint (composite of death from all causes, nonfatal MI, nonfatal stroke, or heart failure requiring hospitalization or emergency service intervention) (hazard ratio [HR], 1.00; 95% confidence interval [CI], 0.59 to 1.71). In the same trial, 13 in the screening arm and 15 in the unscreened arm experienced coronary events (fatal or nonfatal MI, hospitalized unstable angina, or heart failure requiring hospitalization or emergency service intervention) (HR, 0.77; 95% CI, 0.37 to 1.63). In the DADDY-D tria l, 12 in the screened arm and 14 in the unscreened arm experienced a primary outcome, cardiac events defined as a composite of nonfatal MI or cardiac death (HR, 0.85; 95% CI, 0.39 to 1.84).

Subgroup analyses were performed by gender, age, and CV risk for multiple outcomes in the DADDY-D trial. No statistically significant differences were found between groups based on gender, age, or CV risk for the primary outcome of cardiac events. For heart failure, no significant differences were found between those screened and those not screened based on gender, age, or having a CV risk >20, but a difference was found for those with a CV risk <20 (0 vs. 5 events, p=0.022). For cardiac death, no significant differences were found between those screened and those not screened based on gender, CV risk, or being less than 60 years of age, but a difference was found for those >60 years of age. Fewer cardiac deaths were reported for those older than 60 years who were screened than those who were not screened (0 vs. 4 events, p=0.044). No significant differences were found between those screened and not screened based on gender, age, or CV risk for nonfatal MI. The study did not report interaction tests for the subgroup analyses, no adjustments were made for multiple testing, and it is unclear whether the subgroup analyses were planned a priori. The positive subgroup analysis findings are likely due to chance.

### KQ 2 Does the Addition of Screening With Resting or Exercise ECG to Traditional CVD Risk Factor Assessment Accurately Reclassify Persons Into Different Risk Groups or Improve Measures of Calibration and Discrimination?

#### Summary

Fourteen good- or fair-quality studies were included.^47^ Five evaluated exercise ECG^47,48,54-56^ and nine evaluated resting ECG.^49,57-64^ Of those nine, five evaluated multiple ECG changes (a group of major and minor changes)^49,57-60^ and four evaluated only single ECG changes.^61-64^ Of the studies evaluating exercise ECG, three used published coefficient base models (2 FRS and 1 SCORE).^47,48,55^ Of the studies evaluating resting ECG, five reported some analyses using published coefficient base models (5 FRS; 1 also used PCE).^49,57-59,63^

For exercise ECG, although evidence from five cohort studies (9,582 participants) shows that the addition of exercise ECG abnormalities to traditional CVD risk factors results in small improvements in discrimination (absolute improvement in AUC or C-statistics 0.02 to 0.03), it is uncertain whether calibration or appropriate risk classification improves. For resting ECG, evidence from nine cohort studies (66,407 participants) shows that the addition of ECG findings to traditional CVD risk factors results in very small or small improvements in discrimination (absolute improvement in AUC or C-statistics 0.001 to 0.05) and improvements for calibration and appropriate risk classification for prediction of multiple outcomes (e.g., all-cause mortality, CVD mortality, CHD events, or CVD events), but evidence was limited by imprecision, quality, considerable heterogeneity, and the risk categories evaluated.

#### Characteristics of Studies Evaluating Exercise ECG

Five cohort studies evaluated whether adding exercise ECG to traditional CVD risk prediction could improve discrimination, calibration, or risk reclassification (Tables 3 and 4).^47,48,54-56^ The studies evaluated a total of 9,582 participants. Sample sizes ranged from 988^54^ to 3,554.^47^ One enrolled participants in the 1970s;^56^ the other four enrolled participants in the 1990s. Two studies were conducted in the United States,^47,54^ two in France,^48,55^ and one in Norway.^56^ Mean duration of followup ranged from 6 to 8 years in four studies; one had 26 years of followup.^56^ The five studies used data from five different cohorts (although the 2 studies from France may have some overlap in a subset of the participants). For the base model, two used the FRS (with published coefficients of the original model),^48,55^ one used the European SCORE (with published coefficients),^47^ one model development study used FRS variables,^54^ and one model development study used some of the traditional risk factors (age, total cholesterol, systolic blood pressure, and smoking status) and restricted its sample to eliminate other risk factors (excluded women, those with prevalent diabetes, and those on blood pressure-lowering therapy at baseline) but did not account for HDL.^56^

Table 3 Characteristics of Included Studies for KQ 2 That Evaluated Exercise ECG, Part 1

First Author, Year Quality | ECG Findings Evaluated | Model Type: Base Model | Cohort | Source of Patients | Countr y | Sample Size | Years of Follow up
Aktas, 2004^47^ Fair | Exercise ECG according to Bruce (or modified Bruce) protocol; ischemic ST abnormality^a^ using a 12-lead, symptom-limited exercise ECG | Published coefficient: European SCORE^b^ | From Preventive Medicine Section of Cleveland Clinic (1990-2002) | Consecutive participants presenting for an executive physical. Self-referred. | US | 3,554 | Mean: 8
Chang, 2015^54^ Fair | Exercise ECG according to Bruce protocol; stress-induced ischemia^c^ identified via ECG during symptom-limited exercise treadmill testing; METS and DTS | Model development: FRS^d^ variables | From the Methodist Hospital, Flouston Texas (1995-2006) | Persons who had both CACS and stress SPECT for clinically indicated reasons at the Heart and Vascular Center | US | 988 | Median: 6.9
Cournot, 2006^48^ Fair | Symptom-limited exercise ECG^e^ | Published coefficient: FRS^f^ | From the preventive cardiology unit of a teaching hospital (1995-1999) | Consecutive asymptomatic persons self-referred or referredby PCPs and cardiologists for evaluation of risk factors and routine screening | France | 1,051 | Mean: 6
Cournot, 2009^55^ Fair | A positive exercise test^g^ during a symptom-limited exercise ECG with orthogonal and V_1_ to V_6_ leads | Published coefficient: FRS^f^ | From the preventive cardiology unit of a teaching hospital (1996-2004) | Apparently healthy asymptomatic persons self-referred (20%) or referred by PCPs (27%) or other providers to a preventive cardiology unit | France | 2,709 | Median: 6
Erikssen, 2004^56^ Fair | Resting ECG and a symptom-limited bicycle exercise ECG test^h^ | Model development: Classical Risk Factor (CRF) regression model^i^ | From the University Hospital of Oslo (1972-1975) | Apparently healthy males ages 40-60 years recruited from five governmental agencies who participated in a cardiovascular risk assessment | Norway | Assessment 1 (1972-1975): 2,014 Assessment 2 (1980-1982): 1,428 | 26

a An ischemic ST abnormality, which was assessed visually by two independent readers, was defined as a 1-mm horizontal or downsloping ST-segment depression occurring 80 ms after the J-point; ST-segment depression had to be noted in at least three consecutive beats in at least two contiguous leads.

b SCORE includes age, sex, total cholesterol, systolic bloodpressure, and smoking status (this study used the high-risk coefficients from it).

c Ischemia was defined as ≥1 mm of ST-segment depression occurring >80 ms after the J-point. High and low risk were defined as the presence and absence of ischemia, respectively.

d Authors attempted to calculate FRS as published, but continuous BP and cholesterol measurements were not available, so these predictors were dichotomized (hyperlipidemia defined as total cholesterol 200-239 mg/dLand HTN defined as SBP 140-159 mmHg).

e Positive ET was defined as a horizontal or downsloping ST-segment depression ≥1.0 mm at 80 ms after the J-point, in at least two contiguous leads, occurring at any time of exercise or recovery period.

f Used Anderson 1991: 10-year FRS function that includes age, sex, current smoking, diabetes, total cholesterol, and HDL-C.

g Positive exercise testing was defined as a horizontal or downsloping ST-segment depression ≥1.0 mm at 80 ms after the J-point, in at least two contiguous leads, occurring at any time during exercise or the recovery period.

h Exercise predictors were physical fitness (cumulative work during exercise divided by body weight), maximal heart rate, systolic blood pressure at the end of the first exercise load, and exercise ECG interpretation (ST-segment depression ≥1.0 mm at 0.08 after the J-point regardless of ST-segment morphology).

i CRF model included age, total cholesterol, systolic blood pressure, and smoking status. The study included men only; therefore, sex was not needed in the model; the study also excluded persons with prevalent diabetes and persons on blood pressure—lowering therapy at baseline. High-density lipoprotein cholesterol was not accountedfor in the model.

Abbreviations: BP=bloodpressure; CACS=coronary artery calcium score; CRF=Classical Risk Factor; DTS=Duke treadmill score; ECG=electrocardiogram; ET=exercise test; FRS=Framingham Risk Score; HDL-C=high-density lipoprotein cholesterol; HTN=hypertension; METS=metabolic equivalents of task; KQ=key question; PCP=primary care physicians and cardiologists; SCORE=Systematic COronary Risk Evaluation; SPECT=single-photon emission computed tomography; U.S.=United States.

Table 4 Characteristics of Included Studies for KQ 2 That Evaluated Exercise ECG, Part 2

First Author, Year | % CVD | % With Symptoms | Mean Age (SD) | % F | % Non-white | CV Risk | Mean BMI (SD) | % HTN | % DM | % Smokers
Aktas, 2004^47^ | 0 | 0 | 57 (4) | 19 | 2 | SCORE,^a^ median (25^th^-75^th^ percentile) 1^st^ tertile: 0.14 (0.87-1.8) 2^nd^ tertile: 3.0 (2.5-3.5) 3^rd^ tertile: 6.6 (5.2-9.2) | 28 (4) | NR (mean SBP 128) | 3 | 10
Chang, 2015^54^ | 0 (for CAD; NR for CVD) | 16.5^b^ | 57.5 (9.3) | 25 | NR | FRS, mean (SD): 11.1 (6.5) Low risk (<6%): 16.9% Intermediate risk (6%-20%): 69.2% High risk (>20%): 13.9% | NR | 49.6 | 9.6 | 46.5
Cournot, 2006^48^ | 0 | 0 | Total: 51.6 (10.3) | 36 | NR | Mean (median) FRS All: 12.3 (10.4) Negative ET, n=962: 12.1 (10.4) Positive ET, n=89: 14.7 (11.4) | Total: 26.1 (4.5) | ≥160/95 mm Hg: 33.0 ≥140/90 mm Hg: 54.8 | 11.0 | 24.3
Cournot, 2009^55^ | 0 | 0 | Median: 51.6 (10.5) | 38 | NR | FRS, mean (SD): 10.8 (7.8) | 26.0 (4.4) | 48.2 | 6.8 | 23.9
Erikssen, 2004^56^ | 0 | 0 | Assessment 1: 49.8 (5.5) Assessment 2: 56.6 (5.4) | 0 | NR | NR | NR | 0 (treated HTN) | 0 | Assessment 1: 43.8 (NR) Assessment2: 32.8 (NR)

a SCORE provides 10-year risk for cardiovascular mortality and includes age, sex, total cholesterol, systolic blood pressure, and smoking status (this study used the high-risk coefficients from it).

b Study reported 16.5% had at ypical chest pain symptoms but does not report indications for other tests beyond stating that they were “clinically indicated reasons.”

Abbreviations: BMI=body mass index; CAD=coronary artery disease; CV=cardiovascular; CVD=cardiovascular disease; DM=diabetes mellitus; ECG=electrocardiogram; ET=exercise testing; F=female; FRS=Framingham Risk Score; HTN=hypertension; KQ=key question; n=sample size; NR=not reported; SBP=systolic blood pressure; SCORE=Systematic COronary Risk Evaluation; SD=standard deviation.

All were prospective cohorts with participants from cardiology or prevention centers in urban hospitals. Participants were self-referred or referred by providers to a preventive cardiology unit in two studies,^48,55^ participants presented for executive physicals in one study,^47^ participants were a subset of those from a study evaluating coronary artery calcium and SPECT in one study,^54^ and participants were recruited from five governmental agencies in one study.^56^ Four of the studies reported that all participants were asymptomatic. One study reported that 16.5 percent of participants had atypical chest pain symptoms and that the participants were a subset of persons having both coronary artery calcium score (CACS) and SPECT for “clinically indicated reasons”;^54^ it is unclear what proportion of participants were truly asymptomatic and what the clinically indicated reasons for testing were. The mean age of participants ranged from 50 to 58 years. Most participants in all trials were men, with the proportion of female participants ranging from 0 to 38 percent. Four studies did not report information about race/ethnicity; one reported that 2 percent of participants were nonwhite.^47^ The baseline prevalence of hypertension and diabetes ranged from 0 to 55 percent and 0 to 11 percent, respectively. The percentage of smokers ranged from 10 to 47 percent. Mean baseline FRS score was 10.8 to 12.3 in studies reporting it.^48,54,55^

Study end points included all-cause mortality,^47^ coronary events (cardiac deaths, sudden deaths, acute MI, and stable or unstable angina),^48,55^ cardiac events (cardiac death, nonfatal MI, and the need for coronary revascularization following the development of symptomatic CAD),^54^ and CHD mortality (deaths caused by ischemic heart disease and sudden, unexpected deaths).^56^

All five of the included studies received fair-quality ratings (Appendix D). The most common methodological concerns were not reporting CIs for calibration or discrimination (5/5), not reporting measures of reclassification (4/5), selective inclusion of participants in the model based on data availability (4/5), unknown masking of outcome assessors (4/5), unknown if predictors were assessed masked for the outcome (4/5), not reporting both discrimination and calibration (3/5), unclear handling and amount of missing data (2/5), uncertain validity and reliability of method used for measuring outcomes (2/5), using base model equations that have not been externally validated (i.e., model development studies) (2/5), and mean duration of followup less than 10 years (4/5), despite the risk prediction being focused on 10 years. The study with the longest followup (26 years) did not account for one of the traditional risk factors (HDL).^56^ In addition, the only study reporting reclassification did not use the risk categories commonly used in current practice for making treatment decisions (it used <6% vs. 6 to 20% vs. >20%) and may have included many symptomatic participants (16.5% had atypical chest pain and participants were a subset of those having CACS and SPECT for “clinically indicated reasons”).^54^

#### Results of Studies Evaluating Exercise ECG

For the comparison of interest to this review, one model development study reported reclassification,^54^ four reported calibration,^48,54-56^ and three reported discrimination.^47,54,55^ Results of the included studies are shown in Table 5 and Figures 4—7. The frequency of abnormal exercise tests across included studies ranged from 6.4 to 16.7 percent (Appendix E Table 3).

Table 5 Results of Included Studies for KQ 2 That Evaluated Exercise ECG

First Author, Year Quality | Outcome | N (%) With Outcome | Discrimination | Calibration | Reclassification
Aktas, 2004^47^ Fair | All-cause mortality | 114 (3) | C-statistic (95% Cl): SCORE: 0.73 (NR) SCORE + exercise test: 0.76 (NR), p NR | NR | NR
Chang, 2015^54^ Fair | Cardiac events^a^ | 106 (11)^b^ | AUC FRS variables: 0.63 (NR) FRS variables +ETT: NR FRS variables + DTS: NR FRS variables + METS: NR FRS variables + ETT + MET^c^+ DTS^d^: 0.65 (NR) p=0.3 (FRS variables + ETT + MET + DTS vs. FRS variables) | Global χ^2^ FRS variables: 11.72 FRS variables + ETT^e^: 16.16 p=0.04 (FRS + ETT vs. FRS) FRS variables + DTS: 14.59 p=0.24 (FRS + DTS vs. FRS) FRS variables + METS: 14.68 p=0.03 (FRS + METS vs. FRS) | NRI % for FRS variables + ETT (p Value vs FRS variables) All patients: 9.6 (0.007); Appropriate Use Cohort^f^: 11.1 (0.005) Low risk: 0 (1.0); Intermediate risk: 18.9 (0.01); High risk: 8.1 (0.38) Absolute IDI % for FRS variables + ETT (p Value vs FRS variables) All patients: 1.4 (0.006); Appropriate Use Cohort: 1.6 (0.006) Low risk: 0.1 (0.75); Intermediate risk: 1.7 (0.01); High risk: 0.88 (0.39) Relative IDI % for FRS variables + ETT (p Value vs FRS variables) All patients: 110 (<0.0001); Appropriate Use Cohort: 128 (<0.0001) Low risk: 591 (0.35); Intermediate risk: 92 (0.004); High risk: 522 (0.19)
Cournot, 2006^48^ Fair | Total coronary events^g^ (CE) | 34 (3)^h^ | NR | FRS Model vs. FRS Model + exercise test (ET) results Likelihood ratio test: Whole sample (n=1051) p=0.13^i^ Subgroup with pre-test Framingham risk ≥10.4% (n=526): p=0.06^j^ | NR
Cournot, 2009^55^ Fair | Definite coronary events^k^ | 94 (4)^l^ | FRS vs. FRS + femoral bruit + positive exercise test^m^ AUROC (95% Cl): 0.732 (NR) vs. 0.762 (NR), p NR Sensitivity, %:3.2 vs. 8.5 Specificity, %:99.4 vs. 98.6 Positive predictive value, %: 15.8 vs. 19.1 Negative predictive value, %: 96.4 vs. 96.6 | FRS vs. FRS + femoral bruit + positive exercise test^m^ Hosmer-Lemeshow chi-square: P=9.99 vs. P=0.99 Akaike information criterion: 748.9 vs. 727.8 Brier’s score: 0.035 vs. 0.033 | NR
Erikssen, 2004^56^ Fair | CHD Mortality1^n^ | 300 (15) | NR | CRF vs. CRF+X models^o^, Predicted (observed) events: CRF, Assessment 1, 26-year follow-up <8.9%: 30.1 (37) 8.9-11.3%: 41.3 (44) 1.4-15.2%: 54.2 (52) 15.3-20.0%: 70.4 (65) >20.0%: 104.1 (102) Total: 300.1 (300) CRF+X, Assessment 1, 26-year follow-up <7.2%: 24.8 (27) 7.2-10.2%: 37.2 (37) 10.3-14.1%: 49.2 (47) 14.2-20.8%: 67.8 (69) >20.8%: 121.2 (120) Total: 300.2 (300) CRF, Assessment 2, 19-year follow-up <8.9%: 14.7 (16) 8.9-11.3%: 19.9 (19) 1.4-15.2%: 24.9 (21) 15.3-20.0%: 32.4 (38) >20.0%: 51.0 (49) Total: 142.9 (143) CRF+X, Assessment 2, 19-year follow-up <7.2%: 10.7 (10) 7.2-10.2%: 15.9 (18) 10.3-14.1%: 21.8 (27) 14.2-20.8%: 30.6 (23) >20.8%: 64.0 (65) Total: 142.9 (143) CRF, Assessment 1 with Insertion of Assessment 2 data for those who remained healthy (at 2), 19-year follow-up <8.9%: 15.8 (18) 8.9-11.3%: 21.4 (20) 1.4-15.2%: 27.1 (25) 15.3-20.0%: 36.0 (32) >20.0%: 58.6 (48) Total: 158.9 (143) | NR
Erikssen, 2004^56^ Fair (cont’d) | | | | CRF+X, Assessment 1 with Insertion of Assessment 2 data for those who remainedhealthy (at 2), 19-year follow-up <7.2%: 8.0 (12) 7.2-10.2%: 14.9 (15) 10.3-14.1%: 23.3 (30) 14.2-20.8%: 35.6 (31) >20.8%: 76.5 (55) Total: 158.3 (143)

a Cardiac events were defined as a composite of cardiac death, nonfatal MI, and the need for coronary revascularization following the development of symptomatic CAD.

b The 106 events included 17 cardiac death, 16 nonfatal MIs, and 73 coronary revascularizations.

c Metabolic equivalents of task (peak exercise capacity was determined from the ETT to determine METs, and it was categorized as >8. 5 to 8. or <5).

d Duke treadmill score (it was categorized as low, 5 or more, intermediate, 4 to -10, or high, -11 or less)

e ETT is based on criteria for determining ischemia (separate from DTS or METs from the exercise test)

f Appropriate use cohort was 824 patients (87% of the total cohort) considered acceptable candidates for functional testing on the basis of recent appropriate use criteria (i.e., intermediate to high FRS risk and/or chest pain symptoms).

g Total coronary events included cardiac deaths, sudden deaths, acute MI, and stable or unstable angina.

h Including 6 cardiac deaths, 13 stable or unstable angina events, and 15 nonfatal MI. Number of sudden deaths NR.

i When adjusting for age, sex, current tobacco consumption, systolic blood pressure, total cholesterol, HDL cholesterol and diabetes (instead of 10-year Framingham risk of CHD), reported p was 0.10.

j When adjusting for age, sex, current tobacco consumption, systolic blood pressure, total cholesterol, HDL cholesterol and diabetes (instead of 10-year Framingham risk of CHD), reported p was 0.03.

k Definite coronary events included cardiac deaths, sudden deaths, acute MI, and stable or unstable angina. Revascularization (coronary artery bypass surgery or percutaneous coronary intervention) without clinical symptom was not considered as a coronary event.

1 Study reported 8 with sudden death or fatal MI, 24 with nonfatal MI, 15 with acute coronary syndromes, and 47 with stable angina.

m All of the models considering the exercise test variable also included femoral bruit because it had been significant in adjusted HRs. The article provides data for FRS + femoral bruit also, showing that there was little to no change with its addition, e.g., AUROC 0.732 (same as for the model with FRS only).

n Deaths caused by ischemic heart disease and sudden, unexpected deaths were classified as coronary deaths. Cardiovascular deaths also include deaths caused by stroke and ruptured aortic aneurysms.

o Exercise predictors: Physical fitness (cumulative work during exercise divided by body weight), maximal heart rate, systolic blood pressure at end of the first exercise load (100 W). and exercise ECG interpretation (ST-depression of at least 1.0 mm 0.08 s after the J-point regardless of ST-segment morphology)

Abbreviations: AUC=area under the curve; AUROC=area under the receiver operating characteristic curve; CHD=coronary heart disease; CRF=classical risk factors; DTS=Duke treadmill score; ECG=electrocardiogram; ETT=exercise treadmill testing; MET=metabolic equivalents of task; FRS=Framingham Risk Score; IDI=integrated discriminationimprovement; KQ=key question; N=sample; NR=not reported; NRI=net reclassification improvement; SCORE=Systematic COronary Risk Evaluation.

Figure 4 Effect on Discrimination of Adding Exercise or Resting ECG Variables to Framingham Risk Score or Pooled Cohort Equation Base Models

^a^ Study reportedc-statistic rather than AUC.

Abbreviations: AUC=area under the curve; CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; FRS=Framingham Risk Score; LVH=left ventricular hypertrophy; NR=not reported; PCE=pooledcohort equations.

Figure 4 displays the studies reporting discrimination using the Framingham Risk Score or Pooled Cohort Equations with published coefficients for the base model stratified by exercise or resting ECG (multiple changes) and resting ECG (single change). The figure illustrates the AUC or C-statistic for the base model (shown as black squares) and the AUC or C-statistic for the base model plus exercise ECG changes (shown as white squares). In addition to the AUC or C-statistic results, the columns of the figures show the outcome, ECG findings evaluated, base model used, sample size, and number of participants with an event. An absolute change of 0.03 was reported between the base model and the base model plus ECG for exercise ECG. Absolute changes ranging between 0.00 to 0.05 were reported between the base model and the base model plus ECG for resting ECG (multiple changes). An absolute change of 0.01 was reported between the base model and the base model plus ECG for resting ECG (single change).

Figure 5 Effect on Discrimination of Adding Exercise or Resting ECG Variables to Framingham Risk Score, Pooled Cohort Equation, Systemic Coronary Risk Evaluation, or Conventional Risk Factor Base Models

^a^Model also included metabolic equivalent (MET) and Duke treadmill score (DTS).

^b^ Study reportedc-statistic rather than AUC.

^c^ In women without diabetes mellitus.

^d^ In men without diabetes mellitus.

Abbreviations: AUC=area under the curve; CHD=coronary heart disease; CI=confidence interval; CRF=conventionalrisk factors; CVD=cardiovascular disease; ECG=electrocardiography; FRS=Framingham Risk Score; IHD=ischemic heai’t disease; LVH=left ventricular hypertrophy; NR=not reported; PCE=pooledcohort equations; SCORE=Systemic Coronai’y Risk Evaluation.

Figure 5 displays the studies reporting discrimination using the Framingham Risk Score or Pooled Cohort Equations with published coefficients for the base model and the model development studies stratified by exercise or resting ECG (multiple changes) and resting ECG (single change). The figure illustrates the AUC or C-statistic for the base model (shown as black squares) and the AUC or C-statistic for the base model plus ECG changes (shown as white squares). In addition to the AUC or C-statistic results, the columns of the figures show the outcome, ECG findings evaluated, base model used, sample size, and number of participants with an event. An absolute change between 0.02 to 0.03 was reported between the base model and the base model plus ECG for exercise ECG. Absolute changes between 0.01 to 0.05 were reported between the base model and the base model plus ECG for resting ECG (multiple changes). An absolute change between 0.0 to 0.01 was reported between the base model and the base model plus ECG for resting ECG (single change).

Figure 6 Effect on Reclassification of Adding Exercise or Resting ECG Variables to Framingham Risk Score, Pooled Cohort Equation, or Conventional Risk Factor Base Models

^a^ Model also included metabolic equivalent (MET) and Duke treadmill score (DTS).

Abbreviations: CHD=coronary heart disease; CI=confidence interval; CRF-conventional risk factors; CVD=cardiovascular disease; ECG=electrocardiography; FRS=Framingham Risk Score; LVH=left ventriculai’ hypertrophy; NR=not reported; NRl=net reclassification index; PCE=pooledcohort equations.

Figure 6 displays the results of studies evaluating multiple ECG changes on reclassification when adding resting ECG to traditional risk factors stratified by exercise ECG, resting ECG (multiple changes), and resting ECG (single change). It illustrates the NRI results, with black squares indicating the total NRI (sum of the event NRI and nonevent NRI), gray squares indicating the event NRI (net upward reclassification among persons who had an event), and white squares representing nonevent NRI (net downward reclassification among persons who did not have an event). When the data for event and nonevent NRI were not reported, only the total NRI (black square) is displayed. The figure specifically shows model development studies and studies that used the Framingham Risk Score or Pooled Cohort Equations with published coefficients for the base model. In addition to the NRI results, the columns of the figures show the outcome, ECG findings evaluated, base model used, sample size, number of participants with an event, and the risk categories used for analyses. The total NRI for exercise ECG was 0.096. The total NRIs for resting ECG (multiple changes) ranged from 0.019 to 0.30. The total NRIs for resting ECG (single change) ranged from -0.002 to 0.54.

Figure 7 Effect on Reclassification of Adding Resting ECG Variables to Framingham Risk Score or Pooled Cohort Equation Base Models

Abbreviations: CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiography; FRS=Framingham Risk Score; NR=not reported; NRI=net reclassification index; PCE=pooled cohort equations.

Figure 7 displays the results of studies evaluating multiple ECG changes on reclassification when adding resting ECG to traditional risk factors stratified by resting ECG (multiple changes) and resting ECG (single change). It illustrates the NRI results, with black squares indicating the total NRI (sum of the event NRI and nonevent NRI), gray squares indicating the event NRI (net upward reclassification among persons who had an event), and white squares representing nonevent NRI (net downward reclassification among persons who did not have an event). When the data for event and nonevent NRI were not reported, only the total NRI (black square) is displayed. The figure specifically shows the studies that used the Framingham Risk Score or Pooled Cohort Equations with published coefficients for the base model. In addition to the NRI results, the columns of the figures show the outcome, ECG findings evaluated, base model used, sample size, number of participants with an event, and the risk categories used for analyses. The total NRIs for resting ECG (multiple changes) ranged from 0.036 to 0.30. The total NRI for resting ECG (single change) was 0.07.

##### Discrimination

Three studies reported discrimination for the addition of exercise ECG variables to traditional risk factors;^47,54,55^ one of the three used FRS with published coefficients for the base model^55^ and two were model development studies. Main results are shown in Figures 4 and 5, illustrating the AUC or C-statistic for the base model (black squares in the figures) and the AUC or C-statistic for the base model plus exercise ECG (white squares in the figures). Figure 4 is limited to the studies that used FRS or PCE with published coefficients for the base model whereas Figure 5 also shows model development studies. In addition to the AUC or C-statistic results, the columns of the figures show the outcome, ECG findings evaluated, base model used, sample size, and number of participants with an event. All three studies reported small absolute improvements in AUC or C-statistics (0.02 to 0.03), and none of them reported CIs for the discrimination data. One of the three reported a p-value indicating no statistically significant difference between a model with exercise testing variables and the base model with FRS variables (p=0.3).^54^

##### Calibration or Overall Performance

Four studies reported calibration or overall performance of models that added exercise ECG results to traditional risk factors (Table 5).^48,54-56^ Two of the studies used the FRS (with published coefficients) in base models^48,55^ and two were model development studies.^54,56^ None of the studies reported figures such as calibration plots, but one provided a table of predicted and observed events for quintiles of risk.^56^ All four studies reported different measures: likelihood ratio test;^48^ Akaike information criteria (AIC), Brier’s score, and Hosmer-Lemeshow χ2;^55^ global χ2;^54^ and numbers of predicted and observed events.^56^

The two studies that used the FRS were both conducted in France and focused on prediction of coronary events.^48,55^ One study (1,051 participants) reported that model performance was not improved for the full sample with the addition of symptom-limited exercise ECG to the model (p=0.13).^48^ For the subgroup with pretest Framingham risk of 10.4 percent or greater, the authors reported a statistically significant improvement for adding exercise ECG to some base models, but not when the base model was FRS (n=526, p=0.06). The other study (2,709 participants) reported improved goodness of fit with the addition of exercise ECG, indicated by lower AIC (748.9 vs. 727.8) and Brier’s score (0.035 vs. 0.033); the Hosmer-Lemeshow test showed no difference between the models (p, 0.99 vs. 0.99).^55^

Two studies developed new models rather than using published coefficients of existing models (e.g., FRS and PCE). The study described below under Risk Reclassification (Chang et al, 2015^54^) reported better calibration for the model that included exercise testing results than for the base model (global chi-square 16.16 vs. 11.72, p=0.04).^54^ The study conducted in Norway (2,014 participants) reported numbers of predicted and observed events for models with and without exercise testing (Table 5).^56^ Although both models (with and without exercise testing) show steep and similar gradients in age-adjusted CHD mortality (indicating good calibration), the model with exercise testing showed a slightly steeper gradient across quintiles of risk, with slightly better correspondence of predicted and observed events.

##### Risk Reclassification

One study (Chang et al, 2015^54^; 988 participants) reported on the reclassification from adding exercise ECG to traditional CVD risk factor assessment for predicting cardiac events.^54^ It did not use the current common clinical thresholds to reclassify risk; instead, it used categories defined by 10-year risk of <6 percent, 6 to 20 percent, and >20 percent. For the base model, the authors were not able to calculate the FRS as published because blood pressure and cholesterol measurements were not available (so these predictors were dichotomized based on history of hyperlipidemia and hypertension). Therefore, it was considered a model development study with FRS variables in the base model (i.e., rather than a study using the externally validated FRS coefficients in the base model). The study found that adding the presence or absence of stress-induced ischemia detected during symptom-limited exercise treadmill testing to the base model increased the total NRI in subjects overall (9.6%; p=0.007) and in the intermediate risk group (18.9%; p=0.01). It did not report event NRI and nonevent NRI. The study also reported absolute and relative integrated discrimination improvement (IDI). For all patients, the IDI was small but statistically significant (absolute IDI, 1.4%, p=0.006; relative IDI, 110%, p<0.0001). The IDI was also improved significantly for the intermediate risk category (absolute IDI%, 1.7 [p=0.01]; relative IDI, 92% [p=0.004]). The study authors also reported on calibration, finding better calibration for the model that included exercise testing results than for the base model (global chi-square 16.16 vs. 11.72, p=0.04). However, adding exercise testing variables to the base model did not significantly improve discrimination (change in AUC, 0.02, p=0.3).

#### Characteristics of Studies Evaluating Resting ECG

Nine studies of resting ECG met inclusion criteria (Tables 6 and 7).^49,57-64^ Eight were cohort studies and one used data from an RCT.^49^ Five evaluated multiple ECG changes: either a constellation of major and minor ECG changes based on the Minnesota code or an ECG risk equation (that included multiple ECG changes).^49,57-60^ Four only evaluated single ECG changes.^61-64^ Some studies that evaluated multiple ECG changes also reported findings for single/specific ECG changes. Three studies reported results from the National Health and Nutrition Examination Survey (NHANES),^57,59,63^ two studies reported results from the Atherosclerosis Risk in Community study,^62,64^ and the remaining studies reported results from the Health, Aging, Body Composition Study,^58^ the Women’s Health Initiative,^49^ the Jichi Medical School Cohort,^61^ and the Copenhagen City Heart Study.^60^ Excluding double-counted populations, the studies evaluated a total of 68,475 subjects. Sample sizes ranged from 1,264^49^ to 15,375.^62^ One study enrolled participants in the 1970s;^60^ seven enrolled participants in the late 1980s and/or the 1990s, and one used a derivation cohort from the 1970s and a validation cohort from the 1980s and 1990s.^59^ Seven studies were conducted in the United States, one in Japan,^61^ and one in Denmark.^60^ Duration of followup ranged from 649 to 19 years.^59^

Table 6 Characteristics of Included Studies for KQ 2 That Evaluated Resting ECG, Part 1

First Author, Year Quality | ECG Findings Evaluated | Model Type: Base model | Cohort | Source of Patients | Country
Auer et al, 2012^58^ Good | Major^a^ and minor^b^ 12-lead ECG abnormalities classified using the Minnesota Coding System | Both types evaluated Model development: (1) FRS variables^c^ and diabetes (2) FRS variables only Published coefficient: FRS | Health, Aging, and Body Composition Study (Health ABC) Study) | Population-based cohort assessing body composition, long-term conditions, and incident mobility limitation in an older adult cohort (1997-98) | U.S.
Badheka et al, 2013^57^ Fair | Major and Minor 12-lead ECG abnormalities classified using the Minnesota Coding System^d^ | Published coefficient: FRS | NHANES-III | Population-based survey to collect information on the health and nutrition of U.S. households (1988-1994). | U.S.
Badheka et al, 2013^63^ Fair | 12-lead ECG ST-T wave abnormalities in lead aVR classified by the Minnesota Code | Published coefficient: FRS | NHANES-III | Population-based survey to collect information on the health and nutrition of U.S. households (1988-1994). | U.S.
Denes 2007^49^ Fair | Major,^e^ minor,^f^ and incident^g^ 12-lead ECG changes using the Novacode criteria | Published coefficient: FRS | WHI Study (estrogen + progestin trial) | Population-based study on common causes of morbidity/mortality among postmenopausal women (1993-1998). | U.S.
Folsom 2003^64^ Fair | LVH using a 12-lead ECG and the Cornell score | Model development: FRS variables^h^ | ARIC | Population-based study of 4 U.S. communities (1987-1989) | U.S.
Ishikawa 2015^61^ Fair | Prolonged corrected QT (QTc) intervals^i^ and LVH^j^ on 12-lead ECG | Model development: FRS variables plus alcohol intake and heart rate^k^ | The Jichi Medical School Cohort | Government-sponsored screening to clarify the risk factors for cardio/cerebrovascular diseases in the general population (1992-1995) | Japan
Jorgensen 2014^60^ Fair | Major and Minor 12-lead ECG abnormalities classified using Minnesota Code; also reported outcomes for some single ECG changes^m^ | Model development: FRS variables^l^ | The Copenhagen City Heart Study | The Copenhagen City Heart Study (1976-1978) | Denmark
Shah, 2016^59^ Fair | ECG Risk Score including frontal T axis, corrected QT interval, T axis, heart rate, age, sex, age*sex interaction term(selected from major^o^ and minor^p^ abnormalities) | Both types evaluated Published coefficient: FRS^n^ and PCE Model development: FRS variables | NHANES I (development cohort) and NHANES III (validation cohort) | Population-based survey to collect information on the health and nutrition; NHANES I (1971-1975) and NHANES III (1988-1994) | U.S.
Tereshchenko, 2014^62^ Fair | Resting 12-lead, P wave morphology (specifically DTNPV1^r^) | Model development: FRS variables^q^ | ARIC | Population-based study of 4 U.S. communities (1987-1989) | U.S.

a Criteria for major prevalent ECG abnormalities were any of the following: Q-QS wave abnormalities (MC 1-1 to 1-2-8); left ventricular hypertrophy (MC 3-1); Wolff-Parkinson-White syndrome (MC 6-4-1 or 6-4-2); complete bundle branch block or intraventricular block (MC 7-1-1, 7-2-1, 7-4, or 7-8); atrial fibrillation or atrial flutter (MC 8-3); or major ST-T changes (MC 4-1.4-2, 5-1, and 5-2).

b Criteria for minor prevalent ECG abnormalities were minor ST-T changes (MC 4-3, 4-4, 5-3, and 5-4). Participants with both major and minor abnormalities were classified as having major abnormalities. Participants without minor or major ECG abnormalities were classified as having marginal or no abnormalities and their ECG was considered normal.

c FRS variables were age, sex, total and HDL-C systolic blood pressure, and smoking.

d Individuals with any of the following at baseline were considered to have ECG abnormalities: possible or probably MI, cardiac infarction/injury score of >=10, possible or probably left ventricular hypertrophy, any axis deviation, and any rhythm abnormalities other than sinus.

e Criteria for major prevalent ECG abnormalities were any of the following: (1) atrial fibrillation or atrial flutter; (2) high-degree atrioventricular dissociation; (3) left bundle-branch block; (4) right bundle-branch block; (5) indeterminate conduction delay; (6) Qwave MI; (7) isolated ischemic abnormalities; (8) left ventricular hypertrophy with ST-T abnormalities; and (9) miscellaneous arrhythmias (e.g., supraventricular tachycardia, ventricular preexcitation, ventricular tachycardia) with less than 5 participants being included in the analysis and not listed individually. Women with both major and minor abnormalities were classified as having major abnormalities.

f Criteria for minor prevalent ECG abnormalities were any of the following: (1) first- and second-degree atrioventricular block; (2) borderline prolonged ventricular excitation; (3) prolonged ventricular repolarization; (4) isolated minor Q and ST-T abnormalities; (5) left ventricular hypertrophy without ST-T abnormalities; (6) left atrial enlargement; (7)frequent atrial or ventricular premature beats; and (8) fascicular blocks.

g Criteria for incident ECG abnormalities were any of the following: (1) new atrial fibrillation or flutter; (2) new prolonged ventricular excitation; (3) newprolonged ventricular repolarization; (4) new left ventricular hypertrophy; (5) newQ-wave MI; and (6) new ischemic ST-T evolution.

h model included age, race, total & HDL cholesterol, systolic blood pressure, use of antihypertensive medication, and smoking status

i QTc determinedby Bazett QTc intervals of ≥440 ms in men and ≥460 ms in women on a 12-lead ECG

J LVH diagnosed with Cornell product of >=244 mVxms

k model included age, sex, body mass index, current smoking, alcohol intake >20 g/d, systolic blood pressure, antihypertensive medication use, diabetes mellitus, hyperlipidemia, and heart rate.

l Model included age, systolic blood pressure, total cholesterol, sex, current smoking, and diabetes

m Reported outcomes for major or minor ECG changes, T wave changes, ventricular conduction delay, LVH, Q waves, ST depressions, resting heart rate

n FRS model includes age, sex, systolic and diastolic blood pressure, diabetes, tobacco use, total and HDL-C levels, and use of antihypertensives

o Major ECG abnormalities were defined based on Minnesota codes as follows: Major Q/QS waves (1.1, 1.2), ST depression (4.1, 4.2), negative T waves (5.1, 5.2), ventricular conduction defect (7.1, 7.2, or 7.4), atrial fibrillation/flutter (8.3), or ST elevation (9.2).

p Minor ECG abnormalities were defined as having Minnesota codes for Minor Q waves (1.2.8 or 1.3), high R waves (3.1 or 3.3), minor ST changes (4.3 or 4.4), minor T wave changes (5.3 or 5.4), prolonged PR interval (6.3), RR’ in V1 or V2 (7.3 or 7.5), or left anterior fascicular block (7.7).

q FRS components: age, gender, systolic blood pressure, diabetes, HDL and total cholesterol, smoking, and blood pressure-lowering therapy)

r Deep terminal negativity of P wave in V1

Abbreviations: ARIC=Atherosclerosis Risk in Communities; ECG=electrocardiogram; FRS=Framingham Risk Score; HDL-C=high-density lipoprotein cholesterol; LVH=Left ventricular hypertrophy; NHANES-I=National Health and Nutrition Examination Survey-i; NHANES-III=National Health and Nutrition Examination Survey-III; PCE=pooled cohort equations; U.S.=United States; WHI=Women’s Health Initiative.

Table 7 Characteristics of Included Studies for KQ 2 That Evaluated Resting ECG, Part 2

First Author, Year Quality | Sample Size | Years of Follow-up | % CVD | % With Symptoms | Mean Age (SD) | % F | % Non-white | CV Risk | Mean BMI (SD) | % HTN | % DM | % Smokers
Auer et al, 2012 ^58^ Good | 2192 | Median: 8.2 | 0 | NR | 73.5 (2.8) | 55 | 41 | FRS mean (SD): 12.6 (7.3^a^) Mean intermediate risk | 27.4 (4.9) | 57.3 | 13.3 | Current: 10.1 Former: 43.6
Badheka et al, 2013^57^ Fair | 6025 | Mean 13 | 0 | NR^b^ | 58.7 (13) | 54 | 12 | <5: 3391 (59%) 5-10: 987 (17%) 10-20: 854 (15%) >20: 497 (9%) Most low risk | 27.2 (5) | 40 | 0 | 24
Badheka et al, 2013^63^ Fair | 7928 | Mean 13.5 | CAD: 9.8 MI: 5.4 HF: 2.8 Stroke: 2.9 Total: 15.4 | NR | 59.9 (13.4) | 55 | 9.2 | <5: 2625 (35%) 5-10: 1221 (16%) 10-20: 1487 (20%) >20: 2176 (29%) Most low risk | 27.6 (5.5) | 43.8 | 10.9 | 23.1
Denes 2007^49^ Fair | 1,264^c^ | Mean 5.6 | 0 | NR | 63 | 100 | 16 | NR | 28-29^d^ (5.6-6.2) | 55-75 | 4 | Past: 40 Current: 10
Folsom 2003^64^ Fair | 14,054 | Median: 10.2 | 0 with history of CHD | NR | Median: 55 (range 45-64) | 57 | NR^e^ | NR | NR | NR | 10.7 | NR
Ishikaw a 2015^61^ Fair | 10,643 | Mean 10.7 | Unclear, but likely small %^f^ | NR | 55.4 (11.2) | 62 | NR | <2.5: 4648 (55%) 2.5-5: 1819 (22%) >5: 1986 (23%) Most low stroke risk | 23.1 (3.1) | 33.9 | 3.6 | 22.6
Jorgensen 2014^60^ Fair | 6991^g^,^i^ | Median 11.9^h^ | 0 | NR | 70 (4) | 59 | NR | FRS^i^ 25.9-33.4 Mean high risk | 26 (4.3) | NR | 5 | 47
Shah, 2016^59^ Fair | 9969 (derivation: 3640, validation: 6329) | Median: 18.8 (derivation), 10 (validation) | 0 | NR | Total: 55.3 (10.1) | 53 | Derivation: 11 Validation: 26.6 | NHANES ECG risk equation scores: 9.02 (0.79); 8.96 (0.86) Possibly low risk | NR | Anti-hypertensive use: 7.5; 20.4 | 4.9; 16.6 | 34.3; 25.5^j^
Tereshchenko, 2014^62^ Fair | 15,375^k^ | Median 14 | CHD: 5% HF:5% MI: 4% Stroke: 2% | NR^l^ | 54 (5.8) | 55 | 27 | <5: 12,463 (96%) 5-20: 565 (4%) >20: 21 (0.2%) Most low SCD risk | 28 (5.5) | 25 | 10 | 26

a Breakdown by FRS Categories by % 10-year risk was as follows: <5.0:297 (13.6); 5.0-9.9: 525 (23.9); 10.0-19.9: 853 (38.9); ≥20.0: 517 (23.6)

b Study excluded those with self-reported chest pain suggestive of angina or leg pain suggestive of claudication

c The number of participants shown here is the number in analyses eligible for our review. The authors used the 1,264 participants in the WHI blood subsample for the eligible analyses (the larger study included 14.749 participants. 7593 from the estrogen + progestin group and 7.156 from the placebo group).

d When this table includes a range, it means that the data were not reported for the full sample, but were reported separately for subgroups

e % nonwhite was NR for full sample, but the authors reported that 45% of diabetic participants were black.

f Exclusion criteria listed pacemaker implantation, atrial fibrillation, advanced or complete atrioventricular block, dextrocardia, complete left or right bundle block, heart rate over 150 bpm, and history of stroke or MI, but did not address history of CHD, TIA, angina, or PAD.

g For sample with >=10 years follow-up (sample used to calculate discrimination and reclassification outcomes): 4923 had>=10 yearsof follow-up for the endpoint of fatal CVD, 5418 had >=10 years of follow-up for the endpoint of fatalandnonfatalCVD, and 6907 had >=10 years of follow-up for the endpoint of all-cause mortality.

h Median for fatal CVD (primary outcome was 10.9); median for fatal or nonfatal CVD combined (secondary endpoint) was 9.8 years, and median for all-cause mortality was 11.9 years.

i Baseline risk from the SCORE Risk Model: For participants with no ECG Changes: 13.1 (8.0-21.1); for those with ECG Changes: 18.3 (10.7-29.6)

j When 2 numbers are present in these, they are for derivation cohort and the validation cohort

k 13,049 CVD-free persons were in the reclassification analyses

l The study defined prevalent CHD to include those with symptoms of angina or claudication as well as those with diagnoses of CHD.

Abbreviations: AUC=area under the curve; CAD=coronary artery disease; CHD=coronary heart disease; CV=cardiovascular; CVD-cardiovascular disease; DM=diabetes mellitus; FRS=Framingham Risk Score; HF=heart failure; HTN=hypertension; MI=myocardial infarction; NHANES=National Health and Nutrition Examination Survey; NR=notreported; SCD=spontaneous cardiac death; SD=standard deviation.

For the base model, three studies used the FRS (with published coefficients of the original model),^49,57,63^ one used the FRS and the PCE (with published coefficients; it also included model development analyses using FRS variables),^59^ one focused on model development (with traditional risk factors) but also used FRS (with published coefficients) in some secondary analyses,^58^ and four were model development studies using FRS variables (one of those also included alcohol intake and heart rate^61^).^60-62,^ ^64^

All were population-based studies. Overall, the studies provided little or no information about any evaluation of whether participants had symptoms at baseline. It is unclear what proportion of participants were truly asymptomatic. One study reported excluding those with angina or claudication.^57^ Another study included participants with symptoms of angina or claudication, counting them among the 5 percent with prevalent CHD enrolled in the study.^62^ The studies either excluded those with a history of CVD or enrolled a small percentage of persons with a history of CVD. The mean age of participants ranged from 54 to 73 years. The majority of participants in all studies were women and one study enrolled only women.^49^ Three studies did not report information about race/ethnicity; the range of nonwhite participants in those that did report race/ethnicity was 9 to 41 percent. The baseline prevalence of diabetes ranged from 0 to 13 percent. The percentage of smokers ranged from 22 to 54 percent. Mean baseline CVD risk was not reported by most studies.

Study end points included all-cause mortality,^57,59,60^ CV mortality,^57,59,60,63^ CHD events,^49,58,60,^ ^64^ stroke events,^61^ CVD events,^49,60^ sudden cardiac death,^62^ and ischemic heart disease mortality.^59^

One study was rated as good quality,^58^ and the others were rated as fair (Appendix D). The most common methodological concerns were selective inclusion of participants in the model based on data availability (9/9), unknown masking of outcome assessors (8/9), unknown if predictors were assessed masked for the outcome (7/9), not reporting CIs for either calibration or discrimination (5/9), not reporting calibration (5/9), using base model equations that have not been externally validated (i.e., model development studies) (4/9),^58,60,61,64^ not reporting the amount of missing data (2/9), and mean duration of followup less than 10 years (2/9).^49,58^ In addition, of the studies reporting reclassification, just three included a threshold between risk categories corresponding to the current USPSTF recommendations for initiating preventive medications (i.e., 7.5% or 10% 10-year risk).^57-59^ Of the three, one reported using cut points between categories of 1, 5, and 10 percent;^59^ one used <5, 5 to 9.9, 10 to 19.9, and 20 or greater;^57^ and one used <7.5 percent, 7.5 percent to 15 percent, and >15 percent.^58^ The study that used cut points of 1, 5 and 10 percent cited the European Society of Cardiology recommendations (from 2012) for lipid management as the rationale for the chosen cut points; those recommendations are based on SCORE (which predicts CVD death), and the recommendations describe that a 5 percent SCORE risk of CVD death equates to a 10 to 25 percent 10-year FRS risk of total CVD, depending on which of the several Framingham models is chosen.^65^ One study based NRI cut points for risk categories on the distribution of the data rather than using a priori cut points.^60^ One study included alcohol use and heart rate in addition to traditional risk factors in its base model.^61^

Among the five studies that evaluated multiple ECG changes, the most common methodological concerns (Appendix D) were selective inclusion of participants in the model based on data availability (5/5), unknown masking of outcome assessors (4/5), unknown if predictors were assessed masked for the outcome (4/5), not reporting CIs for either calibration or discrimination (3/5), not reporting the amount of missing data (2/5), not reporting calibration (2/5), using base model equations that have not been externally validated (i.e., model development studies) (2/5),^58,60^ and mean duration of followup less than 10 years (2/5).^49,58^ In addition, two studies reporting reclassification did not use the risk categories commonly used in current practice in the United States for making treatment decisions.^59,60^ One study based NRI cut points for risk categories based on the distribution of the data rather than using a priori cut points.^60^

#### Results of Studies Evaluating Resting ECG: Multiple ECG Changes

Five studies evaluated the effect of adding major or minor ECG abnormalities or an ECG risk equation (that included multiple ECG abnormalities) to traditional risk factors.^49,57-60^ Four of the five evaluated the incremental improvement of adding major or minor ECG abnormalities to the FRS or PCE (with published coefficients) for some of the outcomes reported.^49,57-59^ Three studies evaluated CHD events,^49,58,60^ two studies evaluated CVD events,^49,60^ three studies evaluated CVD mortality,^57,59,60^ three studies evaluated all-cause mortality,^57,59,60^ and one evaluated ischemic heart disease mortality.^59^ The frequency of ECG abnormalities across these studies ranged from 31 to 55 percent (Appendix E Table 4).

##### Discrimination

All five studies reported discrimination for the addition of ECG variables to traditional risk factors. Three of the five reported it using FRS or PCE with published coefficients.^49,57,59^ Main results are shown in Figure 4 and Figure 5, illustrating the AUC or C-statistic for the base model (black squares in the figures) and the AUC or C-statistic for the base model plus ECG changes (white squares in the figures). Figure 4 is limited to the studies that used FRS or PCE with published coefficients for the base model whereas Figure 5 also shows model development studies. In addition to the AUC or C-statistic results, the columns of the figures show the outcome, ECG findings evaluated, base model used, sample size, and number of participants with an event. All five studies reported very small^57^ to small absolute improvements in AUC or C-statistics. Two studies reported p-values, with one study indicating statistically significant differences between models with ECG abnormalities and a base model with conventional risk factors for outcomes of fatal CVD and combined fatal and nonfatal CVD (p<0.001);^60^ the other study approached statistical significance (p=0.05).^57^

##### Calibration or Overall Performance

Three studies reported calibration or overall performance of models that added multiple changes from resting ECG to traditional risk factors (Appendix E Table 2).^49,57,58^ Two of the studies used the FRS (with published coefficients) in base models,^49,57^ and one was a model development study (it reported reclassification for the addition of ECG variables to FRS, but only reported calibration for a model with ECG and FRS variables).^58^ None of the studies reported figures such as calibration plots. The measures reported included likelihood ratio χ2 test,^49,58^ Hosmer-Lemeshow χ^2^,^57,58^ and Bayes information criterion (BIC).^57^

The two studies that used the FRS were both conducted in the United States and focused on prediction of CV mortality^57^ or CHD events and CVD events.^49^ One study (6,025 participants) using NHANES data reported that the addition of major and minor ECG changes improved calibration and performance for predicting CV mortality (Hosmer-Lemeshow χ2 decreased from 15.14 to 10.98, p-values 0.05 and 0.2, respectively; BIC decreased from 3,360.54 to 3,358.28).^57^ The other study (1,264 participants) reported that the addition of major and minor ECG abnormalities to FRS improved model performance for predicting both CHD and CVD events (likelihood ratio chi square test: p=0.004 and p=0.02, respectively).

The one model development study that reported calibration for a model with ECG and FRS variables was conducted in the United States and used the Health ABC Study cohort of 2,192 adults ages 70 to 79 years.^58^ The study reported that a model with traditional risk factors (FRS variables) did not show a good calibration and was not improved by the addition of ECG abnormalities (Hosmer-Lemeshow χ2 increased with the addition of ECG abnormalities from 67.6 to 87.9, likelihood ratio p<0.00005, goodness of fit p-values 0.03 for FRS variables vs. 0.01 for FRS variables plus ECG).^58^

##### Risk Reclassification

Four of the five studies evaluating multiple ECG changes reported results on reclassification when adding resting ECG to traditional risk factors (Appendix E Table 2; Figures 6 and 7).^57-60^ Figures 6 and 7 show the NRI results, with black squares indicating the total NRI (sum of the event NRI and nonevent NRI), gray squares indicating the event NRI (net upward reclassification among persons who had an event), and white squares representing nonevent NRI (net downward reclassification among persons who did not have an event). For some studies, only the total NRI (black square) is provided because the data for event and nonevent NRI were not reported. Figure 6 shows model development studies and studies that used FRS or PCE with published coefficients for the base model, whereas Figure 7 is limited to studies that used FRS or PCE with published coefficients for the base model. In addition to the NRI results, the columns of the figures show the outcome, ECG findings evaluated, base model used, sample size, number of participants with an event, and the risk categories used for analyses. Three of the studies used the FRS (with published coefficients) in base models,^57-59^ one also used PCE (with published coefficients) and a model with FRS variables (not using published coefficients),^59^ and one was a model development study.^60^ All four studies reported NRI and all but one^60^ provided event NRI or nonevent NRI data (or the table to allow us to calculate it) for some models. Two studies reported IDI (Appendix E Table 2).^58,59^

For studies using published coefficient models, Figure 7 shows the net reclassification results. Three studies reported outcomes of reclassification and IDI. One study of adults in the NHANES population used four risk categories (<5%, 5 to 10%, 10 to 20%, and >20%) to calculate reclassification indices.^57^ Investigators reported an overall NRI of 3.6 percent, where the NRI for those with events was 3 percent and the NRI for those without events was 0.6 percent, indicating a net appropriate reclassification of those with CVD mortality upward into higher risk categories. This study also reported a clinical NRI for intermediate risk patients of 13.6 percent, although this estimate was not corrected for bias.^66^ The absolute value of the IDI was low, although statistically significant. (0.0001, p<0.001). A study of older adults in the Healthy Aging and Body Composition (Healthy ABC) study also reported an improved overall NRI and IDI when ECG abnormalities were added to FRS (NRI 5.7% [95% CI, -0.4 to 11.6], IDI, 1.03% [95% CI, 0.56% to 1.50%]), although specific NRIs for events and nonevents were not provided for the comparison with FRS.^58^ The third study evaluated the addition of an ECG risk equation (that included frontal T axis, QT interval, and heart rate) to FRS, PCE, or a model with traditional risk factors.^59^ It used NHANES I data to derive the risk equation and validated the model with NHANES III.^59^ The clinical risk thresholds were based on the European Society of Cardiology (1%, 5%, and 10%). Adding the ECG risk equation to the FRS, PCE, or conventional risk factors resulted in improved classification. Categorical NRIs ranged from 4 to 30 percent, and continuous NRI ranged from 33 to 57 percent. Absolute IDI ranged from 0.2 to 2.6 percent, and relative IDIs ranged from 7 percent to 47 percent.

Three model development studies examined improvement in CV risk prediction when any ECG abnormality was added to conventional CV risk factors, which included diabetes in addition to the risk factors of the FRS variables.^58-60^ Two of them also evaluated published coefficient models (FRS or PCE) as described in the previous paragraph.^58,59^ Two studies were conducted in older adult populations with mean age ranging from 70 to 74 years. The Healthy ABC study looked at the outcome of CHD,^58^ while a study of the Copenhagen City Heart Study examined outcomes of fatal CVD events, fatal and nonfatal CVD events, and all-cause mortality.^60^ The third study used NHANES cohorts to evaluate the addition of an ECG risk score to several base models.^59^ All three studies reported improvements in discrimination and reclassification for all outcomes examined.

The models using the Healthy ABC cohort reported an NRI for those with events of -0.9 percent, indicating inappropriate reclassification of patients with CHD events to lower risk categories. The NRI for persons without events was 8.3 percent, indicating appropriate reclassification of patients without CHD events to lower risk categories. The study authors reported on reclassification of intermediate risk participants using an unadjusted and adjusted clinical NRI (13.6% and 6.7%, respectively). The Copenhagen City Heart Study reported improved categorical NRIs and continuous NRIs, although event and nonevent component NRIs were not reported for the former (Appendix E Table 2 and Figure 6).^60^ The study that evaluated the addition of an ECG risk equation (that included frontal T axis, QT interval, heart rate, age, and sex) to a model with traditional risk factors used NHANES I data to derive the risk equation and validated the model with NHANES III.^59^ The clinical risk thresholds were based on the European Society of Cardiology (1%, 5%, and 10%). Adding the ECG risk equation to conventional risk factors resulted in improved classification. Categorical NRIs ranged from 4 percent (for fatal ischemic heart disease) to 11 percent (for all-cause mortality), with reclassification to higher categories for persons with events accounting for most of the total NRI (i.e., event NRIs were greater than nonevent NRIs).

#### Results of Studies Evaluating Resting ECG: Single ECG Changes

Five studies evaluated the effect of adding a single ECG abnormality to traditional risk factors. Studies evaluated a range of outcomes including CVD events,^60^ CHD events,^64^ stroke,^61^ CVD mortality,^60,63^ sudden cardiac death,^62^ and all-cause mortality.^60^ Three studies evaluated T wave changes and other ventricular repolarization abnormalities, three studies examined LVH, and the remaining two studies looked at a variety of ECG changes. The frequency of ECG abnormalities across the studies that evaluated single ECG changes ranged from 1 to 24 percent (Appendix E Table 4).

##### T Wave Changes and Other Ventricular Repolarization Abnormalities

One study using NHANES III data examined the effect of adding observed T wave amplitude greater than -0.2 mV in lead aVR to the FRS on risk prediction of CV mortality.^63^ Investigators observed an improvement in discrimination (C-statistic 0.812 to 0.820), good calibration, and overall categorical NRI of 0.07 using clinical risk categories of <5 percent, 5 to 10 percent, 10 to 20 percent, and >20 percent. Net reclassification of subjects with events was 2.7 percent, and net reclassification of subjects without events was 2.3 percent, indicating participants were appropriately reclassified to higher or lower risk categories. IDI was reported as 0.012 (p<0.01).

The Copenhagen City Heart study examined the addition of any T wave changes or ventricular conduction delay (VCD) to conventional CV risk factors. For both repolarization abnormalities, the C-statistic improved from 0.705 to 0.716 (T wave) or 0.706 (VCD) for the outcome of fatal CVD events. For the combined outcome of nonfatal and fatal CVD events, discrimination improved from 0.651 to 0.658 for any T wave abnormality, but there was no change for VCD. Calibration results were not reported. Different risk thresholds were used for outcomes of fatal CVD events and fatal and nonfatal CVD events (Appendix E Table 2 and Figure 6) when calculating categorical NRIs, and separate event and nonevent NRIs were not reported. Adding T wave changes to conventional risk factors resulted in an overall continuous NRI of 29.2 percent and a categorical NRI of 5.4 percent for fatal CVD events and 20.3 percent and 2.7 percent for fatal and nonfatal CVD events, respectively. Addition of VCD to conventional risk factors resulted in small but significant NRIs for fatal CVD events (overall continuous NRI of 12.1% and categorical NRI of 1.1%) but nonsignificant or no change for fatal and nonfatal CVD events.

Finally, prolonged QTc interval was added to conventional risk factors to participants in the Jichi Medical School Cohort. Discrimination and calibration results were not reported. Adding prolonged QTc to conventional risk factors resulted in a categorical NRI of 0.026 (event NRI, 1.35%; nonevent NRI, 1.22%) and nonsignificant IDI (0.291; p=0.80).^61^

##### Left Ventricular Hypertrophy

Three studies added LVH to conventional risk factors.^60,61,64^ In the Copenhagen City Heart study, the addition of LVH to conventional risk factors resulted in increased discrimination of fatal CVD events and continuous and categorical NRIs of 2.8 percent and 1.1 percent, respectively.^60^ There was no improvement in discrimination or significant NRI findings for fatal or nonfatal CVD events. Calibration and IDI results were not reported for this study. In a study of the Atherosclerosis Risk in Communities (ARIC) cohort, LVH was examined as a continuous measure using the Cornell score, as well as a categorical variable, by gender and diabetes subgroups.^64^ For women, adding continuous or categorical LVH ECG findings to conventional risk factors worsened discrimination of CHD events (0.707 and 0.709, respectively vs 0.711) among those with diabetes and did not change discrimination in those without diabetes (0.777 for all models). For men, there was no or minimal improvement in discrimination. Calibration, reclassification, and IDI outcomes were not reported. The Jichi Medical School Cohort did not report discrimination or calibration outcomes but did report a categorical NRI of 0.020 (event NRI, 1.01%; nonevent NRI, 1.01%) and IDI of 0.004 (p=0.75) for a model that included LVH.^61^

##### Other ECG Changes

The remaining studies evaluated different individual ECG changes combined with conventional risk factors.^60,62^ One study examined the effect of adding the finding of a deep terminal negativity of the P wave in lead V1 to conventional risk factors and reported a categorical NRI of 0.028 for clinical risk thresholds of 5 percent and 15 percent.^62^ Event NRI was 0.028, indicating participants who had events were primarily reclassified to higher risk categories. Discrimination, calibration, and IDI were not reported.

In the Copenhagen City Heart Study, Q waves, ST segment depressions, and resting heart rate were added to conventional risk factors with improvements in discrimination compared with conventional risk factors alone for fatal CVD events and fatal or nonfatal CVD events^60^ (Appendix E Table 2). However, categorical NRIs were only significant for ST segment depressions (3.1% for fatal CVD, 2.2% for all CVD events), and event and nonevent NRIs were not reported separately. Calibration and IDI were also not reported.

### KQ 3a What Are the Harms of Screening With Resting or Exercise ECG, Including Harms of Subsequent Procedures or Interventions Initiated as a Result of Screening? 3b. Do the Harms of Screening Vary for Subgroups Defined by Baseline CVD Risk, Age, Sex, or Race/Ethnicity?

#### Summary

One eligible study reported on harms from subsequent procedures or interventions initiated as a result of screening. It reported that one person out of 12 undergoing revascularization had a nonfatal MI. No other eligible studies reported rates of harms from screening asymptomatic adults with resting or exercise ECG. We searched for, but did not find, other studies evaluating potential harms such as mortality, arrhythmia, CV events, injuries, anxiety, labeling, and harms of subsequent procedures or interventions initiated as a result of screening.

#### Detailed Results

One of the fair-quality RCTs described in KQ 1, the DADDY-D trial, reported some results eligible for this KQ.^53^ Twenty out of 262 participants (7.6%) in the screened group had positive ETTs. Of those 20, 17 underwent coronary angiography (6.5% of the 262 in the screened group). Angiography revealed critical stenosis (not defined) in 71 percent (12/17), and all patients with critical stenosis underwent revascularization procedures (7 percutaneous and 5 surgical). One patient having percutaneous revascularization had a nonfatal acute MI 3 days after the procedure and underwent a second percutaneous angioplasty. His ejection fraction was reported to be normal 6 months after the event.

The other trial described in KQ 1 (DYNAMIT) reported the number of some subsequent tests but did not report whether any of the tests or interventions resulted in harms; adverse events that occurred during followup were not recorded.^52^ Sixty-eight of the 316 participants (21.5%) in the screened group had a definitely abnormal or an uncertain screening test (exercise test or SPECT) result. Of those, 38 underwent coronary angiography (12% of the 316 in the screened group) and nine subsequently underwent coronary angioplasty (7 of those 9 received stents) and three had coronary artery bypass graft.