# 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and key questions (KQs). Figure 1 shows the analytic framework and KQs that guided the review. Three KQs were developed for this review:

1a Does the addition of screening with resting or exercise electrocardiography (ECG) improve health outcomes compared with traditional CVD risk factor assessment alone in asymptomatic adults?
1b Does improvement in health outcomes vary for subgroups defined by baseline CVD risk (e.g., low, intermediate, or high risk), age, sex, or race/ethnicity?
2 Does the addition of screening with resting or exercise ECG to traditional CVD risk factor assessment accurately reclassify persons into different risk groups (e.g., high-, intermediate-, and low-risk groups) or improve measures of calibration and discrimination?
3a What are the harms of screening with resting or exercise ECG, including harms of subsequent procedures or interventions initiated as a result of screening?
3b Do the harms of screening vary for subgroups defined by baseline CVD risk (e.g., low, intermediate, or high risk), age, sex, or race/ethnicity?

Figure 1 Analytic Framework

^*^ Includes adults regardless of their CVD risk (those with low, intermediate, or high risk are eligible) as assessed by traditional risk factors (those included in Framingham risk models): male sex, older age, cigarette smoking, hypertension, dyslipidemia (high total cholesterol, high low-density lipoprotein cholesterol, or low high-density lipoprotein cholesterol), and diabetes.

^†^ This systematic review does not include key questions about the benefits and harms of preventive medications to reduce cardiovascular risk (i.e., aspirin and lipid-lowering therapy) or the benefits and harms of lifestyle counseling, because those have been addressed by other systematic reviews for the USPSTF.

Abbreviations: CVD = cardiovascular disease; ECG = electrocardiography; KQ — key question.

Figure depicts the key questions within the context of the eligible populations, screenings/interventions, comparisons, outcomes, timing, and settings. On the left, the population of interest is adults without symptoms or a diagnosis of CVD. Moving from left to right, the figure illustrates the overarching question: Does the addition of screening with resting or exercise ECG improve health outcomes (i.e., reduce all-cause mortality, cardiovascular mortality, or cardiovascular events) compared with traditional CVD risk factor assessment alone in asymptomatic adults (KQ1)? The figure depicts the pathway from screening with ECG to measures of reclassification, calibration, or discrimination to illustrate the question: Does the addition of screening with resting or exercise ECG to traditional CVD risk factor assessment accurately reclassify persons into different risk groups (e.g., high-, intermediate-, and low-risk groups) or improve measures of calibration and discrimination (KQ2)? Screening may result in harms (KQ3). Following reclassification, persons at increased risk of CVD may receive preventive medications or lifestyle counseling, which may lead to improved health outcomes.

Key Questions to Be Systematically Reviewed

1a Does the addition of screening with resting or exercise electrocardiography (ECG) improve health outcomes compared with traditional cardiovascular disease (CVD) risk factor assessment alone in asymptomatic adults?
1b Does improvement in health outcomes vary for subgroups defined by baseline CVD risk (e.g., low, intermediate, or high risk), age, sex, or race/ethnicity?
2 Does the addition of screening with resting or exercise ECG to traditional CVD risk factor assessment accurately reclassify persons into different risk groups (e.g., high-, intermediate-, and low-risk groups) or improve measures of calibration and discrimination?
3a What are the harms of screening with resting or exercise ECG, including harms of subsequent procedures or interventions initiated as a result of screening?
3b Do the harms vary for subgroups defined by baseline CVD risk (e.g., low, intermediate, or high risk), age, sex, or race/ethnicity?

In addition to addressing our KQs, evidence related to two Contextual Questions was assessed. The first focused on what medications (i.e., aspirin, lipid-lowering therapy) are recommended for persons in each CVD risk category and the fidelity to prescribing and taking the recommended medications. The second focused on the harms and benefits of revascularization procedures in adults without symptoms or a prior diagnosis of CVD. These Contextual Questions were not a part of the systematic review. They are intended to provide additional background information. Literature addressing these questions is summarized in Appendix A.

## Data Sources and Searches

PubMed/MEDLINE and the Cochrane Library were searched for English-language articles published from January 2009 through May 30, 2017. Medical Subject Headings were used as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. The search relied primarily on the 2011 systematic review for the USPSTF^42^ to identify potentially relevant studies published before 2009 (we reassessed all articles included in that systematic review using the eligibility criteria). Complete search terms and limits are listed in Appendix B1. Targeted searches for unpublished literature were conducted by searching ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform. To supplement electronic searches, the reference lists of pertinent review articles and studies that met the inclusion criteria were reviewed and all previously unidentified relevant articles were added. All literature suggested by peer reviewers or public comment respondents was reviewed for eligibility. Since May 2017, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on April 4, 2018 and no additional studies meeting eligibility criteria were identified. All literature search results were managed using EndNote^TM^ version 7.4 (Thomson Reuters, New York, NY).

## Study Selection

Inclusion and exclusion criteria were developed for populations, interventions, comparators, outcomes, settings, and study designs with input from the USPSTF (Appendix B2). Englishlanguage studies of adults age 18 years or older without symptoms or a diagnosis of CVD were included. Studies of children, adolescents, and persons with a history of CVD or symptoms suggesting CVD were excluded. Studies assessing resting ECG or exercise ECG were included and studies that assessed radiology tests, echocardiography, and vectorcardiography were excluded. Eligible studies recruited participants from primary care settings, occupational medicine settings, or the general population in countries categorized as “very high” on the Human Development Index.

For all KQs, controlled clinical trials and randomized, controlled trials (RCTs) comparing groups that were screened with groups that were not screened (i.e., comparing risk stratification using ECG plus traditional risk factors vs. risk stratification using traditional risk factors alone) were eligible. For KQ 1 (direct evidence that screening improves health outcomes), eligible outcomes included all-cause mortality, CV mortality, and CV events (MI, angina, stroke, congestive heart failure, composite CV outcomes).

For KQ 2 (calibration, discrimination, and reclassification), prospective cohort studies comparing CVD risk assessment models that included ECG findings with those that did not include ECG findings were also eligible. Studies were required to report reclassification (ability to correctly reassign persons into clinically meaningful risk categories), calibration (agreement between observed and predicted outcomes), or discrimination (ability to distinguish between persons who will vs. will not have an event). Detailed descriptions of the specific test performance measures are provided in Table 1. These measures assess performance of risk prediction models or the comparative performance of models. Studies that only assessed the association between ECG findings and outcomes (e.g., with adjusted hazard ratios) were excluded. The review focused on the benefits and harms of adding ECG to the current standard practice of CVD risk prediction using traditional risk factors: male sex, older age, cigarette smoking, hypertension, dyslipidemia (high total cholesterol, high low-density lipoprotein cholesterol, or low HDL-C), and diabetes. In current clinical practice, the PCE or FRS is typically used for risk prediction. Studies were not required to specifically use the PCE or FRS to be eligible, although such studies have greatest applicability to current practice. Eligible base models included age, sex, systolic blood pressure, antihypertensive medication use, total cholesterol, HDL, and current smoking or restricted samples to remove some of these variables. Models were not required to include diabetes or race/ethnicity, but models were eligible that included them. Comparisons that would not allow us to isolate the effect attributable to ECG were not eligible.

Table 1 Test Performance Measures for Comparing Risk Assessment or Prediction Models

Purpose of Outcome Measure | Example Measures of Test Performance | Description
Discrimination | c-statistic or AUC; change in c-statistic or AUC | The probability that, for a randomly selected pair of individuals, one with disease and the other without, that the person with disease will have the higher estimated disease probability according to the model. The C-statistic can be conceptualized as the area under the ROC curve (plots sensitivity against 1-specificity); as a rank order statistic, it is insensitive to systematic errors in calibration. The Harrell’s C-statistic is an extension of the AUC for survival analysis allowing for right-censored data and variable time to follow up. The change in c-statistic or AUC can be insensitive in assessing the impact of adding new predictors to a model, and the impact of a new predictor on c-statistics is lower when other strong predictors are in the model.
Calibration | Calibration plot | Graphical assessment of calibration with predictions on the x-axis and outcome on the y-axis. Calibration in the large and calibration slope can be derived from calibration plots.
Calibration | O:E | The ratio of observed to expected events.
Calibration | Hosmer-Lemeshow χ^2^ | Calculated by summing differences between observed and predicted probabilities in each group (e.g., groups defined by deciles or risk strata); a significant p-value signals poor fit. The test is sensitive to how groups are constructed and sensitive to sample size, often being nonsignificant for small N and significant for large N.
Overall performance (captures both calibration and discrimination aspects) | Akaike information criterion (AIC) and Bayes information criterion (BIC) | Measures used during model development to aid in inclusion or exclusion of predictors in a model. The AIC is a function of log likelihood that adds a penalty for each added predictor. The BIC is similar, though imposes a greater penalty than the AIC for added variables. Lower values of both measures indicate better model fit. A change of >10 in the AIC has been proposed to indicate strong evidence for a difference in models.
Overall performance (captures both calibration and discrimination aspects) | Likelihood ratio χ^2^ | Likelihood ratio χ^2^ is a global test of model fit and is a function of the number of terms in the model. Higher values for the ratio, or difference between models, indicate better fit (as do lower absolute log-likelihood values). A global χ^2^ is generally the same as a likelihood χ^2^ (twice the log likelihood ratio).
Overall performance (captures both calibration and discrimination aspects) | R^2^ | There are a number of ways to calculate an R^2^ for a logistic regression. Nagelkerke’s generalized R^2^ is generally analogous to the percentage of variance explained in a linear model and is adjusted to a range of 0 to 1. Higher values indicate better fit. The R^2^ is more helpful than the Brier score because it can be compared across models/studies.
Overall performance (captures both calibration and discrimination aspects) | Brier score | The Brier score computes the sum of squared differences between observed outcomes and fitted probability, where lower values indicate that predicted probabilities are closer to observed outcomes.
Risk reclassification | Net reclassification index or improvement (NRI) | The sum of differences in proportions of individuals moving up (a risk category) minus those moving down with a cardiovascular disease outcome, plus the proportion moving down minus those moving up without an outcome. NRI can be considered separately as the sum of the event NRI (P(up\|event) - P(down\|event)) and nonevent NRI (P(down nonevent) - P(up\|nonevent)). The NRI is of limited value in comparing models with different risk categories.
Risk reclassification | Integrated discriminationimprovement (IDI) | Integrates the NRI over all possible cut-offs; equivalent to difference in discrimination slopes of the two models and to the difference in R^2^.

Note: Table was modified with permission of the authors from the Kaiser Permanente Evidence-based Practice Center; from a table in their report on nontraditional risk factors.

Abbreviations: AIC=Akaike information criterion; AUC=area under the curve; BIC=Bayes information criterion; FRS=Framingham risk score; IDI=integrated discrimination improvement; N=sample size; NRI=net reclassification index or improvement; PCE=pooled cohort equations; ROC=receiver operating characteristic.

For KQ 3 (harms), prospective cohort studies, large retrospective cohort studies, and welldesigned case-control studies (only for rare events) were also eligible. Eligible harms included mortality, arrhythmia, CV events, or injuries from exercise ECG; anxiety; labeling; and harms of subsequent procedures or interventions initiated as a result of screening (e.g., subsequent angiography or revascularization procedures resulting in harm). For harms of subsequent procedures/interventions, studies that compare the procedure/intervention with no procedure/intervention were also eligible. For studies reporting rates of harms from exercise ECG or subsequent procedures/interventions, large registries or multicenter studies without a control group that report rates of harms for asymptomatic persons were also eligible. Two investigators independently reviewed titles and abstracts; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. Two investigators independently reviewed the full text to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

The quality of trials and cohort studies was assessed as good, fair, or poor, using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B3). For risk prediction studies (KQ 2), predefined criteria from the Checklist for Critical Appraisal and Data Extraction for Systematic Review of Prediction Modelling Studies (CHARMS)^43^ were used and adapted for this topic (Appendix B3). Two independent investigators assigned quality ratings for each study. Disagreements were resolved by discussion. Only studies rated as having good or fair quality were included.

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second team member reviewed all data extractions for completeness and accuracy.

## Data Synthesis and Analysis

Findings for each KQ were qualitatively synthesized by summarizing the characteristics and results of included studies in tables, figures, and narrative format. To determine whether metaanalyses were appropriate, the clinical and methodological heterogeneity of the studies was assessed following established guidance.^44^ The populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively, looking for similarities and differences. At least three similar studies had to be available to estimate pooled effects. For KQ 1, pooled effects were not estimated because fewer than three similar studies were found, but risk ratios and 95 percent confidence intervals were calculated for binary outcomes reported by the included RCTs and a forest plot showing the results was created. For KQ 2, considerable heterogeneity of ECG findings assessed, base prediction models used, outcomes (e.g., all-cause mortality, CV mortality, CVD events, fatal ischemic heart disease), and duration of followup was found; therefore, the results are presented in tabular format and in figures. Results were stratified by ECG findings evaluated, separating results for exercise ECG and resting ECG. Within the studies of resting ECG results were stratified to separate those that evaluated the addition of a constellation of ECG abnormalities from those that evaluated single/specific ECG changes. Results were categorized by the base models used as “published coefficient models,” meaning the model preserved the coefficients of original published models that have been externally validated (e.g., FRS or PCE), or as “model development.” For KQ 2, the C-statistic (Harrell’s C) and AUC were used as the primary measures of discrimination and were summarized together. Measures of overall performance were summarized with those of calibration. Net reclassification improvement (NRI) was the primary measure of reclassification, with event and nonevent NRIs reported separately when possible. There is no guidance in the literature about how to qualitatively characterize the magnitude or clinical meaning of changes in discrimination. To describe the magnitude of changes in discrimination, the following definitions were employed for practical reasons. For changes in the C-statistic, 0.1 or greater was considered large, 0.05-0.1 was considered to be moderate, 0.025-0.05 was considered small, and changes less than 0.025 were considered very small. C-statistics range from 0.5 to 1.0; the 0.1 cutpoint for large was set because it represents 20 percent of the possible range. A change in C-statistic of 0.025 approximates a 5 percent higher sensitivity when specificity is 50 percent. Analyses were conducted and figures were produced using Stata version 14 (StataCorp) and Microsoft Excel.

Two independent reviewers assessed the overall strength of the body of evidence for each KQ as high, moderate, low, or insufficient using methods developed for the USPSTF (based on methods of the EPC program^45,46^), based on the overall quality of studies, consistency of results between studies, precision of findings, and risk of reporting bias. The applicability of the findings to U.S. primary care populations and settings was also assessed. Discrepancies were resolved through consensus discussion.

## Expert Review and Public Comment

A draft report was reviewed by content experts, representatives of federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments, as appropriate. It was also posted for public comment. Based on the comments received we revised the report to add additional summary sections within the results; description and interpretation of measures for discrimination, calibration, and reclassification; description of prior USPSTF recommendations; and clarification that this review was limited to studies assessing resting or exercise ECG, along with discussion of the findings of another meta-analysis that evaluated any screening test for coronary artery disease in persons with type 2 diabetes.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and members of the USPSTF participated in developing the scope of work and reviewed draft reports, but the authors are solely responsible for the content.