# 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to inform an update of its 2012 recommendation on screening asymptomatic adults with electrocardiogram (ECG) for the prediction of cardiovascular disease (CVD) events.^1^ In 2012, the USPSTF recommended against screening with resting or exercise ECG for the prediction of coronary heart disease (CHD) events in asymptomatic adults at low risk for CHD events (D recommendation). For asymptomatic adults at intermediate or high risk, the USPSTF concluded that evidence was insufficient to assess the balance of benefits and harms of screening (I statement). The purpose of this report is to systematically evaluate the current evidence on using resting or exercise ECG to screen asymptomatic adults for CVD risk for populations and settings relevant to primary care in the United States. This report summarizes the evidence on the benefits and harms of adding screening with resting or exercise ECG to traditional CVD risk factor assessments compared with using traditional CVD risk factor assessments alone. This report also summarizes the evidence on whether the addition of ECG accurately reclassifies persons into different risk groups or improves measures of calibration and discrimination.

## Condition Definition

CVD is a broad term encompassing atherosclerotic conditions that affect the heart and blood vessels.^2-4^ CVD generally refers to atherosclerosis, including but not limited to CHD (also called ischemic heart disease), cerebrovascular disease, and peripheral artery disease (PAD). In patients with CVD, plaques form within the arteries, causing reduced blood flow and/or arterial blockage. Serious CVD events (sometimes described as hard outcomes) include myocardial infarction (MI), heart failure, stroke, and sudden cardiac death. Less severe CVD events (sometimes called soft outcomes) include angina, claudication, transient ischemic attack (TIA), and revascularization.

## Etiology and Natural History

In CVD, atherosclerotic plaque is deposited over many years within the endothelial lining of the coronary arteries, which provide oxygenated blood to the myocardium. The development of the plaque, containing not only lipids but other molecules secreted from various types of cells, is induced by a cascade of mechanisms including inflammatory processes.^5,^ ^6^ Some sites, such as branch points and the inner curves of arteries, are more susceptible to deposition of atherosclerotic plaque.^7^ Sudden plaque rupture, or intra-luminal thrombosis related to the exposure of the ruptured plaque’s thrombogenic core, is associated (though not invariably) with acute coronary syndrome, MI, and sudden cardiac death.^7,^ ^8^ Progression of atherosclerosis and of CVD is influenced by a variety of risk factors, some of them modifiable and thus targets for intervention.

Evidence of obstructive CHD, upon evaluation by coronary angiography, has been considered to be prognostic of significant morbidity and mortality; however, it has been demonstrated that culprit lesions, in patients who experience acute coronary events due to plaque rupture or acute thrombosis, may not be those angiographically observed to significantly occlude the vessel.^8,^ ^9^ Some persons do not experience symptoms before major first CVD events^10^ because major first events can result from plaque rupture in vessels without significant stenosis.

## Risk Factors

Traditional risk factors for CVD are male sex, older age, cigarette smoking, hypertension, dyslipidemia (high total or low-density lipoprotein cholesterol or low high-density lipoprotein [HDL] cholesterol), and diabetes. They are independently associated with risk of CVD and are included in the traditional Framingham risk assessment model.^11,^ ^12^ Some risk factors are modifiable and could be targets for treatment in patients identified as being at higher risk. Prevalence of risk factors is high in the United States: as of 2014, 16.9 percent of U.S. adults smoked cigarettes; as of 2012, 69 percent were overweight or obese, 13.1 percent had serum total cholesterol levels ≥240 mg/dL, 32.6 percent were hypertensive, and 8.5 percent of adults had diagnosed diabetes mellitus (another 3.3% had undiagnosed diabetes mellitus).^13^ More than 90 percent of CVD events occur in persons with one or more risk factors.^14^ Other factors, some behavioral and others biomarkers, are not included among the major independent traditional risk factors. Although they increase CVD risk to varying degrees, they have not been shown to consistently improve risk prediction in a clinically meaningful way beyond traditional risk factors; these include family history of early CVD, obesity, physical inactivity, atherogenic diet, and presence of prothrombic and proinflammatory factors.^12,^ ^13,^ ^15^

To help providers operationalize the large number of factors that need to be considered, risk prediction equations that integrate and weight the traditional risk factors are used commonly in clinical practice to assess 10-year risk of CVD events and to guide treatment decisions. The USPSTF recommends using the American College of Cardiology/American Heart Association (ACC/AHA) pooled cohort equations (PCE) to calculate 10-year risk for adults ages 40 to 75 years to inform decisions about statin use for prevention of CVD and to inform decisions about aspirin use for primary prevention.^2,^ ^16,^ ^17^ The USPSTF noted that concerns have been raised about the PCE’s potential to overpredict risk and their moderate discrimination, but also that they are the only U.S.-based, externally validated equations that report risk as a combination of cerebrovascular and CHD events.^2,^ ^17^ The PCE approach takes into account age, sex, race, cholesterol levels, systolic blood pressure level, antihypertension treatment, presence of diabetes, and smoking status as risk factors and focuses on prediction of hard outcomes, specifically, heart attack and death from CHD, ischemic stroke, and stroke-related death.^16^ Using the PCE and National Health and Nutrition Examination Survey data from 2011—2012, an estimated 9.4 percent of adults ages 40 to 79 years without a history of CVD have a 10-year risk greater than 20 percent.^18^ Age has a large influence on the PCE’s predicted risk, and it is estimated that 41 percent of men and 27 percent of women ages 60 to 69 years without a history of CVD will have a 10-year risk of at least 10 percent.^19^

## Prevalence and Burden

CVD is the leading cause of death in U.S. adults and causes about a third of all deaths.^13,^ ^18^ In the United States, an estimated 580,000 persons have a first MI each year and about 610,000 have a first stroke.^20^ Adult CVD prevalence increases with each decade of life, with higher prevalence among men than women.^13^ The average annual incidence of first major cardiovascular (CV) event increases from around 25 cases per 1,000 in men ages 35 to 44 years to 80 cases per 1,000 in men age 85 years or older. For women (compared with men), similar incidence rates are observed about 10 years later in life, although the gap narrows for women ages 75 to 84 years and is reversed by age 85 years or older. Prevalence of CHD and stroke were nearly 3 to 4 times greater for adults age 65 years or older than for those ages 45 to 64 years (19.8% vs. 7.1% and 8.3% vs. 2.9%, respectively).^21,^ ^22^ Disparities exist with regard to mortality from and prevalence of CVD. Mortality rates are lowest for white women and highest for black men, and prevalence is highest for American Indians/Alaska Natives and blacks.^21,^ ^22^ CVD is a major source of direct and indirect health care costs in the United States. The estimated total cost of CVD in 2015 was $182 billion, which is predicted to double by 2030.^13^

## Rationale for Screening and Screening Strategies

Because many patients do not have any symptoms of CVD before a serious first event, such as MI or stroke, identifying asymptomatic individuals for treatment with preventive medications may reduce risk for future CVD morbidity and mortality. Approximately 30 percent of patients presenting with acute coronary syndromes do not have a prior diagnosis of CVD.^10,^ ^23^ For screening with resting or exercise ECG to be effective, it must be able to reclassify individuals in a manner that results in treatment changes that improve health outcomes. For example, screening with ECG might reclassify persons into higher or lower risk categories. Appropriately reclassifying such individuals could help target use of preventive interventions to those most likely to benefit or could reduce use of preventive interventions for those least likely to benefit. However, if reclassification was inappropriate, it could lead to an increase in overtreatment or undertreatment.

Potential screening strategies include both resting and exercise ECG. Resting ECG records cardiac electrical activity over a short time, typically 10 seconds. Clinicians interpret the recorded ECG waveforms to look for evidence of conduction problems and/or myocardial ischemia. Resting or exercise ECGs have long been used as tests for the diagnostic evaluation of suspected CVD, which has led to consideration of their use for screening asymptomatic individua ls and risk prediction. Although the most common method of exercise testing is the exercise treadmill test, other methods include bicycles and ergometers. Both resting and exercise ECG may show markers of unrecognized previous MI, silent or inducible myocardial ischemia, and other cardiac abnormalities (such as left ventricular hypertrophy, bundle branch block, or arrhythmias) that may be associated with CVD or may predict future CVD events.

## Treatment Approaches

If screening for CVD risk results in appropriate risk reclassification, intensified preventive interventions focus on lipid-lowering therapy and aspirin, which have been demonstrated to reduce risk as assessed by a variety of outcomes.^24-28^ Other preventive interventions (smoking cessation, blood pressure control, and weight management) would not be significantly affected by reclassification of risk (e.g., recommendations for smoking cessation are the same regardless of risk classification). Current USPSTF recommendations for statins and aspirin for primary prevention are based on the 10-year CVD risk as estimated by the PCE.^2,^ ^17^ The USPSTF recommends initiating use of low- to moderate-dose statins in adults ages 40 to 75 years without a history of CVD who have one or more CVD risk factors (dyslipidemia, diabetes, hypertension, or smoking) and a calculated 10-year CVD risk of 10 percent or greater (B recommendation) and selectively offering statins to adults ages 40 to 75 years without a history of CVD who have one or more CVD risk factors and a calculated 10-year risk of 7.5 percent to 10 percent (C recommendation). For aspirin, the USPSTF recommends initiating low-dose aspirin use for the primary prevention of CVD and colorectal cancer in adults ages 50 to 59 years who have a 10% or greater 10-year CVD risk, are not at increased risk for bleeding, have a life expectancy of at least 10 years, and are willing to take low-dose aspirin daily for at least 10 years (B recommendation). The USPSTF also has a C recommendation for initiating low-dose aspirin use for the primary prevention of CVD and CRC in adults ages 60 to 69 years who have a 10 percent or greater 10-year CVD risk. The ACC and AHA jointly released guidelines (2014) recommending that moderate- to high-intensity statin therapy should be used in persons ages 40 to 75 years without a history of clinical CVD or diabetes and with an estimated 10-year risk of 7.5 percent or greater (Grade A, strong recommendation).^29^ The ACC/AHA also recommended moderate-intensity statins when risk is 5 percent to less than 7.5 percent (Grade C, weak recommendation).

## Recommendations and Clinical Practice in the United States

Numerous organizations recommend against routine screening of asymptomatic adults for CVD with resting or exercise ECG, including the American College of Physicians,^30^ the American Academy of Family Physicians,^31^ and the American College of Preventive Medicine (Appendix A Table 1).^32-34^ Screening of special populations is recommended by some groups. For example, the American Academy of Family Physicians recommends screening otherwise low-risk patients who have certain occupations in which undetected CVD could significantly affect the public (e.g., airline pilots),^35^ and the American College of Sports Medicine recommends screening moderate-risk patients who are beginning a new exercise regimen.^36^

Many risk prediction equations (i.e., tools, models, scores, calculators) are available and have been recommended in various countries for use in clinical practice to guide treatment decisions (Appendix A Table 2). The USPSTF and the ACC/AHA recommend using the PCE to calculate 10-year risk. The existing equations that have been externally validated vary in the risk factors included and predicted outcomes (e.g., global CVD outcomes vs. mortality vs. CHD-specific outcomes). The Framingham Risk Score (FRS) was the first widely used multivariable risk assessment tool^33,^ ^34,^ ^37^ and included sex, age, total and high-density lipoprotein cholesterol (HDL-C), blood pressure, diabetes, and smoking. A variety of Framingham-based risk equations have been externally validated.^27,^ ^33,^ ^34,^ ^37-39^ One early Framingham model (1991)^33^ included left ventricular hypertrophy (LVH) (determined by ECG) along with traditional risk factors, but it was dropped from later models. None of the currently recommended prediction equations include ECG.

Despite recommendations, use of risk assessment in clinical practice may be suboptimal. For example, a survey of over 900 U.S. physicians found that although more than 80 percent agreed that risk calculation is useful, only 41 percent reported that they use it in practice.^40^ Among those who use it, the majority use it to guide lipid-lowering therapy recommendations (69%) and aspirin therapy recommendations (54%).^40^ Limited data are available on using ECGs to assess CVD risk in asymptomatic persons, but a population-based retrospective cohort study of Canadian adults reported that 21.5 percent had an ECG within 30 days of an annual health exam.^41^ The proportion varied widely across 679 primary care practices (from 1.8% to 76.1%).