# Appendix E Additional Tables and Results

Appendix E Table 1 Results Of Included Randomized, Controlled Trials Reporting Health Outcomes (KQ 1)

First Author, Year Trial Name | G1 (N) G2 (N) | All-Cause Mortality G1 N (%) G2 N (%)HR (95% Cl) | CV Mortality G1 N (%) G2 N (%)HR (95% CI) | MI G1 N (%) G2 N (%) HR (95% CI) | Heart Failure G1 N (%) G2 N (%) HR (95% CI) | Stroke G1 N (%) G2 N (%) HR (95% CI) | Other CV Events G1 N (%) G2 N (%) HR (95% CI) | Composite CV Outcome G1 N (%) G2 N (%) HR (95% CI)
Lievre, 2011^47^ DYNAMIT | Screened (316) Not screened (315) | 15 (4.7) 13 (4.1) NR, NS | NR | 4(1.3) 8 (2.5) NR, NS | Hospitalized cardiac failure: 5 (1.6) 4 (1.3) NR, NS | 9 (2.8) 4 (1.3) NR, NS | Revascularization 18 (5.7) 21 (6.7) p=0.61 | Main endpoint^a^ 28 (8.9) 26 (8.3) 1.00 (0.59 to 1.71) Coronary events^b^13 (4.1) 15 (4.8) 0.77 (0.37 to 1.63)
Turrini et al, 2015^48^ DADDY-D | Screened (262) Not screened (258) | NR by group. Total of 19 deaths reported (6 cardiac and 13 non-cardiac) | All 1 (0.4) 5 (1.9) 0.197 (0.023 to 1.683) Female 0/53 (0) 3/51 (5.9) NA, p=0.077 | Non-fatal MI: All 11 (4.2) 12 (4.7) 0.908 (0.400 to 2.057) Female 5/53 (9.4) 1/51 (2) 4.916 (0.573 to 42.142) | All 2 (0.8) 7 (2.7) 0.273 (0.57 to 1.314) Female 0/53 (0) 3/51 (5.9) NA, p 0.065 | NR by group. Total of 7 strokes | NR | Cardiac events (primary outcome; composite of nonfatal MI or cardiac death) All 12 (4.6) 14 (5.4) 0.849 (0.393 to 1.837) Female 5/53 (9.4) 3/51 (5.9) 1.653 (0.395 to 6.928)
Turrini et al, 2015^48^ DADDY-D(continued) | | | Male 1/209 (0.5) 2/207 (1) 0.497 (0.045 to 5.483) ≥60 years 0/182 (0) 4/181 (2.2) NA, p=0.044 <60 years 1/80 (1.3) 1/77 (1.3) 0.993 (0.062 to 15.87) CV risk≥20 1/115 (0.9) 2/112 (1.8)0.494 (0.045 to 5.443) CV risk<200/147 (0) 3/146 (2.1) NA, p=0.08 | Male 6/209 (2.9) 11/207 (5.3) 0.535 (0.198 to 1.446) ≥60 years 7/182 (3.8) 8/181 (4.4)0.859 (0.311 to 2.370) <60 years 4/80 (5) 4/77 (5.2) 0.999 (0.249 to 3.981) CV risk≥20 4/115 (3.5) 6/112 (5.4) 0.656 (0.185 to 2.325) CV risk<20 7/147 (4.8) 6/146 (4.1) 1.176 (0.393 to 3.505) | Male 2/209 (1) 4/207 (1.9) 0.485 (0.89 to 2.647) ≥60 years 2/182 (1.1) 4/181 (2.2) 0.476 (0.087 to 2.599) <60 years 0/80 (0) 3/77 (3.9) NA, p 0.08 CV risk≥20 2/115 (1.7) 2/112 (1.8) 0.961 (0.135 to 6.822) CV risk<20 0/147 (0) 5/146 (3.4) NA, p=0.022 | | | Male 7/209 (3.3) 11/207 (5.3) 0.625 (0.242 to 1.614) ≥60 years 7/182 (3.8) 10/181 (5.5) 0.687 (0.261 to 1.805) <60 years 5/80 (6.3) 4/77 (5.2) 1.264 (0.339 to 4.707) CV risk≥20 5/115 (4.3) 6/112 (5.4) 0.822 (0.251 to 2.692) CV risk<20 7/147 (4.8) 8/146 (5.5) 0.879 (0.318 to 2.426)

a Composite endpoint of death from all causes. nonfatal MI. nonfatal stroke, or heart failure requiring hospitalization or emergency service intervention.

b Defined as fatal or nonfatal MI. hospitalized unstable angina, or heart failure requiring hospitalization or emergency service intervention.

Abbreviations: CI=confidence interval; CV=cardiovascular; DADDY-D=Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients; DYNAMIT=Do You Need to Assess Myocardial Ischemia in Type-2 diabetes; KQ=key question; G=group; HR=hazard ratio; MI=myocardial infarction; N=sample size; NA=not applicable;NR=not reported; NS=not significant.

Appendix E Table 2 Results Of Included Studies For KQ 2 That Evaluated Resting ECG

First Author, Year; Quality | Outcome(s) | N (%) With Outcome(s) | Outcome Measures | Models | Discrimination | Calibration | Reclassification
Auer, 2012^55^ Fair | CHD events^a^ | Total: 351 (16.0) CHD deaths: 96 (4.4) Acute Mis: 101 (4.6) Hospitalizations for angina or coronary revascularization: 154 (7.0) | Base model: CVRF Harrell C index Calibration NRI Adjusted clinical NRI IDI Base model: FRS NRI IDI | 1. CVRF model(used FRS variables)^b^ 2. CVRF + any ECG abnormality 3. FRS model 4. FRS + any ECG abnormality | Harrell C Index (95% CI) CVRF model: 0.58 (0.53–0.62) CVRF + ECG: 0.60 (0.56–0.65) | Hosmer-Lemes how chi-square CVRF model: 67.6 CVRF + ECG: 87.9 Likelihood ratio: p≤0.00005 Goodness of fit p value CVRF model: 0.03 CVRF model + ECG: 0.01 | CVRF + ECG vs. CVRF Overall sample NRI: 7.4% (3.1 %–19.0%) Event NRI: -0.9% Nonevent NRI: 8.3% Adjusted clinical NRI 6.7% (95% CI, 1.2% to 19.3%) IDI: 0.99% (0.32%–2.15%) For the Intermediate Risk Category: NRI 13.6% FRS + ECG vs. FRS NRI 5.7% (-0.4%–11.8%) IDI: 1.03% (0.56%–1.50%) Reclassification with Addition of ECG For those who experience a CHD event <7.5%, no change: 4 <7.5% to 7.5-<15%: 2<7.5% to ≥15%: 0 Total: 6 7.5- <15.0% to <7.5%: 7 7.5-<15.0%, no change: 91 7.5-<15% to ≥15%: 27 Total: 125 ≥15.0% to <7.5%: 0 ≥15.0% to 7.5-<15.0%: 25 ≥15%, no change: 195 Total: 220 For those who do not experience a CHD event <7.5%, no change: 74 <7.5% to 7.5-<15%: 17<7.5% to ≥15%: 0 Total: 91 7.5- <15.0% to <7.5%: 129 7.5- <15.0%, no change: 678 7.5-<15% to ≥15%: 149 Total: 956
Auer, 2012^55^ Fair (continued) | | | | | | | ≥15.0% to <7.5%: 0 ≥15.0% to 7.5-<15.0%: 189 ≥15%, no change: 605 Total: 794
Badheka, 2013^54^ Fair | CV mortality All-cause mortality | CV mortality: 739 (12.3) All-cause mortality: 1,824 (30.3) | AUC IDI Calibration NRI | Model A: FFSS^c^ Model B: FRS + ECG abnormalities | C-statistic Model A: 0.851 (0.836–0.865) Model B: 0.852 (0.838–0.866) p=0.05 | Hosmer-Lemes how chi-square Model A: 15.14 p=0.05 Model B: 10.98 p=0.2 Goodness of fit Likelihood ratio test: p=0.001 Bayesian information criterion Model A: 3360.54 Model B: 3358.28 | Overall NRI: 3.6%, p=0.0001; NRI for Those with Events: 3.0% p=0.03 NRI for Those without Events: NRI: 0.6% p=0.11 Absolute IDI: 0.0001, p≤0.001 For the Intermediate Risk Category: NRI 13.2% Reclassification with Addition of ECG Abnormalities For Those with Events <5%, no change: 92 <5% to 5-10%: 11 <5% to 10–20%: 0 <5% to >20%: 0 Total: 103 5-10% to <5%: 4 5-10%, no change: 98 5-10% to 10–20%: 26 5-10% to >20%: 0 Total: 128 10-20% to <5%: 0 10-20% to 5–10%: 14 10-20%, no change: 205 10-20% to ≥20%: 21 Total: 240 >20% to <5%: 0 >20% to 5-10%: 0 >20% to 10 20%: 19 >20%, no change: 208 Total: 227
Badheka, 2013^54^ Fair (continued) | | | | | | | Rsk Reclassified Higher from Each Category For Those with Events <5%: 11 (10.7%) 5% to <10%: 26 (20.3%) 10% to <20%: 21 (8.8%) >20%: NA Total: 58 (8.3%) Rsk Reclassified Lower from Each Category For Those with Events <5%: NA 5% to <10%: 4 (3%) 10% to <20%: 14 (5.8%) ≥20%: 19 (8.4%) Total: 37 (5.3%) For Those with no Events <5%, no change: 3209 <5% to 5–10%: 79 <5% to 10–20%: 0 <5% to >20%: 0 Total: 3,288 5-10% to <5%: 104 5-10%, no change: 702 5-10% to 10 20%: 53 5-10% to ≥20%: 0 Total: 859 10-20% to <5%: 0 10-20% to 5 10%: 65 10-20%, no change: 512 10-20% to ≥20%: 37 Total: 614 >20% to <5%: 0 >20% to 5–10%: 0 >20% to 10–20%: 31 >20%, no change: 239 Total: 270
Badheka, 2013^54^ Fair (continued) | | | | | | | Rsk Reclassified Higher No Events <5%: 79 (2.4%) 5% to <10%: 53 (6.2%) 10% to <20%: 37 (6.0%) >20%: NA Total: 169 (3.4%) Rsk Reclassified Lower No Events <5%: NA 5% to <10%: 104 (12.1%) 10% to <20%: 65 (10.6%) ≥20%: 31 (11.5%) Total: 200 (4.0%) Intermediate Rsk Cohort: NRI: 13.24% 137 (2.4%) and 187 (3.3%) were reclassified to higher and lower riskgroups, respectively
Badheka, 2013^53^ Fair | Cardiovascular (CV) mortality | 1,226 (15.5) | C-statistic AUROC Calibration Reclassification IDI NRI | Model A: FRS only Model B: FRS plus the variable T-wave amplitude inlead aVR | C-statistic Model A: 0.832 (0.822–0.841) Model B: 0.838(0.828–0.848) p<0.01 AUROC Model A: 0.812 (0.800–0.824) Model B: 0.820(0.807–0.832) p<0.01 | Hosmer-Lemeshow chi-square Model A: 13.7 Model B: 16.7 Goodness of fit Likelihood ratio test: p<0.01 Bayesian information criterion Model A: 5240.0 Model B: 5172.2 | Overall NRI: 0.07 (0.05–0.09) p<0.01 Reclassification of subjects with events: 2.7% p<0.01 Reclassification of subjects without events: 2.3% p<0.01 Absolute IDI 0.012 (0.009–0.015), p<0.01 Relative IDI 0.11 Participants with CVD disease events <5%, no change: 53 <5% to 5–<10%: 11 <5% to 10–<20%: 0 <5% to >20%: 0 Total: 64–5-<10% to <5%: 6 5-<10%, no change: 50 5-<10% to 10–<20%: 22 5-<10% to >20%: 0 Total: 78 10-<20% to <5%: 0 10-<20% to 5–<10%: 13 10-<20%, no change: 148 10-<20% to >20%: 60 Total: 221 >20% to <5%: 0 >20% to 5–<10%: 0 >20% to 10-<20%: 42 >20%, no change: 754 Total: 796
Badheka, 2013^53^ Fair (continued) | | | | | | | Participants with CVD disease events reclassified as higher risk from each category <5%: 11 5%–<10%: 22 10%–<20%: 60 >20%: NA Total: 93 Participants with CVD disease events reclassified as lower risk from each category <5%: NA 5%–<10%: 6 10%–<20%: 13 ≥20%: 42 Total: 61 Participants without CVD disease events <5%, no change: 2,426 <5% to 5–<10%: 135 <5% to 10–<20%: 0 <5% to >20%: 0 Total: 2,561 5–<10% to <5%: 221 5–<10%, no change: 764 5–<10% to 10–<20%: 158 5–<10% to ≥20%: 0 Total: 1,143 10–<20% to <5%: 0 10–<20% to 5-<10%: 216 10–<20%, no change: 898 10–<20% to >20%: 152 Total: 1,266
Badheka, 2013^53^ Fair (continued) | | | | | | | >20% to <5%: 0 >20% to 5-<10%: 0 >20% to 10–<20%: 158 >20%, no change: 12,22 Total: 1,380 Participants without CVD disease events reclassified as higher risk from each category <5%: 135 5%–<10%: 158 10%–<20%: 152 >20%: NA Total: 445 Participants without CVD disease events reclassified as lower risk from each category <5%: NA 5%–<10%: 221 10%–<20%: 216 >20%: 158 Total: 595 Intermediate risk cohort (5% to <20% risk): 60 (20%) of subjects with events and 219 (9.1%) of subjects without events were reclassified appropriately to higher and lower risk categories, respectively
Denes, 2007^58^ Fair | Incident coronary heart disease (CHD)^d^ Incident cardiovascular disease events^e^ | CFID events: 246 (1.7) CVD events: 595 (4) | AUC Calibration/overall performance | FRS FRS + ECG abnormality | AUROC (95% CI) FRS for CFID: 0.69 (0.61-0.86) FRS + ECG abnormality for CFID: 0.74 (0.66–0.90) FRS for CVD: 0.68 (0.62-0.77) FRS + ECG abnormality for CVD: 0.70 (0.65–0.79) | Likelihood ratio chi square test FRS + ECG abnormality CFID: p=0.004 CVD: p=0.02 | NR
Folsom, 2003^63^ Fair | CHD events^f^ | Total: 954 (6.8) Among 707 women with diabetes: 99 (14.0) Among 6,526 women without diabetes: 211 (3.2) Among 566 men with diabetes: 129 (22.8) Among 4,946 men without diabetes: 515 (10.4) | AUROC Calibration | Basic model Basic + LVH model | AUROC Basic Model Women with diabetes: 0.711 Women without diabetes: 0.777 Men with diabetes: 0.680 Men without diabetes: 0.679 Basic + LVH Model (yes/no) Women with diabetes: 0.709 Women without diabetes: 0.777 Men with diabetes: 0.681 Men without diabetes: 0.679 | NR | NR
Ishikawa, 2015^50^ Fair | Stroke events | Total: 375 (3.5) Cerebral hemorrhages: 85 (0.8) Ischemic strokes: 242 (2.3) Subarachnoid hemorrhages: 47 (0.4) Unknown cause: 1 | NRI IDI | Traditional cardiovascular risk factor model^h^ (model) Model with ECG-LVH without QTc interval Model with ECG-LVH with QTc interval Model without QTc interval (as a continuous variable) Model with QTc interval (as acontinuous variable) Model without ECG-LVH Model with ECG-LVH Model without ECG-LVH or QTc interval Model with ECG-LVH and QTc interval | NR | NR | IDI The model with and without QTc Interval (as a continuous variable) IDI= 0.292, p=0.80 The model with and without ECG-LVH IDI= 0.004, p=0.75 The model with and without ECG-LVH and/or QTc interval IDI=0.006, p=0.63 NRI, Frequency (Percentage) The model with and without QTc Interval (as a continuous variable) Categorical NRI= 0.026, p<0.001 Event NRI 1.35% Nonevent NRI 1.22% Reclassification of subjects with stroke events using the model with QTc interval <2.5% to <2.5%: 41 (91.1) <2.5% to 2.5–5.0%: 2 (3.4) <2.5% to >5.0%: 0 (0.0) Total: 43 2.5–5.0% to <2.5%: 4 (8.9) 2.5–5.0% to 2.5–5.0%: 51 (87.9) 2.5–5.0% to >5.0%: 11 (5.7) Total: 66 >5.0% to <2.5%: 0 (0.0) >5.0% to 2.5–5.0%: 5 (8.6) >5.0% to >5.0%: 183 (94.3) Total: 188
Ishikawa, 2015^50^ Fair (continued) | | | | | | | Reclassification of subjects without stroke events using the model with QTc interval <2.5% to <2.5%: 4,401 (95.5) <2.5% to 2.5–5.0%: 162 (9.2) <2.5% to >5.0%: 2 (0.1) Total: 4,565 2.5–5.0% to <2.5%: 205 (4.5) 2.5–5.0% to 2.5–5.0%: 1,384 (78.2) 2.5–5.0% to >5.0%: 165 (9.3) Total: 1,754 >5.0% to <2.5%: 0 (0.0) >5.0% to 2.5–5.0%: 224 (12.7) >5.0% to >5.0%: 1,613 (90.6) Total: 1,837 The model with and without ECG-LVH Categorical NRI= 0.020, p<0.001 Event NRI 1.01% Nonevent NRI 1.01% Reclassification of subjects with stroke events using the model with ECG-LVH <2.5% to <2.5%: 41 (95.3) <2.5% to 2.5–5.0%: 2 (3.2) <2.5% to >5.0%: 0 (0.0) Total: 43 (14.5) 2.5–5.0% to <2.5%: 2 (4.7) 2.5–5.0% to 2.5–5.0%: 56 (88.9) 2.5–5.0% to >5.0%: 8 (4.2) Total: 66 (22.2)
Ishikawa, 2015^50^ Fair (continued) | | | | | | | >5.0% to <2.5%: 0 (0.0) >5.0% to 2.5–5.0%: 5 (7.9) >5.0% to >5.0%: 183 (95.8) Total: 188 (63.3) Reclassification of subjects without stroke events using the model with ECG-LVH <2.5% to <2.5%: 4,495 (97.6) <2.5% to 2.5-5.0%: 70 (4.0) <2.5% to >5.0%: 0 (0.0) Total: 4,565 (56.0) 2.5–5.0% to <2.5%: 110 (2.4) 2.5–5.0% to 2.5-5.0%: 1,551 (88.3) 2.5–5.0% to >5.0%: 93 (5.2) Total: 1,754 (21.5) >5.0% to <2.5%: 0 (0.0) >5.0% to 2.5-5.0%: 135 (7.7) >5.0% to >5.0%: 1,702 (94.8) Total: 1,837 (22.5) The model with and without ECG-LVH and/or QTc interval Categorical NRI=0.035, p<0.001 Reclassification of subjects with stroke events using the model with ECG-LVH and QTc interval <2.5% to <2.5%: 40 (87.0) <2.5% to 2.5–5.0%: 3 (5.5) <2.5% to >5.0%: 0 (0.0) Total: 43 (14.5) 2.5–5.0% to <2.5%: 6(13.0) 2.5–5.0% to 2.5–5.0%: 44 (80.0) 2.5–5.0% to >5.0%: 16(8.2) Total: 66 (22.2)
Ishikawa, 2015^50^ Fair (continued) | | | | | | | >5.0% to <2.5%: 0 (0.0) >5.0% to 2.5–5.0%: 8 (14.5) >5.0% to >5.0%: 180 (91.8) Total: 188–(63.3) Reclassification of subjects without stroke events using the model withECG-LVH and QTc interval <2.5% to <2.5%: 4403 (94.8) <2.5% to 2.5–5.0%: 157 (9.0) <2.5% to >5.0%: 5 (0.3) Total: 4,565 (56.0) 2.5–5.0% to <2.5%: 242 (5.2) 2.5–5.0% to 2.5–5.0%: 1,316 (75.9) 2.5–5.0% to >5.0%: 196 (11.0) Total: 1,754 (21.5) >5.0% to <2.5%: 0 (0.0) >5.0% to 2.5–5.0%: 262 (15.1) >5.0% to >5.0%: 1,575 (88.7) Total: 1,837 (22.5)
Jorgensen, 2014^52^ Fair | Fatal CVD events Fatal or Nonfatal CVD events (combined) All-cause mortality | Fatal CVD events: 2,236 (32.0) Fatal or nonfatal CVD events: 3,849 (55.0) All-cause mortality: 5,626 (80.5) For sample with ≥10 years follow up (used to calculate discrimination and reclassification outcomes): Fatal CVD events: 837 (17) Fatal or nonfatal CVD events: 2,092 (38.6) All-cause mortality: 2,225 (32.2) | C-statistic Continuous NRI Categorical NRI | Conventional risk factors Conventional risk factors and major/minor ECG changes | Any ECG changes C-Index for Fatal CVD Events Conventional risk factors: 0.705 (0.687-0.723) Conventional risk factors and ECG changes: 0.719 (0.702–0.737) p<0.001 Conventional risk factors and ECG changes with increasing severity: 0.719 (0.702–0.736) p<0.001 C-Index for Fatal or Nonfatal CVD Events Conventional risk factors: 0.651 (0.639-0.663) Conventional riskfactors and ECG changes as present or not: 0.660 (0.648-0.672) p<0.001 Conventional risk factors and ECG changes with increasing severity: 0.660 (0.648–0.671) p<0.001 C-Index for all cause mortality Conventional risk factors: 0.652 (0.640–0.664) | NR | Any ECG changes Continuous NRI for fatal CVD events Conventional risk factors and ECG changes as present or not: 42.3 (34.7–50.0) p<0.001 Conventional risk factors and ECG changes with increasing severity: 42.3(34.7-50.0) p<0.001 Categorical NRI for fatal CVD events Conventional risk factors and ECGchanges as present or not: 7.1 (3.6–10.6) p<0.001 Conventional risk factors and ECG changes with increasing severity: 7.2 (3.7–10.7) p<0.001 Continuous NRI for Fatal or Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 29.1 (23.6–34.7) p<0.001 Conventional risk factors and ECG changes with increasing severity: 29.2 (23.7–34.8) p<0.001 Categorical NRI for Fatal or Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 3.8 (1.4–6.3) p<0.001
Jorgensen, 2014^52^ Fair (continued) | | | | | Conventional risk factors and ECG changes: 0.656 (0.645–0.668) p<0.001 Conventional risk factors and ECG changes with increasing severity: 0.656 (0.645–0.668) p<0.001 C-Index for Fatal CVD Events (From Table 3, model validation) Conventional riskfactors: 0.705 (0.703–0.707) Adjusted foroptimism: 0.706 Conventional riskfactors and ECG changes: 0.719 (0.717–0.721) Adjusted for optimism: 0.720p<0.001 Fatal or Nonfatal CVD Events (From Table 3, validation) Conventional risk factors: 0.651 (0.649–0.653) Adjusted for optimism: 0.652 Conventional risk factors and ECG changes: 0.660 (0.658–0.662) | | Conventional risk factors and ECG changes with increasing severity: 4.2 (1.8–6.7) p<0.001 Continuous NRI for All-Cause Mortality Conventional Rsk Factors and ECG Changes as FVesent or Not: 22.7 (17.5–27.8) p<0.001 Categorical NRI for All-Cause Mortality Conventional Rsk Factors and ECG Changes as Present or Not: 1.9 (0.1–3.6) p<0.001 Conventional Rsk Factors and ECG Changes for Fatal CVD Events (From Table 3, validation) Continuous NRI: 42.3 (42.0–42.4) Adjusted for optimism: 42.3 p<0.001 Categorical NRI: 7.1 (6.7–9.0) Adjusted for optimism: 8.6 p<0.001 Conventional Rsk Factors and ECG Changes for Fatal or Nonfatal CVD Events (From Table 3, validation) Continuous NRI: 29.2 (28.4–29.2)
Jorgensen, 2014^52^ Fair (continued) | | | | | Adjusted for optimism: 0.660 p<0.001 T wave changes C-Index for Fatal CVD Events Conventional risk factors: 0.705 (0.687–0.723) Conventional risk factors and ECG change: 0.716 (0.699–0.734) p<0.001 C-Index for Fatal and Nonfatal CVD Events Conventional risk factors: 0.651 (0.639–0.663) Conventional risk factors and ECG change: 0.658 (0.647–0.670) p<0.001 C-Index for All-Cause Mortality Conventional risk factors: 0.652 (0.640–0.664) Conventional risk factors and ECG change: 0.656 (0.644–0.668) p<0.01 | | Adjusted for optimism: 29.2 p<0.001 Categorical NRI: 4.2 (3.5–5.6) Adjusted for optimism: 4.7p<0.001 T wave changes Continuous NRI for Fatal CVD Events Conventional Risk Factors and ECG Changes as Present or Not: 29.2 (21.5–36.8) p<0.001 Categorical NRI for Fatal CVD Events Conventional Risk Factors and ECG Changes as Present or Not: 5.4 (2.2–8.6) p<0.01 Continuous NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 20.3 (14.7–25.9) p<0.001 Categorical NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 2.7 (0.6–4.8) p<0.05
Jorgensen, 2014^52^ Fair (continued) | | | | | Ventricular conduction delay C-Index for Fatal CVD Events Conventional risk factors: 0.705 (0.687–0.723) Conventional risk factors and ECG change: 0.708 (0.690–0.726) p>0.05 C-Index for Fatal and Nonfatal CVD Events Conventional risk factors: 0.651 (0.639–0.663) Conventional risk factors and ECG change: 0.655 (0.643–0.667) p>0.05 C-Index for All-Cause Mortality Conventional risk factors: 0.652 (0.640–0.664) Conventional risk factors and ECG change: 0.653 (0.642–0.665) p>0.05 LVH C-Index for Fatal CVD Events | | Continuous NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 16.5 (11.4–21.7) p<0.001 Categorical NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 1.3 (-0.3–3.0) p>0.05 Ventricular conduction delay Continuous NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 2.8 (-4.9–10.4) p>0.05 Categorical NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 1.1 (0.1–2.1) p<0.05 Continuous NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 5.5(-0.1–11.1) p>0.05
Jorgensen, 2014^52^ Fair (continued) | | | | | Conventional risk factors: 0.705 (0.687–0.723) Conventional risk factors and ECGchange: 0.706 (0.688–0.724) p>0.05 C-Index for Fatal and Nonfatal CVD Events Conventional risk factors: 0.651 (0.639–0.663) Conventional riskfactors and ECG change: 0.651 (0.639–0.663) p>0.05 C-Index for All-Cause Mortality Conventional risk factors: 0.652 (0.640–0.664) Conventional risk factors and ECG change: 0.653 (0.641–0.665) p>0.05 Q waves C-Index for Fatal CVD Events Conventional risk factors: 0.705 (0.687–0.723) | | Categorical NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 0.0 (-1.1–1.2) p>0.05 Continuous NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 3.2 (-2.0–8.4) p>0.05 Categorical NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 0.2 (-0.5–1.0) p>0.05 LVH Continuous NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 12.1 (4.5–19.8) p<0.01 Categorical NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 2.7 (1.0–4.4) p<0.01
Jorgensen, 2014^52^ Fair (continued) | | | | | Conventional risk factors and ECG change: 0.709 (0.691–0.727) p<0.05 C-Index for Fatal and Nonfatal CVD Events Conventional risk factors: 0.651 (0.639–0.663) Conventional risk factors and ECG change: 0.655 (0.643–0.667) p<0.01 C-Index for All-Cause Mortality Conventional risk factors: 0.652 (0.640–0.664) Conventional risk factors and ECG change: 0.654 (0.643–0.666) p<0.05 ST depressions C-Index for Fatal CVD Events Conventional risk factors: 0.705 (0.687–0.723) Conventional risk factors and ECG change: 0.714 (0.697–0.732) p<0.001 | | Continuous NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 6.7 (1.1–12.3) p<0.05 Categorical NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: -1.1 (-2.3–0.1) p>0.05 Continuous NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 7.0 (1.8–12.1) p<0.01 Categorical NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 0.7 (-0.2–1.7) p>0.05 Q waves Continuous NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 5.3 (-0.02–12.9) p>0.05
Jorgensen, 2014^52^ Fair (continued) | | | | | C-Index for Fatal and Nonfatal CVD Events Conventional risk factors: 0.651 (0.639–0.663) Conventional risk factors and ECG change: 0.660 (0.648–0.672) p<0.001 C-Index for All-Cause Mortality Conventional risk factors: 0.652 (0.640–0.664) Conventional risk factors and ECG change: 0.656 (0.644–0.667) p<0.01 Resting heart Rate C-Index for Fatal CVD Events Conventional risk factors: 0.705 (0.687–0.723) Conventional risk factors and ECG change: 0.709 (0.691–0.727) p<0.001 C-Index for Fatal and Nonfatal CVD Events Conventional risk factors: 0.651 (0.639–0.663) | | Categorical NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 1.9 (0.7–3.1) p<0.01b Continuous NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 3.9 (-1.6–9.5) p>0.05 Categorical NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 0.7 (-0.2–1.8) p>0.05 Continuous NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 4.7 (-0.4–9.9) p>0.05 Categorical NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 0.7 (0.0–1.4) p<0.05
Jorgensen, 2014^52^ Fair (continued) | | | | | Conventional risk factors and ECG change: 0.652 (0.640–0.664) p>0.05 C-Index for All-Cause Mortality Conventional risk factors: 0.652 (0.640–0.664) Conventional risk factors and ECG change: 0.661 (0.649–0.672) p<0.001 | | ST depressions Continuous NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 18.0 (10.4–25.6) p<0.001 Categorical NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 3.1 (0.7–5.4) p<0.01 Continuous NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 14.7 (9.1–20.3) p<0.001 Categorical NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 2.2 (0.4–4.1) p<0.01 Continuous NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 11.1 (6.0–16.3) p<0.001
Jorgensen, 2014^52^ Fair (continued) | | | | | | | Categorical NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 1.5 (0.3–2.8) p<0.01 Resting heart Rate Continuous NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 14.1 (6.4–21.7) p<0.001 Categorical NRI for Fatal CVD Events Conventional risk factors and ECG changes as present or not: 0.9 (-1.8–3.7) p>0.05 Continuous NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: 7.3 (1.8–12.9) p<0.05 Categorical NRI for Fatal and Nonfatal CVD Events Conventional risk factors and ECG changes as present or not: -0.2 (-1.4–1.0) p>0.05 Continuous NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 21.4 (16.2–26.6) p<0.001 Categorical NRI for All-Cause Mortality Conventional risk factors and ECG changes as present or not: 3.7 (1.6–5.7) p<0.001
Shah, 2016^57^ Fair | Primary: CVD death Secondary outcomes: 10-year ischemic heart disease (IHD) death and all cause death | Derivation cohort: CVD death: 574 (15.8) Validation cohort: CVD death: 282 (4.4) Fatal IHD: 166 (2.6) All-cause death: 810 (12.8) | C-statistic IDI Calibration risk score model (only for base models) Reclassification NRI | NHANES ECG risk score model FRS model FRS model + ECG risk equation PCE model PCE model + ECG risk equation | C-statistic (95% CI) NHANES ECG risk score model Fatal IHD: 0.80 (0.77–0.83) Fatal CVD: 0.79 (0.76–0.81) All-cause death:0.75 (0.73–0.77) FRS model Fatal IHD: 0.79 (0.76–0.82) Fatal CVD: 0.76 (0.73–0.78) All-cause death: 0.71 (0.69–0.73) | Hosmer-Lemeshow chi-square values NHANES ECG risk score model IHD Death: 185 CVD Death: 281 Death: 600 FRS model IHD Death: 175 CVD Death: 237 Death: 458 Pooled cohort model (ACC-AHA) IHD Death: 152 CVD Death: 222 Death: 447 | NRI, Total (Event NRI; Nonevent NRI), FRS model Categorical NRI Fatal IHD: 24 (17; 7) Fatal CVD: 25 (12; 13) All-cause death: 30 (11; 19) Continuous NRI Fatal IHD: 57 (22; 35) Fatal CVD: 56 (21; 35) All-cause death: 53 (20; 33) ACC-AHA pooled cohort equation model Categorical NRI Fatal IHD: 14 (9; 5) Fatal CVD: 25 (11; 14) All-cause death: 19 (7; 12)
Shah, 2016^57^ Fair (continued) | | | | FRS variables model FRS variables model + ECG risk equation | FRS model + ECG risk equation Fatal IHD: 0.82 (0.79–0.85) Fatal CVD: 0.80 (0.77–0.82) All-cause death: 0.75 (0.74–0.77) Difference between FRS model and FRS model + ECG risk equation Fatal IHD: 0.03 (0.01–0.05) Fatal CVD: 0.04 (0.02–0.06) All-cause death: 0.04 (0.03–0.05) PCE model Fatal IHD: 0.80 (0.77–0.83) Fatal CVD: 0.76 (0.73–0.78) All-cause death: 0.73 (0.71–0.75) PCE model + ECG risk equation Fatal IHD: 0.82 (0.79–0.84) Fatal CVD: 0.80 (0.78–0.83) All-cause death:0.76 (0.74–0.77) | Calibration statistics for the NHANES ECG risk score for CVD death were adequate with p=0.08 in the derivation cohort and p=0.22 in the validation cohort. | Continuous NRI Fatal IHD: 41 (17; 24) Fatal CVD: 54 (20; 34) All-cause death: 35 (18; 17) Framingham variables model Categorical NRI Fatal IHD: 4 (3; 1) Fatal CVD: 11 (7; 4) All-cause death: 10 (6; 4) Continuous NRI Fatal IHD: 37 (9; 28) Fatal CVD: 35 (7; 28) All-cause death: 33 (8; 25) IDI, % FRS model Absolute IDI Fatal IHD: 1.0 Fatal CVD: 1.6 All-cause death: 2.6 Relative IDI Fatal IHD: 25 Fatal CVD: 35 All-cause death: 38 ACC-AHA pooled cohort equation model Absolute IDI Fatal IHD: 0.7 Fatal CVD: 2.0 All-cause death: 1.9 Relative IDI Fatal IHD: 19 Fatal CVD: 47 All-cause death: 25
Shah, 2016^57^ Fair (continued) | | | | | Difference between PCE model and PCE model + ECG risk equation Fatal IHD: 0.02 (0.01–0.03) Fatal CVD: 0.04 (0.03–0.06) All-cause death: 0.03 (0.02–0.03) 19 FRS variables model Fatal IHD: 0.83 (0.81–0.85) Fatal CVD: 0.81 (0.79–0.84) All-cause death: 0.78 (0.76–0.80) FRS variables model + ECG risk equation Fatal IHD: 0.84 (0.82–0.87) Fatal CVD: 0.82 (0.80–0.85) All-cause death: 0.79 (0.77–0.82) Difference between Framingham variables model and Framingham variables model+ ECG risk equation Fatal IHD: 0.01 (0.01–0.02) Fatal CVD: 0.01 (0.01–0.02) All-cause death: 0.01 (0.01–0.02) | | Framingham variables model Absolute IDI Fatal IHD: 0.2 Fatal CVD: 0.8 All-cause death: 2.0 Relative IDI Fatal IHD: 7 Fatal CVD: 13 All-cause death: 8
Tereshchenko 2014^51^ Fair | Sudden cardiac death | SCD: 311 (2.0) | Reclassification NRI | Modified FRS^i^+DTNFV1 vs. modified FRS | NR | NR | DTNPV discrimination ability NRI estimate=0.028, p=0.06 Event NRI: 0.028 (2.8%) Nonevent NRI: 0.0002 (0.02%) Appropriately reclassified participants with SCD outcome into the higher risk categories: 3.4% appropriately reclassified into a higher risk group,0.3% reclassified into a higher riskgroup inappropriately. Reclassification with addition of DTNPV 1 for those with SCD events <5%, no changed 135 <5% to 5–20%: 3 (2.2%) <5% to ≥20%: 0 Total: 138 5%–20% to <5%:1 (2.6%) 5%–20%, no change: 34 5%–20% to ≥20%: 3 (7.8%) Total: 38 ≥20% to <5%:0 ≥20% to 5-20%: 0 ≥20%, no change: 3 Total: 3 Classification based on modified FRS+ DTNPV 1, Total <5%: 136 5-20%: 37 ≥20%: 6 Total: 179 Reclassification for those without SCD events <5%, no change <5%: 12,298 <5% to 5–20%: 27 (0.22%) <5% to ≥20%: 0 Total: 12,325
Tereshchenko, 2014^51^ Fair (continued) | | | | | | | 5%–20% to <5%:35 (6.6%) 5%–20%, no change: 485 5%–20% to ≥20%: 7 (1.3%) Total: 527 ≥20% to <5%:0 ≥20% to 5–20%: 1 (5.6%) ≥20%, no change: 17 Total: 18 Classification based on modified FRS+ DTNPV1, Total <5%: 12333 5–20%: 513 ≥20%: 24 Total: 12,870

a Adjudicated CHD events including hard CHD Events (acute MI and CHD deaths) and soft CHD events (hospitalization for angina and coronary revascularization).

b FRS variables were age, sex, total and high-density lipoprotein cholesterol, systolic blood pressure, smoking.

c FRS model included age, sex, systolic blood pressure, smoking history, serum cholesterol level, and serum high density lipoprotein level.

d CHD defined as acute MI necessitating overnight hospitalizations, silent MI identified on serial ECGs, or death due to CHD.

e CVD end points included CHD (CHD death and nonfatal MI), coronary artery bypass graft surgery/percutaneous transluminal coronary angioplasty and stroke.

f A CHD event was defined as a validated definite or probable hospitalized myocardial infarction, a definite CHD death, an unrecognized myocardial infarction defined by ARIC ECG readings, or coronary revascularization.

g Model included age, race, total & HDF cholesterol, systolic blood pressure, use of antihypertensive medication, and smoking status

h Model included age, sex, body mass index, current smoking, alcohol intake >20 g/d, systolic blood pressure, antihypertensive medication use, diabetes mellitus, hyperlipidemia, and heart rate.

i Modified FRS in this used the CHD Framingham risk score with age, gender, SBP, DM, HDF and total cholesterol, smoking, and BP-lowering therapy; they note that calculated FRS scores were not directly used due to possible issues of the applicability to different ethnic groups and were adjusted for race

Abbreviations: ACC=American College of Cardiology AHA=American Heart Association; AUC=area under the curve; AUROC=area under the receiver operating characteristic curve; CHD=coronary heart disease; CI=confidence interval; CV=cardiovascular; CVD=cardiovascular disease; CVRF=cardiovascular risk factors; ECG=electrocardiogram; DTNPVI=Deep Terminal Negativity of the P Wave in VI ; FRS=Framingham Risk Score; IDI=integrated discrimination improvement; IHD=ischemic heart disease; KQ=keyquestion; FVH= left ventricular hypertrophy; MI=myocardial infarction; NA=not applicable; NHANES=National Health and Nutrition Examination Survey; NRI=netreclassification improvement; PCE=pooled cohort equation; QTc=corrected QT interval; SCD=sudden cardiac death.

Appendix E Table 3 Number And Percentage Of Execise ECGs With Abnormalities In Studies Included For KQ2

First Author, Year | Sample Size | n (%) with Abnormalities | ECG Findings Evaluated | Source of Patients | Country
Aktas, 2004^59^ | 3,554 | 371 (10.4%) had ischemic ST-segment changes 549 (15.4%) had abnormal based on functional capacity or HR recovery | Exercise ECG according to Bruce (or modified Bruce) protocol; ischemic ST abnormality using a 12-lead, symptom-limited exercise ECG | Consecutive participants presenting for an executive physical, Self-referred. | U.S.
Chang, 2015^45^ | 988 (946 with follow up) | 116/946 (12.3%) with follow up had ischemic exercise ECG; 75% with >8 METs; 22% 5-8 METs; <5 METs | Exercise ECG according to Bruce protocol; stress-induced ischemia identified via ECG during symptom-limited exercise treadmill testing; METs and DTS | People who had both CACS and stress SPECT for clinicallyindicated reasons at the Heart and Vascular Center | U.S.
Cournot, 2006^60^ | 1,051 | 89 (8.5%) had positive exercise test | Symptom-limited exercise ECG | Consecutive asymptomatic people self-referred or referred by PCRs and cardiologists for evaluation of risk factors and routine screening | France
Cournot, 2009^56^ | 2,709 | 163 (6.4%) had positive exercise test | A positive exercise test^9^ during a symptom-limited exercise ECG with orthogonal and V_1_ to V_6_ leads | Apparently healthy asymptomatic people self-referred (20%) orreferred by PCRs (27%) or other providers to a preventive cardiology unit | France
Erikssen, 2004^62^ | Assessment 1 (1972–1975): 2,014 Assessment 2 (1980–1982): 1,428 | 205 (10.2%) positive exercise test 238 (16.7%) positive exercise test | Resting ECG and a symptom-limited bicycle exercise ECG test | Apparently healthy males ages 40–60 years recruited from five governmental agencies who participated in a cardiovascular risk assessment | Norway

Abbreviations: CACS=coronary artery calcium score; DTS=Duke treadmill score; ECG=electrocardiogram; HR=hazard ratio; METs=metabolic equivalents; PCPs=primary care physicians; SPECT =Single Photon Emission Computed Tomography; U.S.=United States.

Appendix E Table 4 Number And Percentage Of Resting ECGs With Abnormalities In Studies Included For KQ2

First Author, Year | Sample Size | n (%) With Abnormalities | ECG Findings Evaluated | Source of Patients | Country
Auer et al, 2012^55^ | 2,192 | 782 (36%) any abnormality 506 (23%) major 276 (13%) minor 1,410 (64%) no abnormality | Major^a^ and minor^b^ 12-lead ECG abnormalities classified using the Minnesota Coding System | Population-based cohort assessing body composition, long-term conditions, and incident mobility limitation in an older adult cohort(1997–1998) | U.S.
Badheka et al, 2013^54^ | 6,025 | 3,291 (54.6%) had any ECG abnormalities | Major and Minor 12-lead ECG abnormalities classified using Minnesota Code^d^ | Population-based survey to collect information on the health and nutrition of U.S. households (1988–1994) | U.S.
Badheka et al, 2013^53^ | 7,928 | 1,919 (24.2%) ST-segment elevation (>8 mV) in aVR; 1,459 (18.4%) T-wave amplitude 0.1 mV or greater in aVR | 12-lead ECG ST-T wave abnormalities in lead aVR classified by the Minnesota Code | Population-based survey to collect information on the health and nutrition of U.S. households (1988–1994) | U.S.
Denes, 2007^58^ | 1,264^c^ | Data only reported for the larger WHI sample of 14,749: 910 (6.2%) major 4,095 (27.8%) minor 9,744 (66.1%) none | Major,^e^ minor,^f^ and incident^g^ 12-lead ECG changes using the Novacode criteria | Population-based study on common causes of morbidity/mortality among postmenopausal women (1993–1998) | U.S.
Folsom, 2003^53^ | 14,054 | NR | LVH using a 12-lead ECG and the Cornell score | Population-based study of 4 U.S. communities (1987–1989) | U.S.
Ishikawa, 2015^50^ | 10,643 | 162 (1.5%) had prolonged QTc intervals | Prolonged corrected QT (QTc) intervals^ii^ and LVH on 12-lead ECG | Government-sponsored screening to clarify the risk factors forcardio/cerebrovascular diseases in the general population (1992–1995) | Japan
Jorgensen, 2014^52^ | 6,991^9^ | 2,140 (30.6%) any ECG abnormalities 1,163 (16.6%) major 353 (5.0%) intermediate 624 (8.9%) minor | Major and Minor 12-lead ECG abnormalities classified using Minnesota Code; also reported outcomes for some single ECG changes^m^ | The Copenhagen City Heart Study (1976–1978) | Denmark
Shah, 2016^57^ | 9,969 (derivation: 3,640, validation: 6,329) | NR (reported mean and SD for the variables in the ECG RiskScore) | ECG Risk Score including frontal T axis, corrected QT interval, T axis, heart rate, age, sex, age* sex interaction term (selected from major^o^ and minor^p^ abnormalities) | Population-based survey to collect information on health and nutrition; NHANES I (1971–1975) and NHANES III (1988–1994) | U.S.
Tereshchenko, 2014^51^ | 15,345^k^ | 167 (1.1%) had the specific DTNPV1 abnormality | Resting 12-lead, P wave morphology (specifically DTNPV1^r^) | Population-based study of 4 U.S. communities (1987–1989) | U.S.

Abbreviations: DTNPVI=Deep T erminal Negativity of the P Wave in VI; ECG=electrocardiogram; LVH=left ventricular hypertrophy; NHANES=National Health and Nutrition Examination Survey; NR=not reported; QTc=corrected QT interval; SD=standard deviation; U.S.=United States; WHI=Women’s Health Initiative.

Appendix E Table 5 Results Of Included Randomized, Controlled Trials Reporting Harms(KQ3)

First Author, Year Trial Name | G1 (N) G2 (N) | Mortality Due to Screening G1 N (%) G2 N (%) HR (95% CI) | Arrhythmia G1 N (%) G2 N (%)HR (95% CI) | CV Events Due to Screening G1 N (%)G2 N (%)HR (95% CI) | Injuries G1 N (%) G2 N (%) HR (95% CI) | Anxiety G1 N (%)G2 N (%) HR (95% CI) | Labeling G1 N (%) G2 N (%) HR (95% CI) | Harms of Subsequent Procedures/Interventions G1 N (%) G2 N (%) HR (95% CI)
Lievre et al, 2011^47^ DYNAMIT | Screened (316) Not screened (315) | NR (all-cause mortality describedin KQ 1) | NR | NR | NR | NR | NR | NR (number of revascularizations reported in KQ 1, but NR whether any resulted in harms; 18 vs. 21)
Turrini et al, 2015^48^ DADDY-D | Screened (262) Not screened (258) | NR (all-cause mortality describedin KQ 1) | NR | NR | NR | NR | NR | 20/262 (7.6%) patients who underwent ETT had a positive result. Of those, 17 underwent coronary angiography. It was positive for critical stenosis in 12/17 (70.6%), and all 12 under went revascularization procedures (7 percutaneous and 5 surgery). One patient having percutaneous revascularization had an acute MI (nonfatal) 3 days after the procedure.

Abbreviations: CI=confidence interval; CV=cardiovascular; DADDY-D=Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients; DYNAMIT=Do You Need to Assess Myocardial Ischemia in Type-2 diabetes; ETT=exercise treadmill test; G=group; HR=hazard ratio; KQ=key question; MI=myocardial infarction; N=samplesize; NR=not reported.