# Appendix D Quality Assessments

Appendix D Table 1 Quality Assessment of Randomized, Controlled Trials (KQs1 and 3): Part 1

First Author, Year Trial Name | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | What was the reported intervention fidelity? | Did the study have crossovers or contamination raising concern for bias? | What was the overall attrition? No. (%) | What was the differential attrition? No. (%) | Did the study have differential attrition or overall high attrition raising concern for bias?
Lievre, 2011^47^ DYNAMIT | Yes | Yes | Yes | NR | NR | 7 (1.1%) mortality 16 (2.5%) primary composite outcome | 16 (1.2) | No
Turrini, 2015^48^ and Turrini, 2009^49^ DADDY-D | Yes | Yes | Yes | 17/20 (85%) with positive exercise test underwent angiography | Yes, 44 (17%) in the no screening group had nonprotocol exercise testing (but unclear if those were indicated because of incident symptoms) | NR | NR | Unclear

Abbreviations: DADDY-D=Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients; DYNAMIT=Do You Need to Assess Myocardial Ischemia in Type-2 diabetes; KQ=key question; No. number; NR=not reported.

Appendix D Table 2 Quality Assessment of Randomized, Controlled Trials(KQs1 and 3): Part 2

First Author, Year Trial Name | Were outcome measurements equal, valid and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did the study use acceptablestatisticalmethods? | Quality Rating | Comments
Lievre, 2011^47^ DYNAMIT | Yes | No | No | Yes | Unclear (3.5 years) | None (complete case analysis) | Yes | Fair | Trial stopped early because of trouble recruiting (randomized 631 of the planned 3,000). Not clear that 3.5 years of follow up is sufficient. Applicability: high risk population of diabetics with 2 risk factors (urinary albumin excretion above a threshold, hypertension, hyperlipidemia, PAD, history of TIA, tobacco consumption, and family history of premature CVD); Table 1 shows 14% with PAD, 4-5% with history of TIA; patients referred to a diabetes specialist in a hospital. Study left subsequent investigations after stress test to judgment of cardiologists (no protocol; pragmatic approach for decisions about e.g., angiography or not, various treatments).
Turrini, 2015^48^ and Turrini, 2009^49^ DADDY-D | Yes | No | No | NR | Unclear (3.6 years) | NR Complete case | Yes | Fair | Study did not reach sample size goal (aimed for 364 per group and got about 260); not clear that 3.6 years of followup is sufficient; amount of missing data NR (flow diagram may indicate no missing data though); masking of outcome assessors NR. Applicability: setting was 2 diabetes outpatient clinics, and participants had to have a normal ECG to get into the study.

Abbreviations: CVD=cardiovascular disease; DADDY-D=Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients; DYNAMIT =Do You Need to Assess Myocardial Ischemia in Type-2 diabetes; ECG=electrocardiogram; KQ=key question; NR=not reported; PAD=peripheral artery disease; TIA=transient ischemic attack.

Appendix D Table 3 Quality Assessment of Randomized, Controlled Trials: Additional Questions for Studies Reporting Harms(KQ 3)

First Author, Year Trial Name | Were harms prespecified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Quality Rating | Comments
Turrini, 2015^48^ and Turrini, 2009^49^ DADDY-D | Yes for post-procedure MI. No for other potential harms. | No | Unclear | Yes | Fair (for MI) but poor for other harms | Study reports that one patient had an MI 3 days after a revascularization procedure and that there were no other harms/events for those who underwent revascularization; limited assessment of harms and no mention of, for example, postintervention hematomas or infections. Other than MI, no methods on how harms were defined or measured, if they were measured at all.

Abbreviations: DADDY-D=Does coronary Atherosclerosis Deserve to be Diagnosed earlY in Diabetic patients; KQ=key question; MI=myocardial infarction.

Appendix D Table 4 Quality Ratings For Studies Reporting Reclassification, Calibration, And Discrimination (KQ 2): Part 1

First Author, Year | Does study sample adequately capture the population of interest (participant eligibility and recruitment)? | Was there selective inclusion of participants in the model based on data availability? | If participants are from a treatment RCT, is treatment accounted for? | Enrolled consecutive patients or a random sample? | Were selection criteria clearly described? | Is a valid and reliable definition and method for measurement of the outcomes reported? | Was the same outcome definition (and method for measurement) used in all patients? | Were the outcomes assessed without knowledge of the candidate predictors (i.e., blinded)? | Is a valid and reliable definition and method for measurement and classification of candidate predictor(s)(ECG and risk factors) reported?
Aktas, 2004^59^ | Yes, no CVD and asymptomatic (but executive physical participants may not be representative) | NR | NA | Yes | Yes | Yes | Yes | NR | Yes
Auer, 2012^55^ | Yes | Yes (but little missing data) | NA | Yes | Yes | Yes | Yes | Yes | Yes
Badheka, 2013^53^ | Somewhat unclear; NHANES III sample; symptoms not assessed; just under 10% with CAD | Yes | NA | Complex, nonrandom, multistage stratified sample design (NHANES III) | Yes | Yes | Yes | Unknown | Yes
Badheka, 2013^54^ | Yes | Yes for discrimination and calibration. No for NRI calculations; those excluded 5% with missing data). | NA | Complex, nonrandom multistage stratified sample design | Yes | Yes | Yes | Unknown | Yes
Chang, 2015^45^ | Uncertain, possibly not, see comments | No (although unclear if the 4% without adequate follow up were included in analyses) | NA | Unknown | No, “clinically indicated reasons” for CACS and stress SPECT not defined except for the 16% with atypical chest pain | Yes | Yes | Yes | Yes for most risk factors and ECG/ETT. No, cholesterol and blood pressure were not available, and conservative values were imputed based on history of hypertension or hyperlipidemia.
Cournot, 2006^60^ | Yes, regarding asymptomatic status, but they were self-referred or referred by PCRs and cardiologists to a preventive cardiology unit | Yes | NA | Yes | Yes | Uncertain (questionnaire or phone call to patients and physicians for initial ascertainment) | Yes | Unknown | Yes
Cournot, 2009^56^ | Yes, regarding asymptomatic status, but they were self-referred (20%) or referred by PCRs (27%) or other providers to a preventive cardiology unit | Yes (but little missing data) | NA | No (referrals and frommedia) | Yes | Uncertain (questionnaire or phone call to patients and physicians) | Yes | Unknown | Yes
Denes, 2007^58^ | Yes (but only females with intactuterus in WHI) | Yes (<10% of the larger sample had measured cholesterol data allowing calculation of FRS) | Yes | No | Yes | Yes for CVD; unclear whether inclusion of silent MI from ECGs within the CHD composite outcome is valid and reliable | Yes | Unknown | Yes
Erikssen, 2004^62^ | Yes | Unknown (full sample, survey 1), yes (survey 2) | NA | Yes | Yes | Yes | Yes | Unknown | Yes
Folsom, 2003^63^ | Yes | Yes | NA | Yes | Yes | Yes | Yes | Unknown | Yes
Ishikawa, 2015^50^ | Yes | Yes | NA | Yes | Yes | Yes | Yes | Unknown | Yes
Jorgensen, 2014^52^ | Yes | Yes | NA | Yes | Yes | Yes | Yes | Unknown | Yes
Shah, 2016^57^ | Probably; NHANES I and III samples; symptoms not assessed, but self-reported CVD excluded | Yes (3,640/4,192 with ECG data for derivation cohort, NFIANES I; 6,329/6,927 with ECG for validation cohort (III) | NA | Complex, nonrandom, multistage, stratified sample (NFIANES I and III) | Yes | Yes | Yes | Unknown | Yes
Strom Moller, 2007^61^ | Population-based, but uncertain how many people with prior ASCVD or symptoms were included | Yes | NA | Yes | Yes | Yes | Yes | Unknown | Yes
Tereshchenko, 2014^51^ | Yes, but uncertain how many had CVD at baseline depending on overlap or lack thereof for those with history of CAD, MI, HF, and stroke (could be as low as 5% or as high as 14%) | Yes | NA | Yes | Yes | Yes | Yes | Unknown | Yes

Abbreviations: ASCVD=arteriosclerotic cardiovascular disease; CACS=coronary artery calcium score; CAD=coronary artery disease; CVD=cardiovascular disease; ECG=electrocardiogram; ETT=exercise treadmill test; FRS=Framingham Risk Score; KQ=key question; HF=heart failure; NA=not applicable; NHANES=National Health andNutrition Examination Survey; NRI=Net reclassification index or improvement; PCP=primary care physician; RCT randomized, controlled trial; SPECT =single-photon emissioncomputed tomography; WHtWomen’s Health Initiative.

Appendix D Table 5 Quality Ratings For Studies Reporting Reclassification, Calibration, And Discrimination (KQ 2): Part 2

First Author, Year | Were predictors assessed blinded for the outcome and for each other (if relevant)? | How was the predictor of interest (ECG) handled in the modeling? | Number of (%) Participants With Missing Data (Include Predictors and Outcomes) | Did the study have high attrition raising concern forbias? | How was missing data handled? | Were multiple measures of performance used (e.g., global fit, discrimination, calibration, net reclassification)? | Were both calibration and discrimination measures reported? Were confidence intervals reported? | Were a priori cut points used for classification measures (e.g., sensitivity, specificity, predictive values, NRI)? | Was a bias-corrected NRI used? This applies only tostudies presenting NRI for a specific risk strata?
Aktas, 2004^59^ | NR | Categorized | NR | NR | NR | No | Discrimination only reported, no CIs | NA | NA
Auer, 2012^55^ | Yes | Categorized | For main analyses, excluded those with missing data on traditional risk factors (n=41, <2%); for secondary analyses of people with follow up ECGs at 4 years, excluded 424 (24%) with missing follow up ECGs | No | Complete-case analysis | Yes | Calibration: p-values Discrimination with CIs | Yes | Yes
Badheka, 2013^51^ | Unknown | Categorized | 62 (<1%) missing mortality (n=4) or ST-T data(n=58) | No | Complete-case analysis (related to ST-T and mortality; some multiple imputation used for other variables) | Yes | Both reported, with CIs only for discrimination (also given for NRI) | Yes | NA
Badheka, 2013^54^ | Unknown | Categorized (ECG abnormalities absent vs. present) | 5% (breakdown NR) | No | Multiple imputation | Yes | Both reported, CI only reported for discrimination | Yes | NA
Chang, 2015^45^ | Yes | Categorized (ETT showing presence or absence of ischemia; i.e., high or low risk) | 4% missing follow up for outcomes; 100% missing cholesterol and blood pressure numbers; NR for other predictors | No, not for lost to follow up (but concern formissing data on some predictors) | Imputation for cholesterol and blood pressure based on history of diagnosis of hypertension or hyperlipidemia; unclear for missing outcome data (likely complete case analysis) | Yes | Both reported, no CIs (p-values given) | Yes | Unknown
Cournot, 2006^60^ | Unknown | Categorized | Lost to follow up n=138 (11%); missing predictors Unknown | No | Complete-case analysis | No | Calibration reported without CIs; discrimination not reported | Cut point used and reported but not a priori (was based on median FRS score) | NA
Cournot, 2009^56^ | Unknown | Categorized | 87 (3.4%) | No | Complete-case analysis | Yes | Both reported, no CIs | Unclear (cut point reported, but unclear if a priori decision) | NA
Denes, 2007^58^ | Unknown | Categorized (normal, minor abnormalities, or major abnormalities) | 91% (breakdown NR) for the only eligible results (Figure 3 and the related text) | Unknown (for the sample of interest to us) | Complete-case analysis | No (only discrimination) | Discrimination only reported, with CIs | NA | NA
Erikssen, 2004^62^ | Unknown | Categorized | Not reported (survey 1); for survey 2 586/2,014 (29%) not included | Not reported | Not reported | No | Calibration reported without CIs (number of predicted and observed events); discrimination not reported | Yes | NA
Folsom, 2003^63^ | Unknown | Categorized | 11% | No | Complete-case analysis | Yes | Both reported, no CIs | Unknown | NA
Ishikawa, 2015^50^ | Yes | Categorized and continuous (both were done in separate models) | Overall <14%; No ECG(n=1,285), Incomplete data (n=5) No followup data (n=84) | No | Complete-case analysis | Yes | Neither reported | Yes | NA
Jorgensen, 2014^52^ | Unknown | Categorized | NR | Unknown | Other (complete-case analysis except that missing HDLs imputed by setting to mean of remaining participants) | Yes | Discrimination only reported, with CIs | No, NRI cut points for risk categories were based on the data | NA
Shah, 2016^57^ | Unknown | Some variables categorized and some continuous | 641 (6%) missing ECG data NR for outcomes | No | Complete-case analysis | Yes | Both reported, with CIs for discrimination only | Yes | NA
Strom Moller, 2007^61^ | Yes for the outcome, NR for each other | Categorized | For the 70-year-old cohort, 1,139/2,239 (51%) had ECGs and were included (1,139/1,681, 68%, of those who had been invited) | Yes | Complete case | No | Discrimination only reported, no CIs (data only for the subgroup who had follow up ECGs at age 70) | NA | NA
Tereshchenko, 2014^51^ | Unknown | Categorized | 2.6% | No | Complete-case analysis | Yes | Neither reported for eligible comparisons | Yes | Unknown

Abbreviations: CI=confidence interval. ECG=electrocardiogram; ETT=exercise treadmilltest; FRS=Framingham Risk Score; HDL=high-density lipoprotein cholesterol; KQ=key question; NA=not applicable; NR=not reported; NRI=net reclassification improvement.

Appendix D Table 6 Quality Ratings For Studies Reporting Reclassification, Calibration, And Discrimination (KQ 2): Part 3

First Author, Year | If net reclassification was assessed, were appropriate clinical thres holds used to reclassify risk? | Method used for testing model performance: development dataset only or separate external validation? | In what way was the population a separate external validation from the FRS or PCE? | Was the FRS or PCE recalibrated in the population before ECG was added to the model? | Quality | Comments
Aktas, 2004^59^ | NA | Developmental dataset only with respect to SCORE + exercise ECG models (for models with SCORE alone, could be considered external validation) | Entirely different population (but NA because did not use FRS or PCS; used SCORE) | NA (did not use FRS or PCS for the parts eligible for our evaluation; used SCORE) | Fair | Provides limited information relevant to our questions (just some discrimination statistics without CIs); masking NR, amount and handling of missing data NR; mean follow up of only 8 years (less than desired for 10-year risk prediction). Population referred for executive physical.
Auer, 2012^55^ | Yes | Developmental dataset only (no split of data) | NA | Yes | Good | Applicability to older patients, ages 70-79 years at baseline; good internal validity but developmental dataset and no validation set; did not use FRS because it has not been validated in adults over age 75, but adjusted for traditional risk factors included in FRS and diabetes; used 7.5% to 15% risk thresholds over 7.5 years (attempting to correspond with 10-20% 10-year risk); mean followup was 6.4years
Badheka, 2013^53^ | Used FRS 5%–20% for intermediate risk category (not 7.5% or 10%) | Developmental dataset | Entirely different population (NFIANES III) | Unknown (but seems that it was not) | Fair | Unclear proportion of population with symptoms; masking not reported; used 5%–20% for intermediate risk category
Badheka, 2013^54^ | Yes | Developmental dataset only (no split of data) | Entirely different population (used NFIANES) | Unknown | Fair
Chang, 2015^45^ | Used <6% vs. 6–20% vs. >20% (not 7.5% or 10%) | Developmental dataset only | Entirely different population (but NA because did not use original FRS coefficients) | Yes (unable to use original FRS coefficients because of missing blood pressure and cholesterol values) | Fair | Moderate concern that the population may have limited applicability to our question; menand women with no history of CAD who had coronary artery calcium and stress SFECT performed for “clinically indicated reasons”; 16.5% with a typical chest pain and unclear howmany had other symptoms; risk of misclassification due to imputing unavailable/missing data for all cholesterol and blood pressure measurements based on priordiagnoses of hypertension and hyperlipidemia (measurements were not available so they calculated FRS using conservative imputations; page 135); did not use current clinical thresholds for reclassification; followup was 6.9 years; this is a derivation study without externalvalidation. Calibration NR, p-values for discrimination.
Cournot, 2006^60^ | NA | Developmental dataset with respect to FRS + exercise ECG models; for models with FRS alone, could be considered external validation of FRS | Entirely different population | No | Fair | Masking of outcome assessors and assessors of relevant exposures NR; uncertain validity of outcome assessment procedures (relied primarily on questionnaire and phone calls forinitial ascertainment); calibration reported, but without CIs, and reclassification and discrimination NR; duration of follow up mean 6 years. Perhaps limited applicability of the selected population that included many referrals.
Cournot, 2009^56^ | NA | Developmental dataset with respect to FRS + exercise ECG models; for models with FRS alone, could be considered external validation of FRS | Entirely different population | No | Fair | Masking of outcome assessors and assessors of relevant exposures NR; uncertain validity of outcome assessment procedures (relied primarily on questionnaire and phone calls for initial ascertainment); some measures of discrimination and calibration reported, but without CIs, and reclassification NR; duration of follow up median 6 years. The relevant models also included femoral bruit in addition to adding exercise ECG. Perhaps limited applicability of the selected population that included manyreferrals
Denes, 2007^58^ | NA | Developmental dataset only (no split of data) | Entirely different population (usedWHI) | No | Fair | High proportion of missing data for the analyses eligible for our questions; less than 10% of the sample was included in the analyses eligible for our questions (due to lack of measured cholesterol information for most participants); complete-case analysis; only reports C-statistic
Erikssen, 2004^62^ | NA | Developmental dataset only | NA | NA | Fair | Masking of outcome assessors NR, lack of multiple measures (calibration only; did not report discrimination or reclassification), missing data NR
Folsom, 2003^63^ | NA | Developmental dataset only | Entirely different population (ARIC) | NA (did not use FRS or PCE) | Fair | Masking NR; developmental set only; unclear if cut points for LVFI were defined a priori; reclassification NR
Ishikawa, 2015^50^ | No, used <2.5%, 2.5-5%, >5% | Development dataset only | NA | NA (did not use FRS or FCE; used model with traditional riskfactors plus heart rate and alcohol use as base model) | Fair | Base model included alcohol use and heart rate in addition to traditional risk factors; unclear why these particular clinical thresholds were chosen (<2.5%, 2.5-5%, >5%). Unknown if predictors were assessed blinded for outcomes; ECG QTc (predictor) determined by hand.
Shah, 2016^57^ | Used 1%, 5%, and 10% based on recommendation by the European Society of Cardiology for lipid management | Developmental dataset (NHANES I) and validation (NHANES III) | Entirely different population | Yes and no (appears that they ran analyses both ways) | Fair | Masking NR; some uncertainty about symptom status of participants
Jorgensen, 2014^52^ | No, used cut points determined by the data (low risk: <8.9%; intermediate risk: 8.9%–14.9; high risk: >14.9%)^a^ | Developmental dataset only | Entirely different population (but NA because did not use FRS or PCE) | NA, used different base model with conventional risk factors | Fair | NRI outpoints for risk categories were based on the data; calibration NR; unknown masking; amount of missing ECG data NR
Strom Moller, 2007^61^ | NA | Developmental dataset | NA | NA | Poor | Very high attrition. Study started at age 50. The only eligible analysis/outcome is the part where they report discrimination (ROC curve) for FRS (traditional risk factors) vs. FRS + ECG indicating ischemia fora subgroup of the cohort who had repeated ECGs (20 years later) at age 70 (n=1,139 of the 2.239, 51%); they had 12-year follow up after age 70. No similar analyses provided for the full cohort of 2,239 participants. Also, unclear selection criteria; unclear what proportion of the population had prior CVD or symptoms at baseline for the 50-year-old initial cohort or for the 70-year-old subgroup.
Tereshchenko, 2014^51^ | Used <5%, 5–<20% and ≥20% (not 10% or 7.5%) | Developmental dataset only | Entirely different population (used ARIC) | Yes (FRSs were not directly used due to possible issues of the applicability to different ethnic groups; the authors adjusted for race) | Fair | Did not report calibration or discrimination for eligible comparison (ECG finding+traditional risk factors vs. traditional risk factors alone); unclear masking; did not use 10% or 7.5% threshold in classifications of risk groups

a Supplement table 2 reported different risk categories for categorical NRI – low risk <23.8%. intermediate 23.8-35%. high >35%

Abbreviations: ARIC=Atherosclerosis Risk in Communities study; CAD=coronary artery disease; CI=confidence interval; CVD=cardiovascular disease; ECG=electrocardiogram; KQ=key question; LVH=left ventricular hypertrophy; NA=not applicable; NHANES=National Health and Nutrition Examination Survey; NR=not reported; PCE=pooled cohort equation; RCT=randomized. controlled trial; ROC=receiver operating characteristic; SCORE=Systematic COronary Risk Evaluation; SPECT =single-photon emission computed tomography; WHI=Women’s Health Initiative.