# Appendix C Excluded Studies

X1: Non-English

X2: Ineligible population

X3: Ineligible/no screening/treatment

X4: Ineligible/no comparison

X5: Ineligible/no outcome

X6: Ineligible setting

X7: Ineligible study design

X8: Appears to meet all criteria but ineligible country

X9: Appears to meet all criteria but abstract only

X10: Poor quality

1 Summaries for patients. Adding electrocardiography to medical history and physical examination for evaluation before sports participation in college athletes. Ann Intern Med. 2010 Mar 2;152(5):I13. doi: 10.7326/0003-4819-152-5-20100302000001. PMID: 20194228. Exclusion Code: X7.20194228
2 Abudiab M, Aijaz B, Konecny T, . Use of functional aerobic capacity based on stress testing to predict outcomes in normal, overweight, and obese patients. Mayo Clin Proc. 2013 Dec;88(12):1427-34. doi: 10.1016/j.mayocp.2013.10.013. PMID: 24290116. Exclusion Code: X2.24290116
3 Acampa W, Petretta M, Evangelista L, . Myocardial perfusion imaging and risk classification for coronary heart disease in diabetic patients. The IDIS study: a prospective, multicentre trial. Eur J Nucl Med Mol Imaging. 2012 Mar;39(3):387-95. doi: 10.1007/s00259-011-1983-x. PMID: 22109666. Exclusion Code: X3.22109666
4 Adabag AS, Grandits GA, Prineas RJ, . Relation of heart rate parameters during exercise test to sudden death and all-cause mortality in asymptomatic men. Am J Cardiol. 2008 May 15;101(10):1437-43. doi: 10.1016/j.amjcard.2008.01.021. PMID: 18471455. Exclusion Code: X5.18471455
5 Agarwal SK, Chao J, Peace F, . Premature ventricular complexes on screening electrocardiogram and risk of ischemic stroke. Stroke. 2015 May;46(5):1365-7. doi: 10.1161/strokeaha.114.008447. PMID: 25873602. Exclusion Code: X5.25873602
6 Agarwal SK, Heiss G, Rautaharju PM, . Premature ventricular complexes and the risk of incident stroke: the Atherosclerosis Risk In Communities (ARIC) Study. Stroke. 2010 Apr;41(4):588-93. doi: 10.1161/strokeaha.109.567800. PMID: 20167922. Exclusion Code: X5.20167922
7 Agarwal SK, Simpson RJ, Jr., Rautaharju P, . Relation of ventricular premature complexes to heart failure (from the Atherosclerosis Risk In Communities [ARIC] Study). Am J Cardiol. 2012 Jan 1;109(1):105-9. doi: 10.1016/j.amjcard.2011.08.009. PMID: 21945138. Exclusion Code: X5.21945138
8 Ahmed HM, Al-Mallah MH, McEvoy JW, . Maximal exercise testing variables and 10-year survival: fitness risk score derivation from the FIT Project. Mayo Clin Proc. 2015 Mar;90(3):346-55. doi: 10.1016/j.mayocp.2014.12.013. PMID: 25744114. Exclusion Code: X2.25744114
9 Ahmed T, Steward JA, O’Mahony MS. Dyspnoea and mortality in older people in the community: a 10-year follow-up. Age Ageing. 2012 Jul;41(4):545-9. doi: 10.1093/ageing/afs049. PMID: 22522776. Exclusion Code: X2.22522776
10 Al Rifai M, Patel J, Hung RK, . Higher Fitness Is Strongly Protective in Patients with Family History of Heart Disease: The FIT Project. Am J Med. 2017 Mar;130(3):367-71. doi: 10.1016/j.amjmed.2016.09.026. PMID: 27751899. Exclusion Code: X4.27751899
11 Al Rifai M, Schneider AL, Alonso A, . sRAGE, in flammation, and risk of atrial fibrillation: results from the Atherosclerosis Risk in Communities (ARIC) Study. J Diabetes Complications. 2015 Mar;29(2):180-5. doi: 10.1016/j.jdiacomp.2014.11.008. PMID: 25499973. Exclusion Code: X3.25499973
12 Aladin AI, Whelton SP, Al-Mallah MH, . Relation of resting heart rate to risk for all-cause mortality by gender after considering exercise capacity (the Henry Ford exercise testing project). Am J Cardiol. 2014 Dec 1;114(11):1701-6. doi: 10.1016/j.amjcard.2014.08.042. PMID: 25439450. Exclusion Code: X2.25439450
13 Albayrak S, Ozhan H, Aslantas Y, . Predictors of major adverse cardiovascular events; results of population based MELEN study with prospective follow-up. Eur Rev Med Pharmacol Sci. 2015 Apr;19(8):1446-51. PMID: 25967720. Exclusion Code: X5.25967720
14 Al-Mallah MH, Keteyian SJ, Brawner CA, . Rationale and design of the Henry Ford Exercise Testing Project (the FIT project). Clin Cardiol. 2014 Aug;37(8):456-61. doi: 10.1002/clc.22302. PMID: 25138770. Exclusion Code: X2.25138770
15 Al-Zaiti SS, Carey MG. The Prevalence of Clinical and Electrocardiographic Risk Factors of Cardiovascular Death Among On-duty Professional Firefighters. J Cardiovasc Nurs. 2015 Sep-Oct;30(5):440-6. doi: 10.1097/jcn.0000000000000165. PMID: 24874885. Exclusion Code: X7.24874885
16 Al-Zaiti SS, Fallavollita JA, Wu YW, . Electrocardiogram-based predictors of clinical outcomes: a meta-analysis of the prognostic value of ventricular repolarization. Heart Lung. 2014 Nov-Dec;43(6):516-26. doi: 10.1016/j.hrtlng.2014.05.004. PMID: 24988910. Exclusion Code: X7.24988910
17 Andersen K, Rasmussen F, Held C, . Exercise capacity and muscle strength and risk of vascular disease and arrhythmia in 1.1 million young Swedish men: cohort study. Bmj. 2015;351:h4543. doi: 10.1136/bmj.h4543. PMID: 26378015. Exclusion Code: X5.26378015
18 Anttila I, Nikus K, Nieminen T, . Prevalence and prognostic value of poor Rwave progression in standard resting electrocardiogram in a general adult population. The Health 2000 Survey. Ann Med. 2010 Mar;42(2):123-30. doi: 10.3109/07853890903555334. PMID: 20166814. Exclusion Code: X5.20166814
19 Arad Y, Goodman KJ, Roth M, . Coronary calcification, coronary disease risk factors, C-reactive protein, and atherosclerotic cardiovascular disease events: the St. Francis Heart Study. J Am Coll Cardiol. 2005 Jul 5;46(1):158-65. doi: 10.1016/j.jacc.2005.02.088. PMID: 15992651. Exclusion Code: X3.15992651
20 Arbel Y, Birati EY, Shapira I, . T-wave amplitude is related to physical fitness status. Ann Noninvasive Electrocardiol. 2012 Jul;17(3):214-8. doi: 10.1111/j.1542474X.2012.00512.x. PMID: 22816540. Exclusion Code: X7.22816540
21 Arms trong AW, Azizi S, Wu J, . Psoriasis, electrocardiographic characteristics, and incidence of atrial fibrillation. Arch Dermatol Res. 2013 Dec;305(10):891-7. doi: 10.1007/s00403013-1419-5. PMID: 24166719. Exclusion Code: X4.24166719
22 Aro AL, Anttonen O, Tikkanen JT, . Intraventricular conduction delay in a standard 12-lead electrocardiogram as a predictor of mortality in the general population. Circ Arrhythm Electrophysiol. 2011 Oct;4(5):704-10. doi: 10.1161/circep.111.963561. PMID: 21841194. Exclusion Code: X5.21841194
23 Aro AL, Anttonen O, Tikkanen JT, . Prevalence and prognostic significance of Twave inversions in right precordial leads of a 12-lead electrocardiogram in the middleaged subjects. Circulation. 2012 May 29;125(21):2572-7. doi: 10.1161/circulationaha.112.098681. PMID: 22576982. Exclusion Code: X4.22576982
24 Aro AL, Huikuri HV. Electrocardiographic predictors of sudden cardiac death from a large Finnish general population cohort. J Electrocardiol. 2013 Sep-Oct;46(5):434-8. doi: 10.1016/j.jelectrocard.2013.06.016. PMID: 23871401. Exclusion Code: X7.23871401
25 Aro AL, Huikuri HV, Tikkanen JT, . QRS-T angle as a predictor of sudden cardiac death in a middle-aged general population. Europace. 2012 Jun;14(6):872-6. doi: 10.1093/europace/eur393. PMID: 22183749. Exclusion Code: X4.22183749
26 Artero EG, Jackson AS, Sui X, . Longitudinal algorithms to estimate cardiorespiratory fitness: associations with nonfatal cardiovascular disease and disease-s pecific mortality. J Am Coll Cardiol. 2014 Jun 3;63(21):2289-96. doi: 10.1016/j.jacc.2014.03.008. PMID: 24703924. Exclusion Code: X3.24703924
27 Asia Pacific Cohort Studies C, Barzi F, Patel A, . Cardiovascular risk prediction tools for populations in Asia. J Epidemiol Community Health. 2007 Feb;61(2):115-21. doi: 10.1136/jech.2005.044842. PMID: 17234869. Exclusion Code: X3.17234869
28 Assmann G, Cullen P, Schulte H. Simple scoring scheme for calculating the risk of acute coronary events based on the 10-year follow-up of the prospective cardiovascular Munster (PROCAM) study. Circulation. 2002 Jan 22;105(3):310-5. PMID: 11804985. Exclusion Code: X3.11804985
29 Assmann G, Schulte H, Cullen P, . Assessing risk of myocardial infarction and stroke: new data from the Prospective Cardiovas cular Munster (PROCAM) study. Eur J Clin Invest. 2007 Dec;37(12):925-32. doi: 10.1111/j.1365-2362.2007.01888.x. PMID: 18036028. Exclusion Code: X3.18036028
30 Assmann G, Schulte H, Seedorf U. Cardiovascular risk assessment in the metabolic syndrome: results from the Prospective Cardiovascular Munster (PROCAM) Study. Int J Obes (Lond). 2008 May;32 Suppl 2:S11-6. doi: 10.1038/ijo.2008.29. PMID: 18469834. Exclusion Code: X3.18469834
31 Bachmann TN, Skov MW, Rasmussen PV, . Electrocardiographic Tpeak-Tend interval and risk of cardiovascular morbidity and mortality: Results from the Copenhagen ECG study. Heart Rhythm. 2016 Apr;13(4):915-24. doi: 10.1016/j.hrthm.2015.12.027. PMID: 26707793. Exclusion Code: X5.26707793
32 Badheka AO, Rathod A, Marzouka GR, . Isolated nonspecific ST-segment and Twave abnormalities in a cross-sectional United States population and Mortality (from NHANES III). Am J Cardiol. 2012 Aug 15;110(4):521-5. doi: 10.1016/j.amjcard.2012.04.023. PMID: 22608358. Exclusion Code: X4.22608358
33 Badheka AO, Singh V, Patel NJ, . QRS duration on electrocardiography and cardiovascular mortality (from the National Health and Nutrition Ex amination SurveyIII). Am J Cardiol. 2013 Sep 1;112(5):671-7. doi: 10.1016/j.amjcard.2013.04.040. PMID: 23726176. Exclusion Code: X2.23726176
34 Bakhoya VN, Kurl S, Laukkanen JA. Twave inversion on electrocardiogram is related to the risk of acute coronary syndrome in the general population. Eur J Prev Cardiol. 2014 Apr;21(4):500-6. doi: 10.1177/2047487312460022. PMID: 22952285. Exclusion Code: X2.22952285
35 Balady GJ, Larson MG, Vasan RS, . Usefulness of exercise testing in the prediction of coronary disease risk among asymptomatic persons as a function of the Framingham risk score. Circulation. 2004 Oct 5;110(14):1920-5. doi: 10.1161/01.CIR.0000143226.40607.71. PMID: 15451778. Exclusion Code: X5.15451778
36 Bandorski D, Bogossian H, Ecke A, . Evaluation of the prognostic value of electrocardiography parameters and heart rhythm in patients with pulmonary hypertension. Cardiol J. 2016;23(4):465-72. doi: 10.5603/CJ.a2016.0044. PMID: 27367480. Exclusion Code: X5.27367480
37 Barmpouletos D, Stavens G, Ahlberg AW, . Duration and type of therapy for diabetes: impact on cardiac risk stratification with stress electrocardiographic-gated SPECT myocardial perfusion imaging. J Nucl Cardiol. 2010 Dec;17(6):1041-9. doi: 10.1007/s12350-010-9293-4. PMID: 20963539. Exclusion Code: X3.20963539
38 Bastuji-Garin S, Deverly A, Moyse D, . The Framingham prediction rule is not valid in a European population of treated hypertensive patients. J Hypertens. 2002 Oct;20(10):1973-80. PMID: 12359975. Exclusion Code: X3.12359975
39 Bates RE, Omer M, Abdelmoneim SS, . Impact of Stress Testing for Coronary Artery Disease Screening in Asymptomatic Patients With Diabetes Mellitus: A Community-Based Study in Olmsted County, Minnesota. Mayo Clin Proc. 2016 Nov;91(11):1535-44. doi: 10.1016/j.mayocp.2016.07.013. PMID: 27720456. Exclusion Code: X4.27720456
40 Bauters C, Lemesle G. Screening for asymptomatic coronary artery disease in patients with diabetes mellitus: A systematic review and meta-analysis of randomized trials. BMC Cardiovasc Disord. 2016 May 10;16:90. doi: 10.1186/s12872-016-0256-9. PMID: 27165687. Exclusion Code: X7.26787044
41 Becker A, Leber A, Becker C, . Predictive value of coronary calcifications for future cardiac events in asymptomatic individuals. Am Heart J. 2008 Jan;155(1):154-60. doi: 10.1016/j.ahj.2007.08.024. PMID: 18082507. Exclusion Code: X3.18082507
42 Becker A, Leber AW, Becker C, . Predictive value of coronary calcifications for future cardiac events in asymptomatic patients with diab et es mellitus: a prospective study in 716 patients over 8 years. BMC Cardiovasc Disord. 2008 Oct 10;8:27. doi: 10.1186/1471-2261-8-27. PMID: 18847481. Exclusion Code: X3.18412949
43 Bem D, Lordkipanidze M, Hodgkinson J, . The Effects of Different A spirin Dosing Frequencies and the Timing of Aspirin Intake in Primary and Secondary Prevention of Cardiovascular Disease: A Systematic Review. Clin Pharmacol Ther. 2016 Nov;100(5):500-12. doi: 10.1002/cpt.438. PMID: 27449968. Exclusion Code: X2.27449968
44 Bernard S, Serusclat A, Targe F, . Incremental predictive value of carotid ultrasonography in the assessment of coronary risk in a cohort of asymptomatic type 2 diabetic subjects. Diabetes Care. 2005 May;28(5):1158-62. PMID: 15855582. Exclusion Code: X3.15855582
45 Berry JD, Lloyd-Jones DM, Garside DB, . Framingham risk score and prediction of coronary heart disease death in young men. Am Heart J. 2007 Jul;154(1):80-6. doi: 10.1016/j.ahj.2007.03.042. PMID: 17584558. Exclusion Code: X3.17584558
46 Berry JD, Willis B, Gupta S, . Lifetime risks for cardiovascular disease mortality by cardiorespiratory fitness levels measured at ages 45, 55, and 65 years in men. The Cooper Center Longitudinal Study. J Am Coll Cardiol. 2011 Apr 12;57(15):1604-10. doi: 10.1016/j.jacc.2010.10.056. PMID: 21474041. Exclusion Code: X5.21474041
47 Bhatia RS, Bouck Z, Ivers NM, . Electrocardiograms in Low-Ris k Patients Undergoing An Annual Health Examination. JAMA Intern Med. 2017 Jul 10doi: 10.1001/jamainternmed.2017.2649. PMID: 28692719. Exclusion Code: X5.28692719
48 Bhopal R, Fischbacher C, Vartiainen E, . Predicted and observed cardiovascular disease in South Asians: application of FINRISK, Framingham and SCORE models to Newcastle Heart Project data. J Public Health (Oxf). 2005 Mar;27(1):93-100. doi: 10.1093/pubmed/fdh202. PMID: 15749725. Exclusion Code: X3.15749725
49 Bianco HT, Izar MC, Fonseca HA, . Relevance of target-organlesions as predictors of mortality in patients with diabetes mellitus. Arq Bras Cardiol. 2014 Oct;103(4):272-81. PMID: 25098376. Exclusion Code: X5.25098376
50 Binici Z, Intzilakis T, Niels en OW, . Excessive supraventricular ectopic activity and increased risk of atrial fibrillation and stroke. Circulation. 2010 May 4;121(17):1904-11. doi: 10.1161/circulationaha.109.874982. PMID: 20404258. Exclusion Code: X3.20404258
51 Binici Z, Mouridsen MR, Kober L, . Decreased nighttime heart rate variability is associated with increased stroke risk. Stroke. 2011 Nov;42(11):3196-201. doi: 10.1161/strokeaha.110.607697. PMID: 21921280. Exclusion Code: X3.21921280
52 Blair SN, Kampert JB, Kohl HW, 3rd, . Influences of cardiorespiratory fitness and other precursors on cardiovascular disease and all-cause mortality in men and women. JAMA. 1996 Jul 17;276(3):205-10. PMID: 8667564. Exclusion Code: X5.8667564
53 Bodegard J, Erikssen G, Bjornholt JV, . Symptom-limited exercise testing, ST depressions and long-term coronary heart disease mortality in apparently healthy middle-aged men. Eur J Cardiovasc Prev Rehabil. 2004 Aug;11(4):320-7. PMID: 15292766. Exclusion Code: X5.15292766
54 Boman K, Gerdts E, Wachtell K, . Exercise and cardiovascular outcomes in hypertensive patients in relation to structure and function of left ventricular hypertrophy: the LIFE study. Eur J Cardiovasc Prev Rehabil. 2009 Apr;16(2):242-8. doi: 10.1097/HJR.0b013e328329560e. PMID: 19369828. Exclusion Code: X2.19369828
55 Bouzas-Mosquera A, Peteiro J, AlvarezGarcia N, . Prediction of mortality and major cardiac events by exercise echocardiography in patients with normal exercise electrocardiographic testing. J Am Coll Cardiol. 2009 May 26;53(21):1981-90. doi: 10.1016/j.jacc.2009.01.067. PMID: 19460612. Exclusion Code: X2.19460612
56 Brindle P, Emberson J, Lampe F, . Predictive accuracy of the Framingham coronary risk score in British men: prospective cohort stud y. BMJ. 2003 Nov 29;327(7426):1267. doi: 10.1136/bmj.327.7426.1267. PMID: 14644971. Exclusion Code: X3.14644971
57 Brindle PM, McConnachie A, Upton MN, . The accuracy of the Framingham riskscore in different socioeconomic groups: a prospective study. Br J Gen Pract. 2005 Nov;55(520):838-45. PMID: 16281999. Exclusion Code: X3.16281999
58 Brown DW, Giles W H, Croft JB. Left ventricular hypertrophy as a predictor of coronary heart disease mortality and the effect of hypertension. Am Heart J. 2000 Dec;140(6):848-56. doi: 10.1067/mhj.2000.111112. PMID: 11099987. Exclusion Code: X5.11099987
59 Buonacera A, Boukhris M, Tomasello SD, . Impact of left ventricular remodeling and renal function on 24h-ECG recordings and cardiovascular outcome in elderly hypertensive patients. Eur J Intern Med. 2016 Apr;29:71-7. doi: 10.1016/j.ejim.2016.01.001. PMID: 26781517. Exclusion Code: X2.26781517
60 Buyken AE, von Eckardstein A, Schulte H, . Type 2 diabetes mellitus and risk of coronary heart disease: results of the 10-year follow-up of the PROCAM study. Eur J Cardiovasc Prev Rehabil. 2007 Apr;14(2):230-6. doi: 10.1097/HJR.0b013e3280142037. PMID: 17446801. Exclusion Code: X4.17446801
61 Camhi SM, Katzmarzyk PT, Broyles S, . Association of metabolic risk with longitudinal physical activity and fitness: coronary artery risk development in young adults (CARDIA). Metab Syndr Relat Disord. 2013 Jun;11(3):195-204. doi: 10.1089/met.2012.0120. PMID: 23438155. Exclusion Code: X3.23438155
62 Cardoso CR, Leite NC, Salles GF. Factors as sociated with abnormal T-wave axis and increased QRS-T angle in type 2 diabetes. Acta Diabetol. 2013 Dec;50(6):919-25. doi: 10.1007/s00592-013-0483-9. PMID: 23744129. Exclusion Code: X2.23744129
63 Carlson N, Dixen U, Marott JL, . Predictive value of casual ECG-based resting heart rate compared with resting heart rate obtained from Holter recording. Scand J Clin Lab Invest. 2014 Mar;74(2):163-9. doi: 10.3109/00365513.2013.867531. PMID: 24329133. Ex clusion Code: X2.24329133
64 Carrington MJ, Jennings GL, Clark RA, . Assessing cardiovascular risk in regional areas: the Healthy Hearts Beyond City Limits program. BMC Health Serv Res. 2012;12:296. doi: 10.1186/1472-6963-12296. PMID: 22943553. Exclusion Code: X2.22943553
65 Cederholm J, Eeg-Olofsson K, Eliasson B, . Risk prediction of cardiovascular disease in type 2 diabetes: a risk equation from the Swedish National Diabetes Register. Diabetes Care. 2008 Oct;31(10):2038-43. doi: 10.2337/dc080662. PMID: 18591403. Exclusion Code: X3.18591403
66 Chambless LE, Heiss G, Shahar E, . Prediction of ischemic stroke risk in the Atherosclerosis Risk in Communities Study. Am J Epidemiol. 2004 Aug 1;160(3):259-69. doi: 10.1093/aje/kwh189. PMID: 15257999. Exclusion Code: X4.15257999
67 Ch an A K, Ilias-Khan NA, Xian H, . Arm exercise stress perfusion imaging predicts clinical outcome. J Appl Physiol (1985). 2011 Dec;111(6):1546-53. doi: 10.1152/japplphysiol.00725.2011. PMID: 21852405. Exclusion Code: X2.21852405
68 Chauhan K, Ackerman MJ, Crows on CS, . Population-based study of QT interval prolongation in patients with rheumatoid arthritis. Clin Exp Rheumatol. 2015 JanFeb;33(1):84-9. PMID: 25572282. Exclusion Code: X5.25572282
69 Cheng S, Keyes MJ, Larson MG, . Long-termoutcomes in individuals with prolonged PR interval or first-degree atrioventricular block. Jama. 2009 Jun 24;301(24):2571-7. doi: 10.1001/jama.2009.888. PMID: 19549974. Exclusion Code: X5.19549974
70 Cheng S, Larson MG, Keyes MJ, . Relation of QRS width in healthy persons to risk of future permanent pacemaker implantation. Am J Cardiol. 2010 Sep 1;106(5):668-72. doi: 10.1016/j.amjcard.2010.04.021. PMID: 20723643. Exclusion Code: X5.20723643
71 Cheriyath P, He F, Peters I, . Relation of atrial and/or ventricular premature complexes on a two-minute rhythm strip to the risk of sudden cardiac death (the Atherosclerosis Risk in Communities [ARIC] study). Am J Cardiol. 2011 Jan 15;107(2):151-5. doi: 10.1016/j.amjcard.2010.09.002. PMID: 21211594. Exclusion Code: X5.21211594
72 Chisalita SI, Dahlstrom U, Arnqvist HJ, . Proinsulin and IGFBP-1 predicts mortality in an elderly population. Int J Cardiol. 2014 Jun 15;174(2):260-7. doi: 10.1016/j.ijcard.2014.03.171. PMID: 24794551. Exclusion Code: X3.24794551
73 Chou R, Arora B, Dana T, . Screening asymptomatic adults with resting or exercise electrocardiography: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2011 Sep 20;155(6):375-85. doi: 10.7326/0003-4819155-6-201109200-00006. PMID: 21930855. Exclusion Code: X7.21930855
74 Cicero AF, Rosticci M, Tocci G, . Serumuric acid and other short-term predictors of electrocardiographic alterations in the Brisighella Heart Study cohort. Eur J Intern Med. 2015 May;26(4):255-8. doi: 10.1016/j.ejim.2015.02.007. PMID: 25708168. Exclusion Code: X5.25708168
75 Cilli A, Batmaz F, Demir I, . The diagnostic yield of exercise stress testing as a screening tool for subclinical coronary artery disease in patients with moderate to severe obstructive sleep apnea. J Clin Sleep Med. 2011 Feb 15;7(1):25-9. PMID: 21344047. Exclu s io n Co d e: X7.21344047
76 Cintra FD, Tufik S, Paola A, . Cardiovascular profile in patients with obstructive sleep apnea. Arq Bras Cardiol. 2011 Apr;96(4):293-9. PMID: 21437515. Exclusion Code: X5.21437515
77 Cirillo M, Terradura-Vagnarelli O, Mancini M, . Cohort profile: The Gubbio Population Study. Int J Epidemiol. 2014 Jun;43(3):713-20. doi: 10.1093/ije/dyt025. PMID: 23543599. Exclusion Code: X5.23543599
78 Cole CR, Foody JM, Blackstone EH, . Heart rate recovery after submaximal exercise testing as a predictor of mortality in a cardiovascularly healthy cohort. Ann Intern Med. 2000 Apr 4;132(7):552-5. PMID: 10744592. Exclusion Code: X4.10744592
79 Conen D, Schon T, Aeschbacher S, . Genetic and phenotypic determinants of blood pressure and other cardiovascular risk factors (GAPP). Swiss Med Wkly. 2013;143:w13728. doi: 10.4414/smw.2013.13728. PMID: 23299990. Exclusion Code: X3.23299990
80 Cook NR, Buring JE, Ridker PM. The effect of including C-reactive protein in cardiovascular risk prediction models for women. Ann Intern Med. 2006 Jul 4;145(1):21-9. PMID: 16818925. Exclusion Code: X3.16818925
81 Cooper JA, Miller GJ, Humphries SE. A comparison of the PROCAM and Framingham point-scoring systems for estimation of individual risk of coronary heart disease in the Second Northwick Park Heart Study. Atherosclerosis. 2005 Jul;181(1):93-100. doi: 10.1016/j.atherosclerosis.2004.12.026. PMID: 15939059. Exclusion Code: X3.15939059
82 Courand PY, Jenck S, Bricca G, . R wave in a VL lead: an outstanding ECG index in hypertension. J Hypertens. 2014 Jun;32(6):1317-25. doi: 10.1097/hjh.0000000000000181. PMID: 24751594. Exclusion Code: X4.24751594
83 Crow RS, Hannan PJ, Folsom AR. Prognostic significance of corrected QT and corrected JT interval for incident coronary heart disease in a general population sample stratified by presence or absence of wide QRS complex: the ARIC Study with 13 years of follow-up. Circulation. 2003 Oct 21;108(16):1985-9. doi: 10.1161/01.CIR.0000095027.28753.9D. PMID: 14517173. Exclusion Code: X5.14517173
84 Cuddy TE, Tate RB. Sudden unex pected cardiac death as a function of time since the detection of electrocardiographic and clinical risk factors in apparently healthy men: the Manitoba Follow-Up Study, 1948 to 2004. Can J Cardiol. 2006 Mar 1;22(3):205-11. PMID: 16520850. Exclusion Code: X5.16520850
85 D’Agostino RB, Sr., Grundy S, Sullivan LM, . Validation of the Framingham coronary heart disease prediction scores: results of a multiple ethnic groups investigation. JAMA. 2001 Jul 11;286(2):180-7. PMID: 11448281. Exclusion Code: X3.11448281
86 D’Agostino RB, Sr., Vasan RS, Pencina MJ, . General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008 Feb 12;117(6):743-53. doi: 10.1161/CIRCULATIONAHA.107.699579. PMID: 18212285. Exclusion Code: X3.18212285
87 Danzi G, Giordano A, Biondi-Zoccai G, . [The DANAMI-3-PRIMULTI study]. Giornale italiano di cardiologia (2006); 2016. p. 171-5. Exclusion Code: X1.27029873
88 Darabont R, Tautu OF, Pop D, . Visitto-Vis it Blood Pressure Variability and Arterial Stiffness Independently Predict Cardiovascular Risk Category in a General Population: Results from the SEPHAR II Study. Hellenic J Cardiol. 2015 MayJun;56(3):208-16. PMID: 26021242. Exclusion Code: X3.26021242
89 Daugherty SL, Magid DJ, Kikla JR, . Gender differences in the prognostic value of exercise treadmill test characteristics. Am Heart J. 2011 May;161(5):908-14. doi: 10.1016/j.ahj.2011.01.021. PMID: 21570521. Exclusion Code: X2.21570521
90 Daviglus ML, Liao Y, Greenland P, . Association of nonspecific minorST-T abnormalities with cardio vascular mortality: the Chicago Western Electric Study. JAMA. 1999 Feb 10;281(6):530-6. PMID: 10022109. Exclusion Code: X5.10022109
91 De Bacquer D, De Backer G, Kornitzer M, . Prognostic value of ECG findings for total, cardiovascular disease, and coronary heart disease death in men and women. Heart. 1998 Dec;80(6):570-7. PMID: 10065025. Exclusion Code: X5.10065025
92 de Groot JR, Krul SP, Kroon S, . Unidentified candidates for cardiac resynchronization therapy: guideline adherence in a large academic outpatient clinic in the Netherlands. Pacing Clin Electrophysiol. 2013 Jan;36(1):69-75. doi: 10.1111/pace.12021. PMID: 23078171. Exclusion Code: X2.23078171
93 de L, II, Verhagen HJ, Stolker RJ, . The value of treadmill exercise test parameters together in patients with known or suspected peripheral arterial disease. Eur J Prev Cardiol. 2012 Apr;19(2):192-8. doi: 10.1177/1741826711399986. PMID: 21450584. Exclusion Code: X2.21450584
94 de Lemos JA, Ayers CR, Levine B, . Multimodality Strategy for Cardiovascular Risk Assessment: Performance in 2 Population-Based Cohorts. Circulation. 2017 May 30;135(22):2119-32. doi: 10.1161/CIRCULATIONAHA.117.027272. PMID: 28360032. Exclusion Code: X4.28360032
95 de Ruijter W, Westendorp RG, Assendelft WJ, . Use of Framingham risk score and new biomarkers to predict cardiovascular mortality in older people: population based observational cohort study. BMJ. 2009 Jan 08;338:a3083. doi: 10.1136/bmj.a3083. PMID: 19131384. Exclusion Code: X3.19131384
96 DeFina L, Radford N, Leonard D, . Cardiores piratory fitness and coronary artery calcification in women. Atherosclerosis. 2014 Apr;233(2):648-53. doi: 10.1016/j.atherosclerosis.2014.01.016. PMID: 24561492. Exclusion Code: X7.24561492
97 Denes P, Garside DB, Lloyd-Jones D, . Major and minor electrocardiographic abnormalities and their as sociation with underlying cardiovascular disease and risk factors in Hispanics/Latinos (from the Hispanic Community Health Study/Study of Latinos). Am J Cardiol. 2013 Nov 15;112(10):1667-75. doi: 10.1016/j.amjcard.2013.08.004. PMID: 24055066. Exclusion Code: X4.24055066
98 Detrano RC, Wong ND, Doherty TM, . Coronary calcium does not accurately predict near-term future coronary events in high-risk adults. Circulation. 1999 May 25;99(20):2633-8. PMID: 10338455. Exclusion Code: X3.10338455
99 Dhingra R, Pencina MJ, Wang TJ, . Electrocardiographic QRS duration and the risk of congestive heart failure: the Framingham Heart Study. Hypertension. 2006 May;47(5):861-7. doi: 10.1161/01.HYP.0000217141.20163.23. PMID: 16585411. Exclusion Code: X5.16585411
100 Dhoble A, Lahr BD, Allison TG, . Predicting long-term cardiovascular risk using the mayo clinic cardiovascular risk score in a referral population. Am J Cardiol. 2014 Sep 1;114(5):704-10. doi: 10.1016/j.amjcard.2014.05.061. PMID: 25052544. Exclusion Code: X2.25052544
101 Dhoble A, Lahr BD, Allison TG, . Cardiopulmonary fitness and heart rate recovery as predictors of mortality in a referral population. J Am Heart Assoc. 2014;3(2):e000559. doi: 10.1161/jaha.113.000559. PMID: 24663334. Exclusion Code: X7.24663334
102 Diercks GF, Hillege HL, van Boven AJ, . Microalbuminuria modifies the mortality risk associated with electrocardiographic ST-T segment changes. J Am Coll Cardiol. 2002 Oct 16;40(8):1401. PMID: 12392828. Exclusion Code: X5.12392828
103 Donnan PT, Donnelly L, New JP, . Derivation and validation of a prediction score for major coronary heart disease events in a U.K. type 2 diabetic population. Diabetes Care. 2006 Jun;29(6):1231-6. doi: 10.2337/dc05-1911. PMID: 16732001. Exclusion Code: X3.16732001
104 Ducloux D, Kazory A, Chalopin JM. Predicting coronary heart disease in renal transplant recipients: aprospective study. Kidney Int. 2004 Jul;66(1):441-7. doi: 10.1111/j.1523-1755.2004.00751.x. PMID: 15200454. Exclusion Code: X2.15200454
105 Dunder K, Lind L, Zethelius B, . Evaluation of a scoring scheme, including proinsulin and the apolipoprotein B/apolipoprotein A1 ratio, for the risk of acute coronary events in middle-aged men: Uppsala Longitudinal Study of Adult Men (ULSAM). Am Heart J. 2004 Oct;148(4):596-601. doi: 10.1016/j.ahj.2004.03.021. PMID: 15459588. Exclusion Code: X3.15459588
106 Dyakova M, Shantikumar S, Colquitt Jill L, . Systematic versus opportunistic risk assessment for the primary prevention of cardiovascular disease. Cochrane Database of Systematic Reviews. 2016(1)doi: 10.1002/14651858.CD010411.pub2. PMID: CD010411. Exclusion Code: X7.
107 Ekelund LG, Suchindran CM, McMahon RP, . Coronary heart disease morbidity and mortality in hypercholesterolemic men predicted from an exercise test: the Lipid Research Clinics Coronary Primary Prevention Trial. J Am Coll Cardiol. 1989 Sep;14(3):556-63. PMID: 2768706. Exclusion Code: X4.2768706
108 Elkeles RS, Godsland IF, Feher MD, . Coronary calcium measurement improves prediction of cardiovascular events in asymptomatic patients with type 2 diabetes: the PREDICT study. Eur Heart J. 2008 Sep;29(18):2244-51. doi: 10.1093/eurheartj/ehn279. PMID: 18573867. Exclusion Code: X3.18573867
109 Elsharawy MA, Al-Elq AH, Alkhadra AH, . Screening for asymptomatic cardiovascular disease in Arab patients with diabetes. Int An giol. 2011 Feb;30(1):52-7. PMID: 21248673. Exclusion Code: X4.21248673
110 Empana JP, Ducimetiere P, Arveiler D, . Are the Framingham and PROCAM coronary heart disease risk functions applicable to different European populations? The PRIME Study. Eur Heart J. 2003 Nov;24(21):1903-11. PMID: 14585248. Exclusion Code: X3.14585248
111 Engeseth K, Hodnesdal C, Grundvold I, . Heart rate reserve predicts cardiovascular death among physically unfit but otherwise healthy middle-aged men: a 35-year follow-up study. Eur J Prev Cardiol. 2016 Jan;23(1):59-66. doi: 10.1177/2047487314553202. PMID: 25281482. Exclusion Code: X5.25281482
112 Eranti A, Aro AL, Kerola T, . Prevalence and prognostic significance of abnormal P terminal force in lead V1 of the ECG in the general population. Circ Arrhythm Electrophysiol. 2014 Dec;7(6):1116-21. doi: 10.1161/circep.114.001557. PMID: 25381332. Exclusion Code: X4.25381332
113 Erdem A, Uenishi M, Kucukdurmaz Z, . The effect of metabolic syndrome on heart rate turbulence in non-diabetic patients. Cardiol J. 2012;19(5):507-12. PMID: 23042315. Exclusion Code: X5.23042315
114 Erez A, Kivity S, Berkovitch A, . The association between cardiorespiratory fitness and cardiovascular risk may be modulated by known cardiovascular risk factors. Am Heart J. 2015 Jun;169(6):916-23.e1. doi: 10.1016/j.ahj.2015.02.023. PMID: 26027631. Exclusion Code: X5.26027631
115 Eriksen BO, Lochen ML, Arntzen KA, . Subclinical cardiovascular disease is associated with a high glomerular filtration rate in the nondiabetic general population. Kidney Int. 2014 Jul;86(1):146-53. doi: 10.1038/ki.2013.470. PMID: 24304885. Exclusion Code: X5.24304885
116 Erikssen G, Liestol K, Gullestad L, . The terminal part of the QT interval (T peak to T end): a predictor of mortality after acute myocardial infarction. Ann Noninvasive Electrocardiol. 2012 Apr;17(2):85-94. doi: 10.1111/j.1542-474X.2012.00493.x. PMID: 22537325. Exclusion Code: X2.22537325
117 Estes EH, Zhang ZM, Li Y, . The Romhilt-Estes left ventricular hypertrophy score and its components predict all-cause mortality in the general population. Am Heart J. 2015 Jul;170(1):104-9. doi: 10.1016/j.ahj.2015.04.004. PMID: 26093870. Exclusion Code: X5.26093870
118 Fagher K, Nilsson A, Londahl M. Heart rate-corrected QT interval prolongation as a prognostic marker for 3-year survival in people with Type 2 diabetes undergoing above-ankle amputation. Diabet Med. 2015 May;32(5):679-85. doi: 10.1111/dme.12632. PMID: 25388827. Exclusion Code: X5.25388827
119 Faramawi MF, Caffrey JL, Amanzadeh J, . Cystatin Cestimated renal dysfunction predicts T wave axis deviation in US adults: results from NHANES III. Eur J Epidemiol. 2011 Feb;26(2):101-7. doi: 10.1007/s10654010-9534-5. PMID: 21184143. Exclusion Code: X2.21184143
120 Farrell SW, Finley CE, Haskell WL, . Is There a Gradient of Mortality Risk among Men with Low Cardiorespiratory Fitness? Med Sci Sports Exerc. 2015 Sep;47(9):1825-32. doi: 10.1249/mss.0000000000000608. PMID: 25551401. Exclusion Code: X5.25551401
121 Farrell SW, Finley CE, McAuley PA, . Cardiores piratory fitness, different meas ures of adiposity, and total cancer mortality in women. Obesity (Silver Spring). 2011 Nov;19(11):2261-7. doi: 10.1038/oby.2010.345. PMID: 21293448. Exclusion Code: X5.21293448
122 Farrell SW, Finley CE, Radford NB, . Cardiorespiratory fitness, body mass index, and heart failure mortality in men: Cooper Center Longitudinal Study. Circ Heart Fail. 2013 Sep 1;6(5):898-905. doi: 10.1161/circheartfailure.112.000088. PMID: 23873472. Exclusion Code: X4.23873472
123 Fat emi O, Yuriditsky E, Tsioufis C, . Impact of intensive glycemic control on the incidence of atrial fibrillation and associated cardiovascular outcomes in patients with type 2 diabetes mellitus (from the Action to Control Cardiovascular Risk in Diabetes Study). Am J Cardiol. 2014 Oct 15;114(8):1217-22. doi: 10.1016/j.amjcard.2014.07.045. PMID: 25159234. Exclusion Code: X3.25159234
124 Ferrario M, Chiodini P, Chambless LE, . Prediction of coronary events in a low incidence population. Assessing accuracy of the CUORE Cohort Study prediction equation. Int J Epidemiol. 2005 Apr;34(2):413-21. doi: 10.1093/ije/dyh405. PMID: 15659467. Exclusion Code: X3.15659467
125 Ferrie JE, Singh-Manoux A, Kivimaki M, . Cardiorespiratory risk factors as predictors of 40-year mortality in women and men. Heart. 2009 Aug;95(15):1250-7. doi: 10.1136/hrt.2008.164251. PMID: 19389720. Exclusion Code: X5.19389720
126 Fitzmaurice DA, McCahon D, Baker J, . Is screening for AF worthwhile? Stroke risk in a screened population from the SAFE study. Fam Pract. 2014 Jun;31(3):298-302. doi: 10.1093/fampra/cmu011. PMID: 24728774. Exclusion Code: X4.24728774
127 Fleg JL, Gerstenblith G, Zonderman AB, . Prevalence and prognostic significance of exercise-induced silent my ocardial is chemia detected by thallium scintigraphy and electrocardiography in asymptomatic volunteers. Circulation. 1990 Feb;81(2):428-36. PMID: 2297853. Exclusion Code: X4.2297853
128 Floyd JS, Sitlani CM, Wiggins KL, . Variation in resting heart rate over 4 years and the risks of myocardial infarction and death among older adults. Heart. 2015 Jan;101(2):132-8. doi: 10.1136/heartjnl2014-306046. PMID: 25214500. Exclusion Code: X5.25214500
129 Fuchs T, Torjman A, Galitzkaya L, . The clinical significance of ventricular arrhythmias during an ex ercise test in non-competitive and competitive athletes. Isr Med Assoc J. 2011 Dec;13(12):735-9. PMID: 22332442. Exclusion Code: X5.22332442
130 Fyfe-Johnson AL, Muller CJ, Alonso A, . Heart Rate Variability and Incident Stroke: The Atherosclerosis Riskin Communities Study. Stroke. 2016 Jun;47(6):1452-8. doi: 10.1161/strokeaha.116.012662. PMID: 27217501. Exclusion Code: X5.27217501
131 Garcia MN, Murray KO, Hotez PJ, . Development of chagas cardiac manifestations among Tex as blood donors. Am J Cardiol. 2015 Jan 1;115(1):113-7. doi: 10.1016/j.amjcard.2014.09.050. PMID: 25456877. Exclusion Code: X7.25456877
132 Gaziano TA, Young CR, Fitzmaurice G, . Laboratory-based versus non-laboratorybased method for assessment of cardiovascular disease risk: the NHANESI Follow-up Study cohort. Lancet. 2008 Mar 15;371(9616):923-31. doi: 10.1016/S01406736(08)60418-3. PMID: 18342687. Exclusion Code: X3.18342687
133 Gencer B, Butler J, Bauer DC, . Association of electrocardiogram abnormalities and incident heart failure events. Am Heart J. 2014 Jun;167(6):869-75.e3. doi: 10.1016/j.ahj.2014.03.020. PMID: 24890537. Exclusion Code: X4.24890537
134 Georgoulias P, Demakopoulos N, Valotassiou V, . Long-term prognostic value of heart-rate recovery after treadmill testing in patients with diabetes mellitus. Int J Cardiol. 2009 May 1;134(1):67-74. doi: 10.1016/j.ijcard.2008.01.036. PMID: 18499284. Exclusion Code: X3.18499284
135 Ghaffari S, Kazemi B, Aliakbarzadeh P. Abnormal heart rate recovery after exercise predicts coronary artery disease severity. Cardiol J. 2011;18(1):47-54. PMID: 21305485. Exclusion Code: X7.21305485
136 Giagnoni E, Secchi MB, Wu SC, . Prognostic value of exercise EKG testing in asymptomatic normotensive subjects. A prospective matched study. N Engl J Med. 1983 Nov 3;309(18):1085-9. doi: 10.1056/NEJM198311033091803. PMID: 6621650. Exclusion Code: X5.6621650
137 Giustetto C, Drago S, Demarchi PG, . Risk stratification of the patients with Brugada type electrocardiogram: a community-based prospective study. Europace. 2009 Apr;11(4):507-13. doi: 10.1093/europace/eup006. PMID: 19193676. Exclusion Code: X2.19193676
138 Gordon DJ, Ekelund LG, Karon JM, . Predictive value of the exercise tolerance test for mortality in North American men: the Lipid Research Clinics Mortality Follow-up Study. Circulation. 1986 Aug;74(2):252-61. PMID: 3731417. Exclusion Code: X5.3731417
139 Gorodeski EZ, Ishwaran H, Blackstone EH, . Quantitative electrocardiographic measures and long-term mortality in exercise test patients with clinically normal resting electrocardiograms. Am Heart J. 2009 Jul;158(1):61-70.e1. doi: 10.1016/j.ahj.2009.04.015. PMID: 19540393. Exclusion Code: X2.19540393
140 Gottdiener JS, Arnold AM, Aurigemma GP, . Predictors of congestive heart failure in the elderly: the Cardiovascular Health Study. J Am Coll Cardiol. 2000 May;35(6):1628-37. PMID: 10807470. Exclusion Code: X5.10807470
141 Grassi G, Cifkova R, Laurent S, . Blood pressure control and cardiovascular risk profile in hypertensive patients from central and eastern European countries: results of the BP-CARE study. Eur Heart J. 2011 Jan;32(2):218-25. doi: 10.1093/eurheartj/ehq394. PMID: 21047877. Exclusion Code: X6.21047877
142 Greenland P, LaBree L, Azen SP, . Coronary artery calcium score combined with Framingham score for risk prediction in asymptomatic individuals. JAMA. 2004 Jan 14;291(2):210-5. doi: 10.1001/jama.291.2.210. PMID: 14722147. Ex clusion Code: X3.14722147
143 Greenland P, Xie X, Liu K, . Impact of minor electrocardiographic ST-segment and/or T-wave abnormalities on cardiovascular mortality during long-term follow-up. Am J Cardiol. 2003 May 1;91(9):1068-74. PMID: 12714148. Exclusion Code: X5.12714148
144 Greiser KH, Kluttig A, Schumann B, . Cardiovascular diseases, risk factors and short-term heart rate variability in an elderly general population: the CARLA study 20022006. Eur J Epidemiol. 2009;24(3):123-42. doi: 10.1007/s10654-009-9317-z. PMID: 19199053. Exclusion Code: X7.19199053
145 Groepenhoff H, Vonk-Noordegraaf A, van de Veerdonk MC, . Prognostic relevance of changes in exercise test variables in pulmonary arterial hypertension. PLoS One. 2013;8(9):e72013. doi: 10.1371/journal.pone.0072013. PMID: 24039732. Exclusion Code: X3.24039732
146 Grossman C, Ehrlich S, Shemesh J, . Coronary artery calcium and exercise electrocardiogram as predictors of coronary events in asymptomatic adults. Am J Cardiol. 2015 Mar 15;115(6):745-50. doi: 10.1016/j.amjcard.2014.12.039. PMID: 25616536. Exclusion Code: X4.25616536
147 Grover SA, Dorais M, Paradis G, . Lipid screening to prevent coronary artery disease: a quantitative evaluation of evolving guidelines. CMAJ. 2000 Nov 14;163(10):1263-9. PMID: 11107461. Exclusion Code: X3.11107461
148 Grundy SM, Barlow CE, Farrell SW, . Cardiorespiratory fitness and metabolic risk. Am J Cardiol. 2012 Apr 1;109(7):988-93. doi: 10.1016/j.amjcard.2011.11.031. PMID: 22221951. Exclusion Code: X4.22221951
149 Gulati M, Arnsdorf MF, Shaw LJ, . Prognostic value of the duke treadmill score in asymptomatic women. Am J Cardiol. 2005 Aug 1;96(3):369-75. doi: 10.1016/j.amjcard.2005.03.078. PMID: 16054460. Exclusion Code: X4.16054460
150 Gulati M, Black HR, Arnsdorf MF, . Kidney dysfunction, cardiorespiratory fitness, and the risk of death in women. J Womens Health (Larchmt). 2012 Sep;21(9):917-24. doi: 10.1089/jwh.2011.3406. PMID: 22480201. Exclusion Code: X4.22480201
151 Gulati M, Pandey DK, Arnsdorf MF, . Exercise capacity and the risk of death in women: the St James Women Take Heart Project. Circulation. 2003 Sep 30;108(13):1554-9. doi: 10.1161/01.CIR.0000091080.57509.E9. PMID: 12975254. Exclusion Code: X5.12975254
152 Gulati M, Shaw LJ, Thisted RA, . Heart rate response to exercise stress testing in asymptomatic women: the st. James women take heart project. Circulation. 2010 Jul 13;122(2):130-7. doi: 10.1161/circulationaha.110.939249. PMID: 20585008. Exclusion Code: X5.20585008
153 Gupta S, Rohatgi A, Ayers CR, . Cardiorespiratory fitness and classification of risk of cardiovascular disease mortality. Circulation. 2011 Apr 5;123(13):1377-83. doi: 10.1161/circulationaha.110.003236. PMID: 21422392. Exclusion Code: X3.21422392
154 Guzder RN, Gatling W, Mullee MA, . Prognostic value of the Framingham cardiovascular risk equation and the UKPDS risk engine for coronary heart disease in newly diagnosed Type 2 diabetes: results from a United Kingdom study. Diabet Med. 2005 May;22(5):554-62. doi: 10.1111/j.1464-5491.2005.01494.x. PMID: 15842509. Exclusion Code: X3.15842509
155 Haataja P, Anttila I, Nikus K, . Prognostic implicatios of intraventricular conduction delays in a general population: the Health 2000 Survey. Ann Med. 2015 Feb;47(1):74-80. doi: 10.3109/07853890.2014.985704. PMID: 25613171. Exclusion Code: X5.25613171
156 Hadaegh F, Ehteshami-Afshar S, Hajebrahimi MA, . Silent coronary artery disease and incidence of cardiovascular and mortality events at different levels of glucose regulation; results of greater than a decade follow-up. Int J Cardiol. 2015 Mar 1;182:334-9. doi: 10.1016/j.ijcard.2015.01.017. PMID: 25585379. Exclusion Code: X5.25585379
157 Hadaegh F, Hatami M, Mohebi R, . Electrocardiography-defined silent CHD and risk of cardiovascular events among diabetic patients in a Middle Eastern population. Eur J Prev Cardiol. 2012 Dec;19(6):1227-33. doi: 10.1177/1741826711428065. PMID: 22013153. Exclusion Code: X2.22013153
158 Hage FG, Lusa L, Dondi M, . Exercise stress tests for detecting myocardial ischemia in asymptomatic patients with diabetes mellitus. Am J Cardiol. 2013 Jul 1;112(1):14-20. doi: 10.1016/j.amjcard.2013.02.047. PMID: 23578350. Exclusion Code: X4.23578350
159 Halon DA, Dobrecky-Mery I, Gas par T, . Heart rate recovery after exercise and coronary atheroma in asymptomatic individuals with type 2 diabetes mellitus: a study using 64-slice coronary CT angiography. Int J Cardiol. 2010 Nov 5;145(1):102-3. doi: 10.1016/j.ijcard.2009.05.045. PMID: 19540605. Exclusion Code: X5.19540605
160 Hankil Kim J, Dooley P, Smith R. Clinical Inquiry: Do asymptomatic adults need screening EKGs? J Fam Pract. 2013 Aug;62(8):438-50. PMID: 24143339. Exclusion Code: X7.24143339
161 Hartaigh B, Allore HG, Trentalange M, . Elevations in time-varying resting heart rate predict subsequent all-cause mortality in older adults. Eur J Prev Cardiol. 2015 Apr;22(4):527-34. doi: 10.1177/2047487313519932. PMID: 24445263. Exclusion Code: X2.24445263
162 Hense HW, Schulte H, Lowel H, . Framingham risk function overestimates risk of coronary heart disease in men and women from Germany--res ults from the MONICA Augsburg and the PROCA M cohorts. Eur Heart J. 2003 May;24(10):937-45. PMID: 12714025. Exclusion Code: X3.12714025
163 Heston TF. Standardizing predictive values in diagnostic imaging research. J Magn Reson Imaging. 2011 Feb;33(2):505; author reply 6-7. doi: 10.1002/jmri.22466. PMID: 21274995. Exclusion Code: X7.21274995
164 Hillebrand S, Gast KB, de Mutsert R, . Heart rate variability and first cardiovascular event in populations without known cardiovascular disease: meta-analysis and dose-response meta-regression. Europace. 2013 May;15(5):742-9. doi: 10.1093/europace/eus341. PMID: 23370966. Exclusion Code: X7.23370966
165 Hippisley-Cox J, Coupland C, Vinogradova Y, . Performance of the QRISK cardiovascular risk prediction algorithm in an independent UK sample of patients from general practice: a validation study. Heart. 2008 Jan;94(1):34-9. doi: 10.1136/hrt.2007.134890. PMID: 17916661. Exclusion Code: X3.17916661
166 Hippis ley-Cox J, Coupland C, Vinogradova Y, . Derivation and validation of QRISK, a new cardiovascular disease risk score for the United Kingdom: prospective open cohort study. BMJ. 2007 Jul 21;335(7611):136. doi: 10.1136/bmj.39261.471806.55. PMID: 17615182. Exclusion Code: X3.17615182
167 Hippisley-Cox J, Coupland C, Vinogradova Y, . Predicting cardiovascular risk in England and Wales: prospective derivation and validation of QRISK2. BMJ. 2008 Jun 28;336(7659):1475-82. doi: 10.1136/bmj.39609.449676.25. PMID: 18573856. Exclusion Code: X3.18573856
168 Hisamatsu T, Miura K, Ohkubo T, . Interaction between dietary marine-derived n-3 fatty acids intake and J-point elevation on the risk of cardiac death: a 24-year follow-up of Japanese men. Heart. 2013 Jul;99(14):1024-9. doi: 10.1136/heartjnl2012-303496. PMID: 23666393. Exclusion Code: X4.23666393
169 Hisamatsu T, Ohkubo T, Miura K, . Association between J-point elevation and death from coronary artery disease--15-year follow up of the NIPPON DATA90. Circ J. 2013;77(5):1260-6. PMID: 23358431. Exclusion Code: X4.23358431
170 Ho JS, Fitzgerald SJ, Barlow CE, . Risk of mortality increases with increasing number of abnormal non-ST parameters recorded during exercise testing. Eur J Cardiovasc Prev Rehabil. 2010 Aug;17(4):462-8. doi: 10.1097/HJR.0b013e328336a10d. PMID: 20084008. Exclusion Code: X5.20084008
171 Hodnesdal C, Prestgaard E, Erikssen G, . Rapidly upsloping ST-segmenton exercise ECG: a marker of reduced coronary heart disease mortality risk. Eur J Prev Cardiol. 2013 Aug;20(4):541-8. doi: 10.1177/2047487312444370. PMID: 22492865. Exclusion Code: X4.22492865
172 Hollenberg M, Zoltick JM, Go M, . Comparison of a quantitative treadmill exercise score with standard electrocardiographic criteria in screening asymptomatic young men for coronary artery disease. N Engl J Med. 1985 Sep 5;313(10):600-6. doi: 10.1056/NEJM198509053131003. PMID: 4022047. Exclusion Code: X4.4022047
173 Holtermann A, Mortensen OS, Burr H, . Long work hours and physical fitness: 30year risk of ischaemic heart disease and allcause mortality among middle-aged Caucasian men. Heart. 2010 Oct;96(20):1638-44. doi: 10.1136/hrt.2010.197145. PMID: 20820054. Exclusion Code: X3.20820054
174 Holtermann A, Mortensen OS, Burr H, . Physical work demands and physical fitness in low s ocial classes--30-year ischemic heart disease and all-cause mortality in the Copenhagen Male Study. J Occup Environ Med. 2011 Nov;53(11):1221-7. doi: 10.1097/JOM.0b013e318233865f. PMID: 22015549. Exclusion Code: X3.22015549
175 Hung RK, Al-Mallah MH, McEvoy JW, . Prog nostic value of exercise capacity in patients with coronary artery disease: the FIT (Henry Ford ExercIs e Tes ting) project. Mayo Clin Proc. 2014 Dec;89(12):1644-54. doi: 10.1016/j.mayocp.2014.07.011. PMID: 25440889. Exclusion Code: X2.25440889
176 Hung RK, Al-Mallah MH, Qadi MA, . Cardiores piratory fitness attenuates risk for major adverse cardiac events in hyperlipidemic men and women independent of statin therapy: The Henry Ford ExercIse Testing Project. Am Heart J. 2015 Aug;170(2):390-9. doi: 10.1016/j.ahj.2015.04.030. PMID: 26299238. Exclusion Code: X2.26299238
177 Ilias NA, Xian H, Inman C, . Arm exercise testing predicts clinical outcome. Am Heart J. 2009 Jan;157(1):69-76. doi: 10.1016/j.ahj.2008.09.007. PMID: 19081399. Exclusion Code: X2.19081399
178 Ilkhanoff L, Liu K, Ning H, . Association of QRS duration with left ventricular structure and function and risk of heart failure in middle-aged and older adults: the Multi-Ethnic Study of Atherosclerosis (MESA). Eur J Heart Fail. 2012 Nov;14(11):1285-92. doi: 10.1093/eurjhf/hfs112. PMID: 22791081. Exclusion Code: X5.22791081
179 Ilkhanoff L, Soliman EZ, Prineas RJ, . Clinical characteristics and outcomes associated with the natural history of early repolarization in a young, biracial cohort followed to middle age: the Coronary Artery Risk Development in Young Adults (CARDIA) study. Circ Arrhythm Electrophysiol. 2014 Jun;7(3):392-9. doi: 10.1161/circep.113.000874. PMID: 24759868. Exclusion Code: X3.24759868
180 Inama G, Pedrinazzi C. T-wave alternans and ventricular arrhythmias in athletes: usefulness of follow-up updates. Ann Noninvasive Electrocardiol. 2009 Jan;14(1):99. doi: 10.1111/j.1542474X.2008.00280.x. PMID: 19149801. Exclusion Code: X7.19149801
181 Inohara T, Kohsaka S, Okamura T, . Cumulative impact of axial, structural, and repolarization ECG findings on long-term cardiovascular mortality among healthy individuals in Japan: National Integrated Project for Prospective Observation of NonCommunicable Disease and its Trends in the Aged, 1980 and 1990. Eur J Prev Cardiol. 2014 Dec;21(12):1501-8. doi: 10.1177/2047487313500568. PMID: 23918839. Exclusion Code: X4.23918839
182 Inohara T, Kohsaka S, Okamura T, . Long-term outcome of healthy participants with atrial premature complex: a 15-year follow-up of the NIPPON DATA 90 cohort. PLoS One. 2013;8(11):e80853. doi: 10.1371/journal.pone.0080853. PMID: 24260495. Exclusion Code: X4.24260495
183 Iribarren C, Round AD, Peng JA, . Short QT in a cohort of 1.7 million persons: prevalence, correlates, and prognosis. Ann Noninvasive Electrocardiol. 2014 Sep;19(5):490-500. doi: 10.1111/anec.12157. PMID: 24829126. Exclusion Code: X7.24829126
184 Ishikawa J, Ishikawa S, Kario K. Levels of cornell voltage and cornell product for predicting cardiovascular and stroke mortality and morbidity in the general Japanese population. Circ J. 2014;78(2):465-75. PMID: 24284883. Exclusion Code: X4.24284883
185 Jacob MJ. Evaluation of TMT abnormalities in asymptomatic persons using myocardial perfusions tudy. J Assoc Physicians India. 2011 Mar;59:155-6, 61-3. PMID: 21751624. Exclusion Code: X5.21751624
186 Jee SH, Park JW, Lee SY, . Stroke risk prediction model: a risk profile from the Korean study. Atherosclerosis. 2008 Mar;197(1):318-25. doi: 10.1016/j.atherosclerosis.2007.05.014. PMID: 17586511. Exclusion Code: X3.17586511
187 Jensen MT, Suadicani P, Hein HO, . Elevated resting heart rate, physical fitness and all-cause mortality: a 16-year follow-up in the Copenhagen Male Study. Heart. 2013 Jun;99(12):882-7. doi: 10.1136/heartjnl2012-303375. PMID: 23595657. Exclusion Code: X4.23595657
188 Jeong HC, Kim I, Park KH, . New strategy for detection of subclinical coronary atherosclerosis in asymptomatic patients with type 2 diabetes based on cardiac multi-detector computed tomography and treadmill test. Circ J. 2014;78(3):671-8. PMID: 24401570. Exclusion Code: X4.24401570
189 Jimenez-Pavon D, Artero EG, Lee DC, . Cardiorespiratory Fitness and Risk of Sudden Cardiac Death in Men and Women in the United States: A Prospective Evaluation From the Aerobics Center Longitudinal Study. Mayo Clin Proc. 2016 Jul;91(7):849-57. doi: 10.1016/j.mayocp.2016.04.025. PMID: 27378037. Exclusion Code: X5.27378037
190 Jissho S, Shimada K, Taguchi H, . Impact of electrocardiographic left ventricular hypertrophy on the occurrence of cardiovascular events in elderly hypertensive patients. - The Japanese trial to assess optimal systolic blood pressure in elderly hypertensive patients (JATOS). Circ J. 2010 May;74(5):938-45. PMID: 20339195. Exclusion Code: X2.20339195
191 Johnson NP, Goldberger JJ. Prognostic value of late heart rate recovery after treadmill exercise. Am J Cardiol. 2012 Jul 1;110(1):45-9. doi: 10.1016/j.amjcard.2012.02.046. PMID: 22463837. Exclusion Code: X2.22463837
192 Josephson RA, Shefrin E, Lakatta EG, . Can serial exercise testing improve the prediction of coronary events in asymptomatic individuals? Circulation. 1990 Jan;81(1):20-4. PMID: 2297826. Exclusion Code: X4.2297826
193 Jouven X, Empana JP, Schwartz PJ, . Heart-rate profile during exercise as a predictor of sudden death. N Engl J Med. 2005 May 12;352(19):1951-8. doi: 10.1056/NEJMoa043012. PMID: 15888695. Exclusion Code: X5.15888695
194 Jouven X, Zureik M, Desnos M, . Longterm outcome in asymptomatic men with exercise-induced premature ventricular depolarizations. N Engl J Med. 2000 Sep 21;343(12):826-33. doi: 10.1056/NEJM200009213431201. PMID: 10995861. Exclusion Code: X4.10995861
195 Julius S, Palatini P, Kjeldsen SE, . Usefulness of heart rate to predict cardiac events in treated patients with high-risk systemic hypertension. Am J Cardiol. 2012 Mar 1;109(5):685-92. doi: 10.1016/j.amjcard.2011.10.025. PMID: 22169130. Exclusion Code: X2.22169130
196 Junttila MJ, Tikkanen JT, Kentta T, . Early repolarization as a predictor of arrhythmic and nonarrhythmic cardiac events in middle-aged subjects. Heart Rhythm. 2014 Oct;11(10):1701-6. doi: 10.1016/j.hrthm.2014.05.024. PMID: 24858812. Exclusion Code: X5.24858812
197 Kabutoya T, Ishikawa S, Ishikawa J, . Pwave morphologic characteristics predict cardiovascular events in a communitydwelling population. Ann Noninvasive Electrocardiol. 2012 Jul;17(3):252-9. doi: 10.1111/j.1542-474X.2012.00529.x. PMID: 22816544. Exclusion Code: X7.22816544
198 Kahn S, Frishman WH, Weissman S, . Left ventricular hypertrophy on electrocardiogram: prognostic implications from a 10-year cohort study of older subjects: a report from the Bronx Longitudinal Aging Study. J Am Geriatr Soc. 1996 May;44(5):524-9. PMID: 8617900. Exclusion Code: X5.8617900
199 Kamel H, Bartz TM, Longs treth W T, Jr., . Association between left atrial abnormality on ECG and vascular brain injury on MRI in the Cardiovascular Health Study. Stroke. 2015 Mar;46(3):711-6. doi: 10.1161/strokeaha.114.007762. PMID: 25677594. Exclusion Code: X5.25677594
200 Kamel H, Hunter M, Moon YP, . Electrocardiographic Left Atrial Abnormality and Risk of Stroke: Northern Manhattan Study. Stroke. 2015 Nov;46(11):3208-12. doi: 10.1161/strokeaha.115.009989. PMID: 26396031. Exclusion Code: X5.26396031
201 Kamel H, O’Neal WT, Okin PM, . Electrocardiographic left atrial abnormality and stroke s ubtype in the atherosclerosis risk in communities study. An n Neurol. 2015 Nov;78(5):670-8. doi: 10.1002/ana.24482. PMID: 26179566. Exclusion Code: X5.26179566
202 Kamel H, Soliman EZ, Heckbert SR, . P-wave morphology and the risk of incident ischemic stroke in the Multi-Ethnic Study of Atherosclerosis. Stroke. 2014 Sep;45(9):2786-8. doi: 10.1161/strokeaha.114.006364. PMID: 25052322. Exclusion Code: X5.25052322
203 Kanaya AM, Kandula N, Herrington D, . Mediators of Atherosclerosis in South Asians Living in America (MASALA) study: objectives, methods, and cohort description. Clin Cardiol. 2013 Dec;36(12):713-20. doi: 10.1002/clc.22219. PMID: 24194499. Exclusion Code: X5.24194499
204 Katsikis A, Theodorakos A, Kouzoumi A, . Prognostic value of the Duke treadmill score in octogenarians undergoing myocardial perfusion imaging. Atherosclerosis. 2014 Oct;236(2):373-80. doi: 10.1016/j.atherosclerosis.2014.07.028. PMID: 25133351. Exclusion Code: X2.25133351
205 Katsikis A, Theodorakos A, Papaioannou S, . Long-term prognostic value of myocardial perfusion imaging in octogenarians able to undergo treadmill exercise stress testing. J Nucl Cardiol. 2014 Dec;21(6):1213-22. doi: 10.1007/s12350014-9991-4. PMID: 25189145. Exclusion Code: X2.25189145
206 Kawasaki-Ogita Y, Hamamoto Y, Honjo S, . The limited usefulness of the treadmill test or a risk-guided approach in screening for asymptomatic coronary heart disease in Japanese patients with type 2 diabetes. Intern Med. 2012;51(24):3337-42. PMID: 23257517. Exclusion Code: X5.23257517
207 Kellett J, Rasool S, McLoughlin B. Prediction of mortality 1 year after hospital admission. Qjm. 2012 Sep;105(9):847-53. doi: 10.1093/qjmed/hcs099. PMID: 22690010. Exclusion Code: X2.22690010
208 Kentta T, Karsikas M, Junttila MJ, . QRS-T morphology measured from exercise electrocardiogram as a predictor of cardiac mortality. Europace. 2011 May;13(5):701-7. doi: 10.1093/europace/euq461. PMID: 21186225. Exclusion Code: X5.21186225
209 Khan H, Kunutsor S, Rauramaa R, . Cardiores piratory fitness and risk of heart failure: a population-based follow-up study. Eur J Heart Fail. 2014 Feb;16(2):180-8. doi: 10.1111/ejhf.37. PMID: 24464981. Exclusion Code: X2.24464981
210 Khan HS, Iftikhar I, Khan Q. Validity of Electrocardiographic QT Interval in Predicting Left Ventricular Diastolic Dysfunction in Patients with Suspected Heart Failure. J Coll Physicians Surg Pak. 2016 May;26(5):353-6. doi: 27225136. Exclusion Code: X2.27225136
211 Khan R, Jang IK. Evaluation of coronary allograft vasculopathy using multi-detector row computed tomography: a systematic review (Provisional abstract). European Journal of Cardio-Thoracic Surgery. 2012;41(2):415-22. PMID: DARE12012022142. Exclusion Code: X2.21820912
212 Kim JH, Baggish AL. Electrocardiographic right and left bundle branch block patterns in athletes: prevalence, pathology, and clinical s ignificance. J Electrocardiol. 2015 May-Jun;48(3):380-4. doi: 10.1016/j.jelectrocard.2015.03.015. PMID: 25836379. Exclusion Code: X7.25836379
213 Kobal SL, Wilkof-Segev R, Patchett MS, . Prognostic value of myocardial ischemic electrocardiographic response in patients with normal stress echocardiographic study. Am J Cardiol. 2014 Mar 15;113(6):945-9. doi: 10.1016/j.amjcard.2013.11.051. PMID: 24440328. Exclusion Code: X2.24440328
214 Koenig W, Lowel H, Baumert J, . Creactive protein modulates risk prediction based on the Framingham Score: implications for future risk assessment: results from a large cohort study in southern Germany. Circulation. 2004 Mar 23;109(11):1349-53. doi: 10.1161/01.CIR.0000120707.98922.E3. PMID: 15023871. Exclusion Code: X3.15023871
215 Kokkinos P, Doumas M, Myers J, . A graded association of exercise capacity and all-cause mortality in males with highnormal blood pressure. Blood Press. 2009;18(5):261-7. doi: 10.3109/08037050903272859. PMID: 19919397. Exclusion Code: X4.19919397
216 Kokkinos P, Faselis C, Myers J, . Statin therapy, fitness, and mortality risk in middle-aged hypertensive male veterans. Am J Hypertens. 2014 Mar;27(3):422-30. doi: 10.1093/ajh/hpt241. PMID: 24436326. Exclusion Code: X2.24436326
217 Kokkinos P, Myers J, Doumas M, . Heart rate recovery, exercise capacity, and mortality risk in male veterans. Eur J Prev Cardiol. 2012 Apr;19(2):177-84. doi: 10.1177/1741826711398432. PMID: 21450594. Exclusion Code: X4.21450594
218 Kokkinos PF, Faselis C, Myers J, . Interactive effects of fitness and statin treatment on mortality risk in veterans with dyslipidaemia: a cohort study. Lancet. 2013 Feb 2;381(9864):394-9. doi: 10.1016/s01406736(12)61426-3. PMID: 23199849. Exclusion Code: X2.23199849
219 Koller MT, Steyerberg EW, Wolbers M, . Validity of the Framingham point scores in the elderly: results from the Rotterdam study. Am Heart J. 2007 Jul;154(1):87-93. doi: 10.1016/j.ahj.2007.03.022. PMID: 17584559. Exclusion Code: X3.17584559
220 Kook HY, Jeong MH, Oh S, . Current trend of acute myocardial infarction in Korea (from the Korea Acute Myocardial Infarction Regis try from 2006 to 2013). Am J Cardiol. 2014 Dec 15;114(12):1817-22. doi: 10.1016/j.amjcard.2014.09.019. PMID: 25438907. Exclusion Code: X2.25438907
221 Kop WJ, Stein PK, Tracy RP, . Autonomic nervous system dysfunction and inflammation contribute to the increased cardiovascular mortality risk associated with depression. Psychosom Med. 2010 Sep;72(7):626-35. doi: 10.1097/PSY.0b013e3181eadd2b. PMID: 20639389. Exclusion Code: X3.20639389
222 Kothari V, Stevens RJ, Adler AI, . UKPDS 60: risk of stroke in type 2 diabetes estimated by the UK Prospective Diabetes Study risk engine. Stroke. 2002 Jul;33(7):1776-81. PMID: 12105351. Exclusion Code: X3.12105351
223 Krepp JM, Lin F, Min JK, . Relationship of electrocardiographic left ventricular hypertrophy to the presence of diastolic dysfunction. Ann Noninvasive Electrocardiol. 2014 Nov;19(6):552-60. doi: 10.1111/anec.12166. PMID: 24750238. Exclusion Code: X4.24750238
224 Krijthe BP, Leening MJ, Heeringa J, . Unrecognized myocardial infarction and risk of atrial fibrillation: the Rotterdam Study. Int J Cardiol. 2013 Sep 30;168(2):1453-7. doi: 10.1016/j.ijcard.2012.12.057. PMID: 23332895. Exclusion Code: X5.23332895
225 Kurl S, Laukkanen JA, Tuomainen TP, . Association of exercise-induced, silent STsegment depression with the risk of stroke and cardiovascular diseases in men. Stroke. 2003 Jul;34(7):1760-5. doi: 10.1161/01.STR.0000078564.46376.0A. PMID: 12829872. Exclusion Code: X5.12829872
226 Kurl S, Makikallio TH, Laukkanen JA. Twave inversion and mortality risk. Ann Med. 2015 Feb;47(1):69-73. doi: 10.3109/07853890.2014.985703. PMID: 25613172. Exclusion Code: X5.25613172
227 Kurl S, Makikallio TH, Rautaharju P, . Duration of QRS complex in resting electrocardiogram is a predictor of sudden cardiac death in men. Circulation. 2012 May 29;125(21):2588-94. doi: 10.1161/circulationaha.111.025577. PMID: 22615341. Exclusion Code: X2.22615341
228 Kurl S, Sivenius J, Makikallio TH, . Exercise workload, cardiovascular risk factor evaluation and the risk of stroke in middle-aged men. J Intern Med. 2009 Feb;265(2):229-37. doi: 10.1111/j.13652796.2008.02006.x. PMID: 18793247. Exclusion Code: X5.18793247
229 Ladapo JA, Blecker S, Douglas PS. Physician decision making and trends in the use of cardiac stress testing in the United States: an analysis of repeated crosssectional data. Ann Intern Med. 2014 Oct 7;161(7):482-90. doi: 10.7326/m14-0296. PMID: 25285541. Exclusion Code: X7.25285541
230 Ladapo JA, Blecker S, Elashoff MR, . Clinical implications of referral bias in the diagnostic performance of exercise testing for coronary artery disease (Provisional abstract). Database of Abstracts of Reviews of Effects. 2013(2):e000505. PMID: DARE12014040303. Exclusion Code: X3.
231 Lakoski SG, Barlow CE, Farrell SW, . Impact of body mass index, physical activity, and other clinical factors on cardiores piratory fitness (from the Cooper Center longitudinal study). Am J Cardiol. 2011 Jul 1;108(1):34-9. doi: 10.1016/j.amjcard.2011.02.338. PMID: 21529738. Exclusion Code: X5.21529738
232 Lakoski SG, Willis BL, Barlow CE, . Midlife Cardio res piratory Fitness, Incident Cancer, and Survival After Cancer in Men: The Cooper Center Longitudinal Study. JAMA Oncol. 2015 May;1(2):231-7. doi: 10.1001/jamaoncol.2015.0226. PMID: 26181028. Exclusion Code: X5.26181028
233 Larsen BS, Kumarathurai P, Falkenberg J, . Excessive Atrial Ectopy and Short A trial Runs Increase the Risk of Stroke Beyond Incident Atrial Fibrillation. J Am Coll Cardiol. 2015 Jul 21;66(3):232-41. doi: 10.1016/j.jacc.2015.05.018. PMID: 26184616. Exclusion Code: X5.26184616
234 Larsen CT, Dahlin J, Blackburn H, . Prevalence and prognosis of electrocardiographic left ventricular hypertrophy, ST segment depression and negative T-wave; the Copenhagen City Heart Study. Eur Heart J. 2002 Feb;23(4):315-24. doi: 10.1053/euhj.2001.2774. PMID: 11812068. Exclusion Code: X5.11812068
235 Larstorp AC, Okin PM, Devereux RB, . Changes in electrocardiographic left ventricular hypertrophy and risk of major cardiovascular events in is olated systolic hypertension: the LIFE study. J Hum Hypertens. 2011 Mar;25(3):178-85. doi: 10.1038/jhh.2010.52. PMID: 20505749. Exclusion Code: X5.20505749
236 Lauer MS, Okin PM, Larson MG, . Impaired heart rate response to graded ex ercise. Prognostic implications of chronotropic incompetence in the Framingham Heart Study. Circulation. 1996 Apr 15;93(8):1520-6. PMID: 8608620. Exclusion Code: X5.8608620
237 Laukkanen JA, Di Angelantonio E, Khan H, . T-wave inversion, QRS duration, and QRS/T angle as electrocardiographic predictors of the risk for sudden cardiac death. Am J Cardiol. 2014 Apr 1;113(7):1178-83. doi: 10.1016/j.amjcard.2013.12.026. PMID: 24513474. Exclusion Code: X2.24513474
238 Laukkanen JA, Kurl S, Lakka TA, . Exercise-induced silent myocardial is chemia and coronary morbidity and mortality in middle-aged men. J Am Coll Cardiol. 2001 Jul;38(1):72-9. PMID: 11451298. Exclusion Code: X5.11451298
239 Laukkanen JA, Kurl S, Rauramaa R, . Systolic blood pressure response to exercise testing is related to the risk of acute myocardial infarction in middle-aged men. Eur J Cardiovasc Prev Rehabil. 2006 Jun;13(3):421-8. PMID: 16926673. Exclusion Code: X5.16926673
240 Laukkanen JA, Rauramaa R, Kurl S. Exercise workload, coronary risk evaluation and the risk of cardiovascular and all-cause death in middle-aged men. Eur J Cardiovasc Prev Rehabil. 2008 Jun;15(3):285-92. doi: 10.1097/HJR.0b013e3282f37a33. PMID: 18525382. Exclusion Code: X5.18525382
241 Laukkanen JA, Willeit P, Kurl S, . Elevated systolic blood pressure during recovery from exercise and the risk of sudden cardiac death. J Hypertens. 2014 Mar;32(3):659-66. doi: 10.1097/hjh.0000000000000066. PMID: 24317550. Exclusion Code: X2.24317550
242 Lee CD, Sui X, Blair SN. Combined effects of cardiorespiratory fitness, not smoking, and normal waist girth on morbidity and mortality in men. Arch Intern Med. 2009 Dec 14;169(22):2096-101. doi: 10.1001/archinternmed.2009.414. PMID: 20008693. Exclusion Code: X5.20008693
243 Lee DC, Sui X, Artero EG, . Long-term effects of changes in cardiorespiratory fitness and body mass index on all-cause and cardiovascular disease mortali y in men: the Aerobics Center Longitudinal Study. Circulation. 2011 Dec 6;124(23):2483-90. doi: 10.1161/circulationaha.111.038422. PMID: 22144631. Exclusion Code: X3.22144631
244 Lee DC, Sui X, Ortega FB, . Comparisons of leisure-time physical activity and cardiorespiratory fitness as predictors of all-cause mortality in men and women. Br J Sports Med. 2011 May;45(6):504-10. doi: 10.1136/bjsm.2009.066209. PMID: 20418526. Exclusion Code: X5.20418526
245 Lee ET, Howard BV, Wang W, . Prediction of coronary heart disease in a population with high prevalence of diabetes and albuminuria: the Strong Heart Study. Circulation. 2006 Jun 27;113(25):2897-905. doi: 10.1161/CIRCULATIONAHA.105.593178. PMID: 16769914. Exclusion Code: X4.16769914
246 Lee JM, Yoo KD, Oh YS, . Relationship between resting electrocardiographic parameters and estimated 10-year risk for coronary heart disease in healthy adults in the USA. Ann Noninvasive Electrocardiol. 2010 Oct;15(4):315-20. doi: 10.1111/j.1542474X.2010.00386.x. PMID: 20946553. Exclusion Code: X5.20946553
247 Lee V, Hemingway H, Harb R, . The prognostic significance of premature ventricular complexes in adults without clinically apparent heart disease: a metaanalysis and systematic review. Heart. 2012 Sep;98(17):1290-8. doi: 10.1136/heartjnl2012-302005. PMID: 22781425. Exclusion Code: X7.22781425
248 Leigh JA, O’Neal WT, So liman EZ. Electrocardiographic Left Ventricular Hypertrophy as a Predictor of Cardiovascular Disease Independent of Left Ventricular Anatomy in Subjects Aged >/=65 Years. Am J Cardiol. 2016 Jun 01;117(11):1831-5. doi: 10.1016/j.amjcard.2016.03.020. PMID: 27067620. Exclusion Code: X4.27067620
249 Leo T, Uberoi A, Jain NA, . The impact of ST elevation on athletic screening. Clin J Sport Med. 2011 Sep;21(5):433-40. doi: 10.1097/jsm.0b013e31822cf105. PMID: 21892017. Exclusion Code: X7.21892017
250 Levitt K, Aves T, Dorian P, . Lack of difference in T wave variability between patients at risk of sudden cardiac death and healthy subjects. J Electrocardiol. 2014 Mar-Apr;47(2):251-6. doi: 10.1016/j.jelectrocard.2013.12.007. PMID: 24456792. Exclusion Code: X4.24456792
251 Li Y, Dawood FZ, Chen H, . Minor isolated Q waves and cardiovascular events in the MESA study. Am J Med. 2013 May;126(5):450.e9-e16. doi: 10.1016/j.amjmed.2012.10.030. PMID: 23582938. Exclusion Code: X4.23582938
252 Li Y, Shah AJ, Soliman EZ. Effect of electrocardiographic P-wave axis on mortality. Am J Cardiol. 2014 Jan 15;113(2):372-6. doi: 10.1016/j.amjcard.2013.08.050. PMID: 24176072. Exclusion Code: X2.24176072
253 Liao Y, McGee DL, Cooper RS. Prediction of coronary heart disease mortality in blacks and whites: pooled data from two national cohorts. Am J Cardiol. 1999 Jul 1;84(1):31-36. PMID: 10404847. Exclusion Code: X3.10404847
254 Liao Y, McGee DL, Cooper RS, . How generalizable are coronary risk prediction models? Comparison of Framingham and two national cohorts. Am Heart J. 1999 May;137(5):837-45. PMID: 10220632. Exclusion Code: X3.10220632
255 Liao YL, Liu KA, Dyer A, . Major and minor electrocardiographic abnormalities and risk of death from coronary heart disease, cardiovascular diseases and all causes in men and women. J Am Coll Cardiol. 1988 Dec;12(6):1494-500. PMID: 3192848. Exclusion Code: X5.3192848
256 Lindekleiv H, Wilsgaard T, Macfarlane PW, . QT interval and the risk of myocardial infarction and all-cause death: a cohort study. J Cardiovasc Electro physiol. 2012 Aug;23(8):846-52. doi: 10.1111/j.15408167.2012.02308.x. PMID: 22509793. Exclusion Code: X4.22509793
257 Lindman AS, Veierod MB, Pedersen JI, . The ability of the SCORE high-risk model to predict 10-year cardiovascular disease mortality in Norway. Eur J Cardiovasc Prev Rehabil. 2007 Aug;14(4):501-7. doi: 10.1097/HJR.0b013e328011490a. PMID: 17667638. Exclusion Code: X3.17667638
258 Liu J, Hong Y, D’Agostino RB, Sr., . Predictive value for the Chinese population of the Framingham CHD risk assessment tool compared with the Chinese MultiProvincial Cohort Study. JAMA. 2004 Jun 2;291(21):2591-9. doi: 10.1001/jama.291.21.2591. PMID: 15173150. Exclusion Code: X3.15173150
259 Liu R, Sui X, Laditka JN, . Cardiores piratory fitness as a predictor of dementia mortality in men and women. Med Sci Sports Exerc. 2012 Feb;44(2):253-9. doi: 10.1249/MSS.0b013e31822cf717. PMID: 21796048. Exclusion Code: X5.21796048
260 Lovett KM, Liang BA. Direct-to-consumer cardiac screening and suspect risk evaluation. Jama. 2011 Jun 22;305(24):2567-8. doi: 10.1001/jama.2011.865. PMID: 21693746. Exclusion Code: X7.21693746
261 Lowres N, Neubeck L, Redfern J, . Screening to identify unknown atrial fibrillation. A systematic review. Thromb Haemost. 2013 Aug;110(2):213-22. doi: 10.1160/th13-02-0165. PMID: 23595785. Exclusion Code: X7.23595785
262 Lyerly GW, Sui X, Church TS, . Maximal exercise electrocardiography responses and coronary heart disease mortality among men with diabetes mellitus. Circulation. 2008 May 27;117(21):2734-42. doi: 10.1161/CIRCULATIONAHA.107.729277. PMID: 18490521. Exclusion Code: X5.18490521
263 Lyerly GW, Sui X, Church TS, . Maximal exercise electrocardiographic responses and coronary heart disease mortality among men with metabolic syndrome. Mayo Clin Proc. 2010 Mar;85(3):239-46. doi: 10.4065/mcp.2009.0509. PMID: 20160139. Exclusion Code: X5.20160139
264 Lyerly GW, Sui X, Lavie CJ, . The association between cardiorespiratory fitness and risk of all-cause mortality among women with impaired fasting glucose or undiagnosed diabetes mellitus. Mayo Clin Proc. 2009 Sep;84(9):780-6. doi: 10.1016/s0025-6196(11)60487-4. PMID: 19720775. Exclusion Code: X5.19720775
265 Macfarlane PW, Murray H, Sattar N, . The incidence and risk factors for new onset atrial fibrillation in the PROSPER study. Europace. 2011 May;13(5):634-9. doi: 10.1093/europace/eur016. PMID: 21325345. Exclusion Code: X2.21325345
266 Macfarlane PW, Norrie J, Committee WE. The value of the electrocardiogram in risk assessment in primary prevention: experience from the West of Scotland Coronary Prevention Study. J Electrocardiol. 2007 Jan;40(1):101-9. doi: 10.1016/j.jelectrocard.2006.05.003. PMID: 17069838. Exclusion Code: X4.17069838
267 Machado DB, Crow RS, Boland LL, . Electrocardiographic findings and incident coronary heart disease among participants in the Atherosclerosis Risk in Communities (ARIC) study. Am J Cardiol. 2006 Apr 15;97(8):1176-81. doi: 10.1016/j.amjcard.2005.11.036. PMID: 16616022. Exclusion Code: X5.16616022
268 Magnani JW, Johnson VM, Sullivan LM, . P wave duration and risk of longitudinal atrial fibrillation in persons >/= 60 years old (from the Framingham Heart Study). Am J Cardiol. 2011 Mar 15;107(6):917-21.e1. doi: 10.1016/j.amjcard.2010.10.075. PMID: 21255761. Exclusion Code: X5.21255761
269 Magnani JW, Wang N, Nelson KP, . Electrocardiographic PR interval and adverse outcomes in older adults: the Health, Aging, and Body Composition study. Circ Arrhythm Electrophysiol. 2013 Feb;6(1):84-90. doi: 10.1161/circep.112.975342. PMID: 23243193. Exclusion Code: X2.23243193
270 Maheshwari A, Norby FL, Soliman EZ, . Relation of Prolonged P-Wave Duration to Risk of Sudden Cardiac Death in the General Population (from the Atherosclerosis Risk in Communities Study). Am J Cardiol. 2017 May 01;119(9):1302-6. doi: 10.1016/j.amjcard.2017.01.012. PMID: 28267962. Exclusion Code: X2.28267962
271 Mainous AG, 3rd, Everett CJ, Player MS, . Importance of a patient’s personal health history on assessments of future risk of coronary heart disease. J Am Board Fam Med. 2008 Sep-Oct;21(5):408-13. doi: 10.3122/jabfm.2008.05.080046. PMID: 18772295. Exclusion Code: X3.18772295
272 Mainous AG, 3rd, Koopman RJ, Diaz VA, . A coronary heart disease risk score based on patient-reported information. Am J Cardiol. 2007 May 1;99(9):1236-41. doi: 10.1016/j.amjcard.2006.12.035. PMID: 17478150. Exclusion Code: X3.17478150
273 Makimoto H, Nakagawa E, Takaki H, . Augmented ST-segment elevation during recovery from exercise predicts cardiac events in patients with Brugada syndrome. J Am Coll Cardiol. 2010 Nov 2;56(19):1576-84. doi: 10.1016/j.jacc.2010.06.033. PMID: 21029874. Exclusion Code: X2.21029874
274 Mandyam MC, Soliman EZ, Alonso A, . The QT interval and risk of incident atrial fibrillation. Heart Rhythm. 2013 Oct;10(10):1562-8. doi: 10.1016/j.hrthm.2013.07.023. PMID: 23872693. Exclusion Code: X2.23872693
275 Mandyam MC, Soliman EZ, Heckbert SR, . Long-term outcomes of left anterior fascicular block in the absence of overt cardiovascular dis ease. Jama. 2013 Apr 17;309(15):1587-8. doi: 10.1001/jama.2013.2729. PMID: 23592102. Exclusion Code: X4.23592102
276 Marfella R, Sasso FC, Siniscalchi M, . Brief episodes of silent atrial fibrillation predict clinical vascular brain disease in type 2 diabetic patients. J Am Coll Cardiol. 2013 Aug 6;62(6):525-30. doi: 10.1016/j.jacc.2013.02.091. PMID: 23684685. Exclusion Code: X4.23684685
277 Marine JE, Shetty V, Chow GV, . Prevalence and prognostic significance of exercise-induced nonsustained ventricular tachycardia in asymptomatic volunteers: BLSA (Baltimore Longitudinal Study of Aging). J Am Coll Cardiol. 2013 Aug 13;62(7):595-600. doi: 10.1016/j.jacc.2013.05.026. PMID: 23747767. Exclusion Code: X4.23747767
278 Marrugat J, Subirana I, Comin E, . Validity of an adaptation of the Framingham cardiovascular risk function: the VERIFICA Study. J Epidemiol Community Health. 2007 Jan;61(1):40-7. doi: 10.1136/jech.2005.038505. PMID: 17183014. Exclusion Code: X4.17183014
279 Martin WH, 3rd, Xian H, Chandiramani P, . Cardiovascular mortality prediction in veterans with arm exercise vs pharmacologic myocardial perfusion imaging. Am Heart J. 2015 Aug;170(2):362-70. doi: 10.1016/j.ahj.2015.05.004. PMID: 26299235. Exclusion Code: X2.26299235
280 Massing MW, Simpson RJ, Jr., Rautaharju PM, . Usefulness of ventricular premature complexes to predict coronary heart disease events and mortality (from the Atherosclerosis Risk In Communities cohort). Am J Cardiol. 2006 Dec 15;98(12):1609-12. doi: 10.1016/j.amjcard.2006.06.061. PMID: 17145219. Exclusion Code: X5.17145219
281 May M, Lawlor DA, Brindle P, . Cardiovascular disease risk assessment in older women: can we improve on Framingham? British Women’s Heart and Health prospective cohort study. Heart. 2006 Oct;92(10):1396-401. doi: 10.1136/hrt.2005.085381. PMID: 16547204. Exclusion Code: X3.16547204
282 McAuley P, Pittsley J, Myers J, . Fitness and fatness as mortality predictors in healthy older men: the veterans exercise testing study. J Gerontol A Biol Sci Med Sci. 2009 Jun;64(6):695-9. doi: 10.1093/gerona/g1n039. PMID: 19196639. Exclusion Code: X5.19196639
283 McAuley PA, Sui X, Church TS, . The joint effects of cardiorespiratory fitness and adiposity on mortality risk in men with hypertension. Am J Hypertens. 2009 Oct;22(10):1062-9. doi: 10.1038/ajh.2009.122. PMID: 19617881. Exclusion Code: X5.19617881
284 McEwan P, Williams JE, Griffiths JD, . Evaluating the performance of the Framingham risk equations in a population with diabetes. Diabet Med. 2004 Apr;21(4):318-23. doi: 10.1111/j.14645491.2004.01139.x. PMID: 15049932. Exclusion Code: X3.15049932
285 M cNeill AM, Rosamond WD, Girman CJ, . The metabolic syndrome and 11-year risk of incident cardiovascular disease in the atherosclerosis risk in communities study. Diabetes Care. 2005 Feb;28(2):385-90. PMID: 15677797. Exclusion Code: X3.15677797
286 Menotti A, Mulder I, Kromhout D, . The association of silent electrocardiographic findings with coronary deaths among elderly men in three European countries. The FINE study. Acta Ca rdiol. 2001 Feb;56(1):27-36. doi: 10.2143/AC.56.1.2005590. PMID: 11315121. Exclusion Code: X4.11315121
287 Menotti A, Seccareccia F. Electrocardiographic Minnesota code findings predicting short-termmortality in asymptomatic subjects. The Italian RIFLE Pooling Project (Risk Factors and Life Expectancy). G Ital Cardiol. 1997 Jan;27(1):40-9. PMID: 9199942. Exclusion Code: X5.9199942
288 Michaelides AP, Andrikopoulos GK, Antoniades C, . Duration of treadmill exercise testing combined with QRS score predicts adverse cardiac outcome at longterm follow-up. Coron Artery Dis. 2009 Aug;20(5):337-42. doi: 10.1097/MCA.0b013e32832c4589. PMID: 19543085. Exclusion Code: X2.19543085
289 Michaelides A P, Liakos CI, Vyssoulis GP, . The interplay of exercise heart rate and blood pressure as a predictor of coronary artery disease and arterial hypertension. J Clin Hypertens (Greenwich). 2013 Mar;15(3):162-70. doi: 10.1111/jch.12035. PMID: 23458587. Exclusion Code: X4.23458587
290 Milne R, Gamble G, Whitlock G, . Discriminative ability of a risk-prediction tool derived from the Framingham Heart Study compared with single risk factors. N Z Med J. 2003 Nov 07;116(1185):U663. PMID: 14615805. Exclusion Code: X3.14615805
291 Minkkinen M, Nieminen T, Verrier RL, . Impaired exercise capacity predicts sudden cardiac death in a low-risk population: enhanced specificity with heightened T-wave alternans. Ann Med. 2009;41(5):380-9. doi: 10.1080/07853890902802971. PMID: 19301163. Exclusion Code: X5.19301163
292 Miyamoto A, Hayashi H, Makiyama T, . Risk determinants in individuals with a spontaneous type 1 Brugada ECG. Circ J. 2011;75(4):844-51. PMID: 21343656. Exclusion Code: X2.21343656
293 Miyasaka Y, Barnes ME, Gersh BJ, . Coronary ischemic events after first atrial fibrillation: risk and survival. Am J Med. 2007 Apr;120(4):357-63. doi: 10.1016/j.amjmed.2006.06.042. PMID: 17398231. Exclusion Code: X2.17398231
294 Moller CS, Haggstrom J, Zethelius B, . Age and follow-up time affect the prognostic value of the ECG and conventional cardiovascular risk factors for stroke in adult men. J Epidemiol Community Health. 2007 Aug;61(8):704-12. doi: 10.1136/jech.2006.048074. PMID: 17630370. Exclusion Code: X5.17630370
295 Mora S, Redberg RF, Cui Y, . Ability of exercise testing to predict cardiovascular and all-cause death in asymptomatic women: a 20-year follow-up of the lipid research clinics prevalence study. JAMA. 2003 Sep 24;290(12):1600-7. doi: 10.1001/jama.290.12.1600. PMID: 14506119. Exclusion Code: X5.14506119
296 Mora S, Redberg RF, Sharrett AR, . Enhanced risk assessment in asymptomatic individuals with exercise testing and Framingham risk scores. Circulation. 2005 Sep 13;112(11):1566-72. doi: 10.1161/CIRCULATIONAHA.105.542993. PMID: 16144993. Exclusion Code: X5.16144993
297 Morin DP, Saad MN, Shams OF, . Relationships between the T-peak to T-end interval, ventricular tachyarrhythmia, and death in left ventricular systolic dysfunction. Europace. 2012 Aug;14(8):1172-9. doi: 10.1093/europace/eur426. PMID: 22277646. Exclusion Code: X2.22277646
298 Morshedi-Meibodi A, Larson MG, Levy D, . Heart rate recovery after treadmill exercise testing and risk of cardiovascular disease events (The Framingham Heart Study). Am J Cardiol. 2002 Oct 15;90(8):848-52. PMID: 12372572. Exclusion Code: X4.12372572
299 Moyer VA. Screening for coronary heart disease with electrocardiography: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012 Oct 2;157(7):512-8. doi: 10.7326/0003-4819-157-7-20121002000514. PMID: 22847227. Exclusion Code: X7.22847227
300 Muramoto D, Yong CM, Singh N, . Patterns and prognosis of all components of the J-wave pattern in multiethnic athletes and ambulatory patients. Am Heart J. 2014 Feb;167(2):259-66. doi: 10.1016/j.ahj.2013.10.027. PMID: 24439988. Exclusion Code: X7.24439988
301 Muzzarelli S, Pfis terer ME, Muller-Brand J, . Gate-keeper to coronary angiography: comparison of exercise testing, myocardial perfusion SPECT and individually tailored approach for risk stratification. Int J Cardiovasc Imaging. 2010 Dec;26(8):871-9. doi: 10.1007/s10554-010-9627-y. PMID: 20411429. Exclusion Code: X2.20411429
302 Nakamura K, Berry NC, An PG, . Significance of ST-segment elevation in lead aVR. Arch Intern Med. 2012 Mar 12;172(5):389-91. doi: 10.1001/archinternmed.2011.2224. PMID: 22412103. Exclusion Code: X7.22412103
303 Nakamura Y, Okamura T, Higashiyama A, . Prognostic values of clockwise and counterclockwise rotation for cardiovascular mortality in Japanese subjects: a 24-year follow-up of the National Integrated Project for Prospective Observation of Noncommunicable Disease and Its Trends in the Aged, 1980-2004 (NIPPON DATA80). Circulation. 2012 Mar 13;125(10):1226-33. doi: 10.1161/circulationaha.111.070045. PMID: 22308300. Exclusion Code: X4.22308300
304 Narayanan K, Zhang L, Kim C, . QRS fragmentation and sudden cardiac death in the obese and overweight. J Am Heart Assoc. 2015 Mar;4(3):e001654. doi: 10.1161/jaha.114.001654. PMID: 25762804. Exclusion Code: X7.25762804
305 Nehme Z, Boyle MJ, Brown T. Diagnostic accuracy of prehospital clinical prediction models to identify short-term outcomes in patients with acute coronary syndromes: a systematic review (Provisional abstract). Journal of Emergency Medicine. 2013;44(5):946-54.e6. PMID: DARE12013030041. Exclusion Code: X2.23321296
306 Nielsen JB, Kuhl JT, Pietersen A, . Pwave duration and the risk of atrial fibrillation: Results from the Copenhagen ECG Study. Heart Rhythm. 2015 Sep;12(9):1887-95. doi: 10.1016/j.hrthm.2015.04.026. PMID: 25916567. Exclusion Code: X5.25916567
307 Niemeijer MN, Berg ME, Eijgelsheim M, . Short-term QT variability markers for the prediction of ventricular arrhythmias and sudden cardiac death: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):1831-6. PMID: DARE-12014050251. Exclusion Code: X5.
308 Nieminen T, Verrier RL, Leino J, . Atrioventricular conduction and cardiovascular mortality: assessment of recovery PR interval is superior to preexercise measurement. Heart Rhythm. 2010 Jun;7(6):796-801. doi: 10.1016/j.hrthm.2010.02.029. PMID: 20188862. Exclusion Code: X2.20188862
309 Noseworthy PA, Peloso GM, Hwang SJ, . QT interval and long-term mortality risk in the Framingham Heart Study. Ann Noninvasive Electrocardiol. 2012 Oct;17(4):340-8. doi: 10.1111/j.1542474X.2012.00535.x. PMID: 23094880. Exclusion Code: X4.23094880
310 Ofoma U, He F, Shaffer ML, . Premature cardiac contractions and risk of incident ischemic stroke. J Am Heart Assoc. 2012 Oct;1(5):e002519. doi: 10.1161/jaha.112.002519. PMID: 23316293. Exclusion Code: X5.23316293
311 Ofstad AP, Gullestad L, Orvik E, . Interleukin-6 and activin A are independently associated with cardiovascular events and mortality in type 2 diabetes: the prospective Asker and Baerum Cardiovascular Diabetes (ABCD) cohort study. Cardiovasc Diabetol. 2013;12:126. doi: 10.1186/1475-2840-12-126. PMID: 23987834. Exclusion Code: X2.23987834
312 Ogliari G, Mahinrad S, Stott DJ, . Resting heart rate, heart rate variability and functional decline in old age. Cmaj. 2015 Oct 20;187(15):E442-9. doi: 10.1503/cmaj.150462. PMID: 26323697. Exclusion Code: X2.26323697
313 Ohtomo K, Shigeeda T, Hirose A, . Silen t myocardial is chaemia in patients with diabetic retinopathy. Acta Op hthalmol. 2014 Sep;92(6):e492-3. doi: 10.1111/aos.12362. PMID: 24698540. Exclusion Code: X4.24698540
314 Okin PM, Anderson KM, Levy D, . Heart rate adjustment of exercise-induced ST segment depression. Improved risk stratification in the Framingham Offspring Study. Circulation. 1991 Mar;83(3):866-74. PMID: 1999037. Exclusion Code: X5.1999037
315 Okin PM, Grandits G, Rautaharju PM, . Prognostic value of heart rate adjustment of exercise-induced ST segment depression in the multiple risk factor intervention trial. J Am Coll Cardiol. 1996 May;27(6):1437-43. PMID: 8626955. Exclusion Code: X5.8626955
316 Okin PM, Hille DA, Kjeldsen SE, . Persistence of left ventricular hypertrophy is associated with increased cardiovascular morbidity and mortality in hypertensive patients with lower achieved systolic pres sure during antihypertensive treatment. Blood Press. 2014 Apr;23(2):71-80. doi: 10.3109/08037051.2013.791414. PMID: 23721506. Exclusion Code: X2.23721506
317 Okin PM, Kjeldsen SE, Julius S, . Effect of changing heart rate during treatment of hypertension on incidence of heart failure. Am J Cardiol. 2012 Mar 1;109(5):699-704. doi: 10.1016/j.amjcard.2011.10.026. PMID: 22154318. Exclusion Code: X5.22154318
318 Okin PM, Kjeldsen SE, Julius S, . Allcause and cardiovascular mortality in relation to changing heart rate during treatment of hypertensive patients with electrocardiographic left ventricular hypertrophy. Eur Heart J. 2010 Sep;31(18):2271-9. doi: 10.1093/eurheartj/ehq225. PMID: 20601389. Exclusion Code: X5.20601389
319 Okin PM, Oikarinen L, Viitas alo M, . Prognostic value of changes in the electrocardiographic strain pattern during antihypertensive treatment: the Losartan Intervention for End-Point Reduction in Hypertension Study (LIFE). Circulation. 2009 Apr 14;119(14):1883-91. doi: 10.1161/circulationaha.108.812313. PMID: 19332468. Exclusion Code: X5.19332468
320 Okin PM, Oikarinen L, Viitas alo M, . Serial assessment of the electrocardiographic strain pattern for prediction of new-onset heart failure during antihypertensive treatment: the LIFE study. Eur J Heart Fail. 2011 Apr;13(4):384-91. doi: 10.1093/eurjhf/hfq224. PMID: 21239405. Exclusion Code: X5.21239405
321 Oliveira RB, Myers J, Araujo CG, . Maximal exercise oxygen pulse as a predictor of mortality among male veterans referred for exercise testing. Eur J Cardiovasc Prev Rehabil. 2009 Jun;16(3):358-64. doi: 10.1097/HJR.0b013e3283292fe8. PMID: 19357518. Exclusion Code: X3.19357518
322 Olson KA, Viera A J, Soliman EZ, . Long-term prognosis associated with J-point elevation in a large middle-aged biracial cohort: the ARIC study. Eur Heart J. 2011 Dec;32(24):3098-106. doi: 10.1093/eurheartj/ehr264. PMID: 21785106. Exclusion Code: X5.21785106
323 O’Neal WT, Shah AJ, Efird JT, . Subclinical myocardial injury identified by cardiac infarction/injury score and the risk of mortality in men and women free of cardiovascular disease. Am J Cardiol. 2014 Oct 1;114(7):1018-23. doi: 10.1016/j.amjcard.2014.06.032. PMID: 25129878. Exclusion Code: X5.25129878
324 O’Neal WT, Wang YG, Wu HT, . Electrocardiographic J Wave and Cardiovascular Outcomes in the General Population (from the Atherosclerosis Risk In Communities Study). Am J Cardiol. 2016 Sep 15;118(6):811-5. doi: 10.1016/j.amjcard.2016.06.047. PMID: 27596326. Exclusion Code: X5.27596326
325 Orford JL, Sesso HD, Stedman M, . A comparison of the Framingham and European Society of Cardiology coronary heart disease risk prediction models in the normative aging study. Am Heart J. 2002 Jul;144(1):95-100. PMID: 12094194. Exclusion Code: X3.12094194
326 Ortega FB, Lee DC, Katzmarzyk PT, . The intriguing metabolically healthy but obese phenotype: cardiov ascular prognosis and role of fitness. Eur Heart J. 2013 Feb;34(5):389-97. doi: 10.1093/eurheartj/ehs174. PMID: 22947612. Exclusion Code: X3.22947612
327 Ota C, Shiono SN, Fujino Y, . Prevalence and Prognostic Value of Early Repolarization in Low Risk Surgical Patients. Biomed Res Int. 2015;2015:309260. doi: 10.1155/2015/309260. PMID: 26266254. Exclusion Code: X4.26266254
328 Ozgur ES, Nayci SA, Ozge C, . An integrated index combined by dynamic hyperinflation and exercise capacity in the prediction of morbidity and mortality in COPD. Respir Care. 2012 Sep;57(9):1452-9. doi: 10.4187/respcare.01440. PMID: 22348294. Exclusion Code: X4.22348294
329 Paisible AL, Chang CC, So-Armah KA, . HIV infection, cardiovascular disease risk factor profile, and risk for acute myocardial infarction. J Acquir Immune Defic Syndr. 2015 Feb 1;68(2):209-16. doi: 10.1097/qai.0000000000000419. PMID: 25588033. Exclusion Code: X3.25588033
330 Palmerini T, Dangas G, Mehran R, . Predictors and implications of stent thrombosis in non-ST-segment elevation acute coronary syndromes: the ACUITY Trial. Circ Cardiovasc Interv. 2011 Dec 1;4(6):577-84. doi: 10.1161/circinterventions.111.963884. PMID: 22028471. Exclusion Code: X2.22028471
331 Parikh NI, Gona P, Larson MG, . Longterm trends in myocardial infarction incidence and case fatality in the National Heart, Lung, and Blood Institute’s Framingham Heart study. Circulation. 2009 Mar 10;119(9):1203-10. doi: 10.1161/circulationaha.108.825364. PMID: 19237656. Exclusion Code: X5.19237656
332 Park JI, Shin SY, Park SK, . Usefulness of the integrated scoring model of treadmill tests to predict myocardial ischemia and silent myocardial ischemia in communitydwelling adults (from the Rancho Bernardo study). Am J Cardiol. 2015 Apr 15;115(8):1049-55. doi: 10.1016/j.amjcard.2015.01.536. PMID: 25728643. Exclusion Code: X5.25728643
333 Park YM, Sui X, Liu J, . The effect of cardiorespiratory fitness on age-related lipids and lipoproteins. J Am Coll Cardiol. 2015 May 19;65(19):2091-100. doi: 10.1016/j.jacc.2015.03.517. PMID: 25975472. Exclusion Code: X5.25975472
334 Pataky Z, Golay A, Laville M, . Fasting insulin at baseline influences the number of cardiometabolic risk factors and R-R interval at 3years in a healthy population: the RISC Study. Diabetes Metab. 2013 Sep;39(4):330-6. doi: 10.1016/j.diabet.2013.05.008. PMID: 23876398. Exclusion Code: X5.23876398
335 Payne CJ, Payne AR, Gibson SC, . Is there still a role for preoperative 12-lead electrocardiography? World J Surg. 2011 Dec;35(12):2611-6. doi: 10.1007/s00268011-1289-y. PMID: 21989644. Exclusion Code: X2.21989644
336 Paynter NP, Chasman DI, Buring JE, . Cardiovascular disease risk prediction with and without knowledge of genetic variation at chromosome 9p 21.3. Ann Intern Med. 2009 Jan 20;150(2):65-72. PMID: 19153409. Exclusion Code: X3.19153409
337 Peel JB, Sui X, Matthews CE, . Cardiorespiratory fitness and digestive cancer mortality: findings from the aerobics center longitudinal study. Cancer Epidemiol Biomarkers Prev. 2009 Apr;18(4):1111-7. doi: 10.1158/1055-9965.epi-08-0846. PMID: 19293313. Exclusion Code: X5.19293313
338 Perelshtein Brezinov O, Kivity S, Segev S, . Gender-Related Cardiovascular Risk in Healthy Middle-Aged Adults. Am J Cardiol. 2016 Dec 01;118(11):1669-73. doi: 10.1016/j.amjcard.2016.08.045. PMID: 27737731. Exclusion Code: X4.27737731
339 Perez-Rodon J, Martinez-Alday J, BaronEsquivias G, . Prognostic value of the electrocardiogram in patients with syncope: data from the group for syncope study in the emergency room (GESINUR). Heart Rhythm. 2014 Nov;11(11):2035-44. doi: 10.1016/j.hrthm.2014.06.037. PMID: 24993462. Exclusion Code: X2.24993462
340 Perino AC, Soofi M, Singh N, . The long-term prognostic value of the Q wave criteria for prior myocardial infarction recommended in the universal definition of myocardial infarction. J Electrocardiol. 2015 Sep-Oct;48(5):798-802. doi: 10.1016/j.jelectrocard.2015.07.004. PMID: 26233646. Exclusion Code: X4.26233646
341 Peters RK, Cady LD, Jr., Bischoff DP, . Physical fitness and subsequent myocardial infarction in healthy workers. JAMA. 1983 Jun 10;249(22):3052-6. PMID: 6854827. Exclusion Code: X5.6854827
342 Pfister R, Cairns R, Erdmann E, . Prognostic impact of electrocardiographic signs in patients with Type 2 diabetes and cardiovascular disease: results from the PROactive study. Diabet Med. 2011 Oct;28(10):1206-12. doi: 10.1111/j.14645491.2011.03281.x. PMID: 21388447. Exclusion Code: X2.21388447
343 Pittaras AM, Faselis C, Doumas M, . Heart rate at rest, exercise capacity, and mortality risk in veterans. Am J Cardiol. 2013 Nov 15;112(10):1605-9. doi: 10.1016/j.amjcard.2013.07.042. PMID: 24035162. Exclusion Code: X2.24035162
344 Pontone G, Andreini D, Bartorelli AL, . A long-term prognostic value of CT angiography and exercise ECG in patients with suspected CAD. JACC Cardiovasc Imaging. 2013 Jun;6(6):641-50. doi: 10.1016/j.jcmg.2013.01.015. PMID: 23764093. Exclusion Code: X2.23764093
345 Porthan K, Viitasalo M, Jula A, . Predictive value of electrocardiographic QT interval and T-wave morphology parameters for all-cause and cardiovascular mortality in a general population sample. Heart Rhythm. 2009 Aug;6(8):1202-8, 8.e1. doi: 10.1016/j.hrthm.2009.05.006. PMID: 19632634. Exclusion Code: X5.19632634
346 Prineas RJ, Grandits G, Rautaharju PM, . Long-termprognostic significance of isolated minor electrocardiographic T-wave abnormalities in middle-aged men free of clinical cardiovascular disease (The Multiple Risk Factor Intervention Trial [MRFIT]). Am J Cardiol. 2002 Dec 15;90(12):1391-5. PMID: 12480053. Exclusion Code: X5.12480053
347 Prineas RJ, Rautaharju PM, Grandits G, . Independent risk for cardiovascular disease predicted by modified continuous score electrocardiographic criteria for 6-year incidence and regression of left ventricular hypertrophy among clinically disease free men: 16-year follow-up for the multiple risk factor intervention trial. J Electrocardiol. 2001 Apr;34(2):91-101. PMID: 11320456. Exclusion Code: X5.11320456
348 Puddu PE, Menotti A, Tolonen H, . Determinants of 40-year all-cause mortality in the European cohorts of the Seven Countries Study. Eur J Epidemiol. 2011 Aug;26(8):595-608. doi: 10.1007/s10654011-9600-7. PMID: 21713523. Exclusion Code: X5.21713523
349 Qureshi W, Shah AJ, Salahuddin T, . Long-termmortality risk in individuals with atrial or ventricular premature complexes (results from the Third National Health and Nutrition Ex amination Survey). Am J Cardiol. 2014 Jul 1;114(1):59-64. doi: 10.1016/j.amjcard.2014.04.005. PMID: 24819898. Exclusion Code: X5.24819898
350 Qureshi WT, Alirhayim Z, Blaha MJ, . Cardiorespiratory Fitness and Risk of Incident Atrial Fibrillation: Results From the Henry Ford Exercise Testing (FIT) Project. Circulation. 2015 May 26;131(21):1827-34. doi: 10.1161/circulationaha.114.014833. PMID: 25904645. Exclusion Code: X2.25904645
351 Rafique AM, Biner S, Ray I, . Metaanalysis of prognostic value of stress testing in patients with asymptomatic severe aortic stenosis. Am J Cardiol. 2009 Oct 1;104(7):972-7. doi: 10.1016/j.amjcard.2009.05.044. PMID: 19766766. Exclusion Code: X2.19766766
352 Rai M, Baker WL, Parker MW, . Metaanalysis of optimal risk stratification in patients >65 years of age. Am J Cardiol. 2012 Oct 15;110(8):1092-9. doi: 10.1016/j.amjcard.2012.05.048. PMID: 22795509. Exclusion Code: X7.22795509
353 Rangel MO, O’Neal WT, Soliman EZ. Usefulness of the Electrocardiographic PWave Axis as a Predictor of Atrial Fibrillation. Am J Cardiol. 2016 Jan 1;117(1):100-4. doi: 10.1016/j.amjcard.2015.10.013. PMID: 26552511. Exclusion Code: X2.26552511
354 Rassi CH, Churchill TW, Tavares CA, . Use of imaging and clinical data to screen for cardiovascular disease in asymptomatic diabetics. Cardiovasc Diabetol. 2016 Feb 09;15:28. doi: 10.1186/s12933-016-0334-4. PMID: 26861208. Exclusion Code: X4.26817691
355 Rautaharju PM, Ge S, Nelson JC, . Comparison of mortality risk for electrocardiographic abnormalities in men and women with and without coronary heart disease (from the Cardiovascular Health Study). Am J Cardiol. 2006 Feb 1;97(3):309-15. doi: 10.1016/j.amjcard.2005.08.046. PMID: 16442387. Exclusion Code: X5.16442387
356 Rautaharju PM, Kooperberg C, Larson JC, . Electrocardiographic abnormalities that predict coronary heart disease events and mortality in postmenopausal women: the Women’s Health Initiative. Circulation. 2006 Jan 31;113(4):473-80. doi: 10.1161/CIRCULATIONAHA.104.496091. PMID: 16449726. Exclusion Code: X5.16449726
357 Rautaharju PM, Kooperberg C, Larson JC, . Electrocardiographic predictors of incident congestive heart failure and allcause mortality in postmenopausal women: the Women’s Health Initiative. Circulation. 2006 Jan 31;113(4):481-9. doi: 10.1161/CIRCULATIONAHA.105.537415. PMID: 16449727. Exclusion Code: X5.16449727
358 Rautaharju PM, Prineas RJ, Eifler WJ, . Prognostic value of exercise electrocardiogram in men at high risk of future coronary heart disease: Multiple Risk Factor Intervention Trial experience. J Am Coll Cardiol. 1986 Jul;8(1):1-10. PMID: 3711503. Exclusion Code: X5.3711503
359 Rautaharju PM, Zhang ZM, Haisty WK, Jr., . Electrocardiographic predictors of incident heart failure in men and women free from manifest cardiovascular disease (from the Atherosclerosis Risk in Communities [ARIC] study). Am J Cardiol. 2013 Sep 15;112(6):843-9. doi: 10.1016/j.amjcard.2013.05.011. PMID: 23768456. Exclusion Code: X4.23768456
360 Rautaharju PM, Zhang ZM, Vitolins M, . Electrocardiographic repolarizationrelated variables as predictors of coronary heart disease death in the women’s health initiative study. J Am Heart Assoc. 2014 Aug;3(4)doi: 10.1161/jaha.114.001005. PMID: 25074699. Exclusion Code: X5.25074699
361 Rautaharju PM, Zhang ZM, Warren J, . Electrocardiographic predictors of coronary heart disease and sudden cardiac deaths in men and women free from cardiovascular disease in the Atherosclerosis Risk in Communities study. J Am Heart Assoc. 2013 Jun;2(3):e000061. doi: 10.1161/jaha.113.000061. PMID: 23723252. Exclusion Code: X4.23723252
362 Ravera M, Cannavo R, Noberasco G, . High performance of a risk calculator that includes renal function in predicting mortality of hypertensive patients in clinical application. J Hypertens. 2014 Jun;32(6):1245-54. doi: 10.1097/hjh.0000000000000177. PMID: 24751593. Exclusion Code: X3.24751593
363 Reissigova J, Zvarova J. The Framingham risk function underestimated absolute coronary heart disease risk in Czech men. Methods Inf Med. 2007;46(1):43-9. PMID: 17224979. Exclusion Code: X3.17224979
364 Rich JD, Chen S, Ward RP. Comparison of high risk stress myocardial perfusion imaging findings in men with rapid versus prolonged recovery of ST-segment depression after exercise stress testing. Am J Cardiol. 2010 May 15;105(10):1361-4. doi: 10.1016/j.amjcard.2009.12.061. PMID: 20451679. Exclusion Code: X3.20451679
365 Rich JD, Thenappan T, Freed B, . QTc prolongation is associated with impaired right ventricular function and predicts mortality in pulmonary hypertension. Int J Cardiol. 2013 Aug 10;167(3):669-76. doi: 10.1016/j.ijcard.2012.03.071. PMID: 22459397. Exclusion Code: X4.22459397
366 Ridker PM, Buring JE, Rifai N, . Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA. 2007 Feb 14;297(6):611-9. doi: 10.1001/jama.297.6.611. PMID: 17299196. Exclusion Code: X3.17299196
367 Ridker PM, Paynter NP, Rifai N, . Creactive protein and parental history improve global cardiovascular risk prediction: the Reynolds Risk Score for men. Circulation. 2008 Nov 25;118(22):2243-51, 4p following 51. doi: 10.1161/CIRCULATIONAHA.108.814251. PMID: 18997194. Exclusion Code: X3.18997194
368 Rizk DV, Gutierrez O, Levitan EB, . Prevalence and prognosis of unrecognized myocardial infarctions in chronic kidney disease. Nephrol Dial Transplant. 2012 Sep;27(9):3482-8. doi: 10.1093/ndt/gfr684. PMID: 22167594. Exclusion Code: X2.22167594
369 Rodrigues TC, Ehrlich J, Hunter CM, . Reduced heart rate variability predicts progression of coronary artery calcification in adults with type 1 diabetes and controls without diabetes. Diabetes Technol Ther. 2010 Dec;12(12):963-9. doi: 10.1089/dia.2010.0070. PMID: 21128843. Exclusion Code: X5.21128843
370 Rollin A, Maury P, Kee F, . Isolated negative T waves in the general population is a powerful predicting factor of cardiac mortality and coronary heart disease. Int J Cardiol. 2016 Jan 15;203:318-24. doi: 10.1016/j.ijcard.2015.10.118. PMID: 26523363. Exclusion Code: X5.26523363
371 Rosengarten JA, Scott PA, Morgan JM. Fragmented QRS for the prediction of sudden cardiac death: a meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):epub. PMID: DARE-12014061825. Exclusion Code: X5.
372 Rowin EJ, Maron BJ, Appelbaum E, . Significance of false negative electrocardiograms in preparticipation screening of athletes for hypertrophic cardiomyopathy. Am J Cardiol. 2012 Oct 1;110(7):1027-32. doi: 10.1016/j.amjcard.2012.05.035. PMID: 22809754. Exclusion Code: X2.22809754
373 Rutter MK, Wahid ST, McComb JM, . Significance of silent ischemia and microalbuminuria in predicting coronary events in asymptomatic patients with type 2 diabetes. J Am Coll Cardiol. 2002 Jul 3;40(1):56-61. PMID: 12103256. Exclusion Code: X5.12103256
374 Rywik TM, O’Connor FC, Gittings NS, . Role of nondiagnostic ex ercise-in d uced ST-segment abnormalities in predicting future coronary events in as ymptomatic volunteers. Circulation. 2002 Nov 26;106(22):2787-92. PMID: 12451004. Exclusion Code: X5.12451004
375 Rywik TM, Zink RC, Gittings NS, . Independent prognostic significance of ischemic ST-segment response limited to recovery from treadmill exercise in asymptomatic subjects. Circulation. 1998 Jun 2;97(21):2117-22. PMID: 9626171. Ex clusion Code: X5.9626171
376 Saguner AM, Ganahl S, Baldinger SH, . Usefulness of electrocardiographic parameters for risk prediction in arrhythmogenic right ventricular dysplasia. Am J Cardiol. 2014 May 15;113(10):1728-34. doi: 10.1016/j.amjcard.2014.02.031. PMID: 24792740. Exclusion Code: X2.24792740
377 Salles GF, Cardoso CR, Fiszman R, . Prognostic impact of baseline and serial changes in electrocardiographic left ventricular hypertrophy in resistant hypertension. Am Heart J. 2010 May;159(5):833-40. doi: 10.1016/j.ahj.2010.02.012. PMID: 20435193. Exclusion Code: X2.20435193
378 Salles GF, Cardoso CR, Fonseca LL, . Prognostic significance of baseline heart rate and its interaction with beta-blocker use in resistant hypertension: a cohort study. Am J Hypertens. 2013 Feb;26(2):218-26. doi: 10.1093/ajh/hps004.PMID:23382406. Exclusion Code: X2.23382406
379 Salles GF, Cardoso CR, Muxfeldt ES. Prognostic value of ventricular repolarization prolongation in resistant hypertension: a prospective cohort study. J Hypertens. 2009 May;27(5):1094-101. doi: 10.1097/HJH.0b013e32832720b3. PMID: 19390353. Exclusion Code: X2.19390353
380 Santhanakris hnan R, W ang N, Larson MG, . Racial Differences in Electrocardiographic Characteristics and Prognostic Significance in Whites Versus As ians. J Am Heart Assoc. 2016 Mar 25;5(3):e002956. doi: 10.1161/jaha.115.002956. PMID: 27016575. Exclusion Code: X5.27016575
381 Savonen KP, Kiviniemi V, Laaksonen DE, . Two-minute heart rate recovery after cycle ergometer exercise and all-cause mortality in middle-aged men. J Intern Med. 2011 Dec;270(6):589-96. doi: 10.1111/j.1365-2796.2011.02434.x. PMID: 21801244. Exclusion Code: X4.21801244
382 Savonen KP, Lakka TA, Laukkanen JA, . Effectiveness of workload at the heart rate of 100 beats/min in predicting cardiovascular mortality in men aged 42, 48, 54, or 60 years at baseline. Am J Cardiol. 2007 Aug 15;100(4):563-8. doi: 10.1016/j.amjcard.2007.03.061. PMID: 17697806. Exclusion Code: X5.17697806
383 Schelbert EB, Cao JJ, Sigurdsson S, . Prevalence and prognosis of unrecognized myocardial infarction determined by cardiac magnetic resonance in older adults. Jama. 2012 Sep 5;308(9):890-6. doi: 10.1001/2012.jama.11089. PMID: 22948699. Exclusion Code: X2.22948699
384 Scheltens T, Verschuren WM, Boshuizen HC, . Estimation of cardiovascular risk: a comparison between the Framingham and the SCORE model in people under 60 years of age. Eur J Cardiovasc Prev Rehabil. 2008 Oct;15(5):562-6. doi: 10.1097/HJR.0b013e3283063a65. PMID: 18756178. Exclusion Code: X3.18756178
385 Schinkel AF, Boiten HJ, van der Sijde JN, . Prediction of 9-year cardiovascular outcomes by myocardial perfusion imaging in patients with normal exercise electrocardiographic testing. Eur Heart J Cardiovasc Imaging. 2012 Nov;13(11):900-4. doi: 10.1093/ehjci/jes104. PMID: 22588207. Exclusion Code: X2.22588207
386 Schinkel AF, Elhendy A, van Domburg RT, . Prognostic significance of QRS duration in patients with suspected coronary artery disease referred for noninvasive evaluation of myocardial ischemia. Am J Cardiol. 2009 Dec 1;104(11):1490-3. doi: 10.1016/j.amjcard.2009.07.012. PMID: 19932780. Exclusion Code: X5.19932780
387 Schlegel TT, Kulecz WB, Feiveson AH, . Accuracy of advanced versus strictly conventional 12-lead ECG for detection and screening of coronary artery disease, left ventricular hypertrophy and left ventricular systolic dysfunction. BMC Cardiovasc Disord. 2010;10:28. doi: 10.1186/1471-2261-10-28. PMID: 20565702. Exclusion Code: X3.20565702
388 Schmidt C, Bergstrom G. Apolipoprotein B/apolipoprotein A-I ratio and apolipoprotein B: long-term predictors of myocardial infarction in initially healthy middle-aged men--a 13-year follow-up. Angiology. 2014 Nov;65(10):901-5. doi: 10.1177/0003319713511849. PMID: 24277914. Exclusion Code: X3.24277914
389 Schnabel RB, Rienstra M, Sullivan LM, . Risk assessment for incident heart failure in individuals with atrial fibrillation. Eur J Heart Fail. 2013 Aug; 15(8):843-9. doi: 10.1093/eurjhf/hft041. PMID: 23594831. Exclusion Code: X2.23594831
390 Scholte AJ, Schuijf JD, Kharagjitsingh AV, . Prevalence and predictors of an abnormal stress myocardial perfusion study in asymptomatic patients with type 2 diabetes mellitus. Eur J Nucl Med Mol Imaging. 2009 Apr;36(4):567-75. doi: 10.1007/s00259-008-0967-y. PMID: 18985347. Exclusion Code: X3.18985347
391 Schouten O, van Kuijk JP, Flu WJ, . Long-term outcome of prophylactic coronary revascularization in cardiac high-risk patients undergoing major vascular surgery (from the randomized DECREASE-V Pilot Study). Am J Cardiol. 2009 Apr 1;103(7):897-901. doi: 10.1016/j.amjcard.2008.12.018. PMID: 19327412. Exclusion Code: X2.19327412
392 Schroder K, Wegscheider K, W enger NK, . Resting electrocardiogram predicts mortality in postmenopausal women with coronary heart disease or with risk factors for coronary heart disease. Eur J Prev Cardiol. 2014 Jun;21(6):749-57. doi: 10.1177/2047487312454022. PMID: 22752417. Exclusion Code: X2.22752417
393 Schultz MG, Otahal P, Cleland VJ, . Exercise-induced hypertension, cardiovascular events, and mortality in patients undergoing exercise stress testing: a systematic review and meta-analysis. Am J Hypertens. 2013 Mar;26(3):357-66. doi: 10.1093/ajh/hps053. PMID: 23382486. Exclusion Code: X7.23382486
394 Scott AC, Bilesky J, Lamanna A, . Limited utility of exercise stress testing in the evaluation of suspected acute coronary syndrome in patients aged less than 40 years with intermediate risk features. Emerg Med Australas. 2014 Apr;26(2):170-6. doi: 10.1111/1742-6723.12222. PMID: 24708007. Exclusion Code: X2.24708007
395 Seicean S, Strohl KP, Seicean A, . Sleep disordered breathing as a risk of cardiac events in subjects with diabetes mellitus and normal exercise echocardiographic findings. Am J Cardiol. 2013 Apr 15;111(8):1214-20. doi: 10.1016/j.amjcard.2012.12.053. PMID: 23415514. Exclusion Code: X2.23415514
396 Sellers MB, Divers J, Lu L, . Prevalence and determinants of electrocardiographic abnormalities in African Americans with type 2 diabetes. J Epidemiol Glob Health. 2014 Dec;4(4):289-96. doi: 10.1016/j.jegh.2014.04.003. PMID: 25455646. Exclusion Code: X5.25455646
397 Shah B, Bangalore S, Gianos E, . Temporal trends in clinical characteristics of patients without known cardiovascular disease with a first episode of myocardial infarction. Am Heart J. 2014 Apr;167(4):480-8.e1. doi: 10.1016/j.ahj.2013.12.019. PMID: 24655696. Exclusion Code: X7.24655696
398 Shah SA, Kambur T, Chan C, . Relation of short-term heart rate variability to incident heart failure (from the Multi-Ethnic Study of Atherosclerosis). Am J Cardiol. 2013 Aug 15;112(4):533-40. doi: 10.1016/j.amjcard.2013.04.018. PMID: 23683953. Exclusion Code: X4.23683953
399 Shah SF, Meo SA. Usefulness of standard treadmill stress testing in women. J Pak Med Assoc. 2009 Apr;59(4):197-200. PMID: 19402276. Exclusion Code: X2.19402276
400 Shaw LJ, Min JK, Budoff M, . Induced cardiovascular procedural costs and resource consumption patterns after coronary artery calcium screening: results from the EISNER (Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research) study. J Am Coll Cardiol. 2009 Sep 29;54(14):1258-67. doi: 10.1016/j.jacc.2009.07.018. PMID: 19778667. Exclusion Code: X3.19778667
401 Shaw LJ, Wilson PW, Hachamovitch R, . Improved near-term coronary artery disease risk classification with gated stress myocardial perfusion SPECT. JACC Cardiovasc Imaging. 2010 Nov;3(11):1139-48. doi: 10.1016/j.jcmg.2010.09.008. PMID: 21071002. Exclusion Code: X3.21071002
402 Shaya GE, Al-Mallah MH, Hung RK, . High Exercise Capacity Attenuates the Risk of Early Mortality After a First Myocardial Infarction: The Henry Ford Exercise Testing (FIT) Project. Mayo Clin Proc. 2016 Feb;91(2):129-39. doi: 10.1016/j.mayocp.2015.11.012. PMID: 26848000. Exclusion Code: X2.26848000
403 Shibasaki K, Ogawa S, Yamada S, . Association of decreased sympathetic nervous activity with mortality of older adults in long-term care. Geriatr Gerontol Int. 2014 Jan;14(1):159-66. doi: 10.1111/ggi.12074. PMID: 23879364. Exclusion Code: X2.23879364
404 Shin SY, Park JI, Park SK, . Utility of graded exercise tolerance tests for prediction of cardiovascular mortality in old age: The Rancho Bernardo Study. Int J Cardiol. 2015 Feb 15;181:323-7. doi: 10.1016/j.ijcard.2014.12.026. PMID: 25544200. Exclusion Code: X5.25544200
405 Shiraishi J, Sawada T, Kimura S, . Enhanced cardiovascular protective effects of valsartan in high-risk hypertensive patients with left ventricular hypertrophy--sub-analysis of the KYOTO HEART study. Circ J. 2011;75(4):806-14. PMID: 21436597. Exclusion Code: X2.21436597
406 Sigurdsson E, Sigfusson N, Sigvaldason H, . Silent ST-T changes in an epidemiologic cohort study--a marker of hypertension or coronary heart disease, or both: the Reykjavik study. J Am Coll Cardiol. 1996 Apr;27(5):1140-7. doi: 10.1016/0735-1097(95)00614-1. PMID: 8609333. Exclu s io n Co d e: X5.8609333
407 Silventoinen K, Pankow J, Lindstrom J, . The validity of the Finnish Diabetes Risk Score for the prediction of the incidence of coronary heart disease and stroke, and total mortality. Eur J Cardiovasc Prev Rehabil. 2005 Oct;12(5):451-8. PMID: 16210931. Ex clusion Code: X3.16210931
408 Simmons RK, Sharp S, Boekholdt SM, . Evaluation of the Framingham risk score in the European Prospective Investigation of Cancer-Norfolk cohort: does adding glycated hemoglobin improve the prediction of coronary heart disease events? Arch Intern Med. 2008 Jun 9;168(11):1209-16. doi: 10.1001/archinte.168.11.1209. PMID: 18541829. Exclusion Code: X3.18541829
409 Simms AD, Weston CF, West RM, . Mortality and missed opportunities along the pathway of care for ST-elevation myocardial infarction: a national cohort study. Eur Heart J Acute Cardiovasc Care. 2015 Jun;4(3):241-53. doi: 10.1177/2048872614548602. PMID: 25228048. Exclusion Code: X2.25228048
410 Simons LA, Simons J, Friedlander Y, . Risk functions for prediction of cardiovascular disease in elderly Australians: the Dubbo Study. Med J Aust. 2003 Feb 3;178(3):113-6. PMID: 12558481. Exclusion Code: X3.12558481
411 Sinner MF, Reinhard W, Muller M, . Association of early repolarization pattern on ECG with risk of cardiac and all-cause mortality: a population-based prospective cohort study (MONICA /KORA). PLoS Med. 2010 Jul;7(7):e1000314. doi: 10.1371/journal.pmed.1000314. PMID: 20668657. Exclusion Code: X5.20668657
412 Siscovick DS, Ekelund LG, Johnson JL, . Sensitivity of exercise electrocardiography for acute cardiac events during moderate and strenuous physical activity. The Lipid Research Clinics Coronary Primary Prevention Trial. Arch Intern Med. 1991 Feb;151(2):325-30. PMID: 1992960. Exclusion Code: X4.1992960
413 Skalski J, Allis on TG, Miller TD. The safety of cardiopulmonary exercise testing in a population with high-risk cardiovascular diseases. Circulation. 2012 Nov 20;126(21):2465-72. doi: 10.1161/circulationaha.112.110460. PMID: 23091065. Exclusion Code: X2.23091065
414 Skretteberg PT, Grundvold I, Kjeldsen SE, . HDL-cholesterol and prediction of coronary heart disease: modified by physical fitness? A 28-year follow-up of apparently healthy men. Atherosclerosis. 2012 Jan;220(1):250-6. doi: 10.1016/j.atherosclerosis.2011.10.009. PMID: 22062589. Exclusion Code: X3.22062589
415 Slattery ML, Jacobs DR, Jr. Physical fitness and cardiovascular disease mortality. The US Railroad Study. Am J Epidemiol. 1988 Mar;127(3):571-80. PMID: 3341361. Exclusion Code: X5.3341361
416 Smetana P, Schmidt A, Zabel M, . Assessment of repolarization heterogeneity for prediction of mortality in cardiovascular disease: peak to the end of the T wave interval and nondipolar repolarization components. J Electrocardiol. 2011 May-Jun;44(3):301-8. doi: 10.1016/j.jelectrocard.2011.03.004. PMID: 21511064. Exclusion Code: X2.21511064
417 Smith JG, Platonov PG, Hedblad B, . Atrial fibrillation in the Malmo Diet and Cancer study: a study of occurrence, risk factors and diagnostic validity. Eur J Epidemiol. 2010 Feb;25(2):95-102. doi: 10.1007/s10654-009-9404-1. PMID: 19936945. Exclusion Code: X5.19936945
418 Snoek JA, Jongman JK, Brandon T, . Performance of the Lausanne questionnaire and the 2010 European Society of Cardiology criteria for ECG interpretation in athletes. Eur J Prev Cardiol. 2015 Mar;22(3):397-405. doi: 10.1177/2047487313506827. PMID: 24057687. Exclusion Code: X5.24057687
419 Soliman EZ, Cammarata M, Li Y. Explaining the inconsistent associations of PR interval with mortality: the role of P-duration contribution to the length of PR interval. Heart Rhythm. 2014 Jan;11(1):93-8. doi: 10.1016/j.hrthm.2013.10.003. PMID: 24096163. Exclusion Code: X2.24096163
420 Soliman EZ, Els alam MA, Li Y. The relationship between high resting heart rate and ventricular arrhythmogenesis in patients referred to ambulatory 24h electrocardiographic recording. Europace. 2010 Feb;12(2):261-5. doi: 10.1093/europace/eup344. PMID: 19887457. Exclusion Code: X2.19887457
421 Soliman EZ, Howard G, Cushman M, . Prolongation of QTc and risk of stroke: The REGARDS (REasons for Geographic and Racial Differences in Stroke) study. J Am Coll Cardiol. 2012 Apr 17;59(16):1460-7. doi: 10.1016/j.jacc.2012.01.025. PMID: 22497826. Exclusion Code: X2.22497826
422 Soliman EZ, Howard G, Meschia JF, . Self-reported atrial fibrillation and risk of stroke in the Reasons for Geographic and Racial Differences in Stroke (REGARDS) study. Stroke. 2011 Oct;42(10):2950-3. doi: 10.1161/strokeaha.111.621367. PMID: 21817138. Exclusion Code: X5.21817138
423 Soliman EZ, Lopez F, O’Neal WT, . Atrial Fibrillation and Risk of ST-Segment-Elevation Versus Non-ST-Segment-Elevation Myocardial Infarction: The Atherosclerosis Risk in Communities (ARIC) Study. Circulation. 2015 May 26;131(21):1843-50. doi: 10.1161/circulationaha.114.014145. PMID: 25918127. Ex clusion Code: X4.25918127
424 Soliman EZ, Prineas RJ. Early repolarization and sudden cardiac death. South Med J. 2009 Jan;102(1):110-1. doi: 10.1097/SMJ.0b013e31818fbe44. PMID: 19077760. Exclusion Code: X7.19077760
425 Soliman EZ, Shah AJ, Boerkircher A, . Inter-relationship between electrocardiographic left ventricular hypertrophy and QT prolongation as predictors of increased risk of mortality in the general population. Circ Arrhythm Electrophysiol. 2014 Jun;7(3):400-6. doi: 10.1161/circep.113.001396. PMID: 24762807. Exclusion Code: X5.24762807
426 Soliman EZ, Zhang ZM, Chen LY, . Usefulness of Maintaining a Normal Electrocardiogram Over Time for Predicting Cardiovascular Health. Am J Cardiol. 2017 Jan 15;119(2):249-55. doi: 10.1016/j.amjcard.2016.09.051. PMID: 28126148. Exclusion Code: X2.28126148
427 Soofi M, Jain NA, Myers J, . A New 12-Lead ECG Prognostic Score. Ann Noninvasive Electrocardiol. 2015 Nov;20(6):554-60. doi: 10.1111/anec.12261. PMID: 25640186. Exclusion Code: X4.25640186
428 Stacey RB, Leaverton PE, Schocken DD, . Prediabetes and the association with unrecognized myocardial infarction in the multi-ethnic study of atherosclerosis. Am Heart J. 2015 Nov;170(5):923-8. doi: 10.1016/j.ahj.2015.08.003. PMID: 26542500. Exclusion Code: X3.26542500
429 Stavrakis S, Patel N, Te C, . Development and validation of a prognostic index for risk stratification of patients with early repolarization. Ann Noninvasive Electrocardiol. 2012 Oct;17(4):361-71. doi: 10.1111/j.1542-474X.2012.00533.x. PMID: 23094882. Exclusion Code: X7.23094882
430 Stefanini GG, Kalesan B, Pilgrim T, . Impact of sex on clinical and angiographic outcomes among patients undergoing revascularization with drug-eluting stents. JACC Cardiovasc Interv. 2012 Mar;5(3):301-10. doi: 10.1016/j.jcin.2011.11.011. PMID: 22440496. Exclusion Code: X2.22440496
431 Stein PK, Barzilay JI, Chaves PH, . Heart rate variability and its changes over 5 years in older adults. Age Ageing. 2009 Mar;38(2):212-8. doi: 10.1093/ageing/afn292. PMID: 19147739. Exclusion Code: X3.19147739
432 Stein R, Nguyen P, Abella J, . Prevalence and prognostic significance of exercise-induced right bundle branch block. Am J Cardiol. 2010 Mar 1;105(5):677-80. doi: 10.1016/j.amjcard.2009.10.050. PMID: 20185016. Exclusion Code: X2.20185016
433 St ein R, Sallam K, Adhikarla C, . Natural history of early repolarization in the inferior leads. Ann Noninvasive Electrocardiol. 2012 Oct;17(4):331-9. doi: 10.1111/j.1542-474X.2012.00537.x. PMID: 23094879. Exclusion Code: X7.23094879
434 Stephens JW, Ambler G, Vallance P, . Cardiovascular risk and diabetes. Are the methods of risk prediction satisfactory? Eur J Cardiovasc Prev Rehabil. 2004 Dec;11(6):521-8. PMID: 15580065. Exclusion Code: X3.15580065
435 Stern MP, W illiams K, Gonzalez-Villalpando C, . Does the metabolic syndrome improve identification of individuals at risk of type 2 diabetes and/or cardiovascular disease? Diabetes Care. 2004 Nov;27(11):2676-81. PMID: 15505004. Exclusion Code: X3.15505004
436 Stewart RA, Young AA, Anderson C, . Relationship between QRS duration and left ventricular mass and volume in patients at high cardiovascular risk. Heart. 2011 Nov;97(21):1766-70. doi: 10.1136/heartjnl-2011-300297. PMID: 21835757. Exclusion Code: X5.21835757
437 Stiles MC, Seaquist ER, Yale JF, . Is silent myocardial infarction more common in women with type 2 diabetes than in men? J Diabetes Complications. 2012 Mar-Apr;26(2):118-22. doi: 10.1016/j.jdiacomp.2012.02.002. PMID: 22446034. Exclusion Code: X5.22446034
438 Strom Moller C, Zethelius B, Sundstrom J, . Persistent ischaemic ECG abnormalities on repeated ECG examination have important prognostic value for cardiovascular disease beyond established risk factors: a population-based study in middle-aged men with up to 32 years of follow-up. Heart. 2007 Sep;93(9):1104-10. doi: 10.1136/hrt.2006.109116. PMID: 17483125. Exclusion Code: X10.17483125
439 Suadicani P, Hein HO, Gyntelberg F. Antihypertensive treatment, high triglycerides, and low high-density lipoprotein cholesterol and risk of ischemic heart disease mortality: a 16-year follow-up in the Copenhagen male study. Metab Syndr Relat Disord. 2010 Jun;8(3):215-22. doi: 10.1089/met.2009.0072. PMID: 20156073. Exclusion Code: X5.20156073
440 Suh B, Park S, Shin DW, . Early repolarization is as sociated with significant coronary artery stenosis in as ymptomatic adults. Atherosclerosis. 2016 Feb;245:50-3. doi: 10.1016/j.atherosclerosis.2015.11.026. PMID: 26694693. Exclusion Code: X5.26694693
441 Sui X, LaMonte MJ, Blair SN. Cardiores piratory fitness as a predictor of nonfatal cardiovascular events in asymptomatic women and men. Am J Epidemiol. 2007 Jun 15;165(12):1413-23. doi: 10.1093/aje/kwm031. PMID: 17406007. Exclusion Code: X5.17406007
442 Suka M, Sugimori H, Yoshida K. Application of the updated Framingham risk score to Japanese men. Hypertens Res. 2001 Nov;24(6):685-9. PMID: 11768728. Exclusion Code: X3.11768728
443 Suka M, Sugimori H, Yoshida K. Validity of the Framingham risk model applied to Japanese men. Methods InfMed. 2002;41(3):213-5. PMID: 12162145. Exclusion Code: X3.12162145
444 Sun Z, Ng KH. Diagnostic value of coronary CT angiography with prospective ECG-gating in the diagnosis of coronary artery disease: a systematic review and metaanalysis (Provisional abstract). International Journal of Cardiovascular Imaging. 2012;28(8):2109-19. PMID: DARE-12013001989. Exclusion Code: X3.22212661
445 Sung J, Cho SJ, Choe YH, . Relationship between aerobic fitness and progression of coronary atherosclerosis. Heart Vessels. 2016 Sep;31(9):1418-23. doi: 10.1007/s00380-015-0745-2. PMID: 26400860. Exclusion Code: X5.26400860
446 Sutherland SE, Gazes PC, Keil JE, . Electrocardiographic abnormalities and 30-year mortality among white and black men of the Charleston Heart Study. Circulation. 1993 Dec;88(6):2685-92. PMID: 8252679. Exclusion Code: X5.8252679
447 Suvisaari J, Perala J, Saarni SI, . Coronary heart disease and cardiac conduction abnormalities in persons with psychotic disorders in a general population. Psychiatry Res. 2010 Jan 30;175(1-2):126-32. doi: 10.1016/j.psychres.2008.07.021. PMID: 19926142. Exclusion Code: X2.19926142
448 Svart K, Lehtinen R, Nieminen T, . Exercise electrocardiography detection of coronary artery disease by ST-segment depression/heart rate hysteresis in women: the Finnish Cardiovascular Study. Int J Cardiol. 2010 Apr 15;140(2):182-8. doi: 10.1016/j.ijcard.2008.11.038. PMID: 19068271. Exclusion Code: X4.19068271
449 Tait J, Ashton T. Critical left main coronary artery stenosis identified by colour Doppler screening during pre-exercise stress echocardiogram. Can J Cardiol. 2011 May-Jun;27(3):390.e13-4. doi: 10.1016/j.cjca.2010.12.055. PMID: 21601777. Exclusion Code: X7.21601777
450 Takase B, Masaki N, Hattori H, . Usefulness of automatic QT dispersion measurement for detecting exercise-induced myocardial is chemia. Anadolu Kardiyol Derg. 2009 Jun;9(3):189-95. PMID: 19520652. Exclusion Code: X2.19520652
451 Teodorescu C, Reinier K, Uy-Evanado A, . Resting heart rate and risk of sudden cardiac death in the general population: influence of left ventricular systolic dysfunction and heart rate-modulating drugs. Heart Rhythm. 2013 Aug;10(8):1153-8. doi: 10.1016/j.hrthm.2013.05.009. PMID: 23680897. Exclusion Code: X2.23680897
452 Teodorescu C, Reinier K, Uy-Evanado A, . Prolonged QRS duration on the resting ECG is as sociated with sudden death risk in coronary disease, independent of prolonged ventricular repolarization. Heart Rhythm. 2011 Oct;8(10):1562-7. doi: 10.1016/j.hrthm.2011.06.011. PMID: 21699869. Exclusion Code: X2.21699869
453 Tereshchenko LG, Shah AJ, Li Y, . Electrocardiographic deep terminal negativity of the P wave in V1 and risk of mortality: the National Health and Nutrition Ex amination Survey III. J Cardiovasc Electrophysiol. 2014 Nov;25(11):1242-8. doi: 10.1111/jce.12453. PMID: 24837486. Ex clusion Code: X4.24837486
454 Tikkanen JT, Anttonen O, Junttila MJ, . Long-term outcome associated with early repolarization on electrocardiography. N Engl J Med. 2009 Dec 24;361(26):2529-37. doi: 10.1056/NEJMoa0907589. PMID: 19917913. Exclusion Code: X5.19917913
455 Tikkanen JT, Huikuri HV. Early repolarization ECG pattern in the Finnish general population. J Electrocardiol. 2013 Sep-Oct;46(5):439-41. doi: 10.1016/j.jelectrocard.2013.06.012. PMID: 23871658. Exclusion Code: X7.23871658
456 Tikkanen JT, Junttila MJ, Anttonen O, . Early repolarization: electrocardiographic phenotypes associated with favorable long-term outcome. Circulation. 2011 Jun 14;123(23):2666-73. doi: 10.1161/circulationaha.110.014068. PMID: 21632493. Exclusion Code: X5.21632493
457 Tohidi M, Hadaegh F, Harati H, . Creactive protein in risk prediction of cardiovascular outcomes: Tehran Lipid and Glucose Study. Int J Cardiol. 2009 Mar 6;132(3):369-74. doi: 10.1016/j.ijcard.2007.11.085. PMID: 18242731. Exclusion Code: X3.18242731
458 Tota-Maharaj R, Blaha MJ, Blankstein R, . Association of coronary artery calcium and coronary heart disease events in young and elderly participants in the multi-ethnic study of atherosclerosis: a secondary analysis of a prospective, population-based cohort. Mayo Clin Proc. 2014 Oct;89(10):1350-9. doi: 10.1016/j.mayocp.2014.05.017. PMID: 25236430. Exclusion Code: X3.25236430
459 Turakhia MP, Ullal AJ, Hoang DD, . Feasibility of extended ambulatory electrocardiogram monitoring to identify silent atrial fibrillation in high-risk patients: the Screening Study for Undiagnosed Atrial Fibrillation (STUDY-AF). Clin Cardiol. 2015 May;38(5):285-92. doi: 10.1002/clc.22387. PMID: 25873476. Exclusion Code: X4.25873476
460 Uberoi A, Sallam K, Perez M, . Prognostic implications of Q waves and T-wave inversion associated with early repolarization. Mayo Clin Proc. 2012 Jul;87(7):614-9. doi: 10.1016/j.mayocp.2012.04.009. PMID: 22766081. Exclusion Code: X7.22766081
461 Ulmer H, Kollerits B, Kelleher C, . Predictive accuracy of the SCORE risk function for cardiovascular disease in clinical practice: a prospective evaluation of 44 649 Austrian men and women. Eur J Cardiovasc Prev Rehabil. 2005 Oct;12(5):433-41. PMID: 16210929. Exclusion Code: X3.16210929
462 Uthamalingam S, Zheng H, Leavitt M, . Exercise-induced ST-segment elevation in ECG lead a VR is a useful indicator of significant left main or ostial LAD coronary artery stenosis. JACC Cardiovasc Imaging. 2011 Feb;4(2):176-86. doi: 10.1016/j.jcmg.2010.11.014. PMID: 21329903. Exclusion Code: X2.21329903
463 Vaara S, Nieminen MS, Lokki ML, . Cohort Profile: the Corogene study. Int J Epidemiol. 2012 Oct;41(5):1265-71. doi: 10.1093/ije/dyr090. PMID: 21642350. Exclusion Code: X2.21642350
464 Vaidya D, Yanek LR, Moy TF, . Incidence of coronary artery disease in siblings of patients with premature coronary artery disease: 10 years of follow-up. Am J Cardiol. 2007 Nov 1;100(9):1410-5. doi: 10.1016/j.amjcard.2007.06.031. PMID: 17950799. Exclusion Code: X3.17950799
465 Vakil KP, Malhotra S, Sawada S, . Waist circumference and metabolic syndrome: the risk for silent coronary artery disease in males. Metab Syndr Relat Disord. 2012 Jun;10(3):225-31. doi: 10.1089/met.2011.0099. PMID: 22324791. Exclusion Code: X7.22324791
466 van Noord C, Sturkenboom MC, Straus SM, . Serum glucose and insulin are associated with QTc and RR intervals in nondiabetic elderly. Eur J Endocrinol. 2010 Feb;162(2):241-8. doi: 10.1530/eje-09-0878. PMID: 19897609. Exclusion Code: X5.19897609
467 Vandvik PO, Lincoff AM, Gore JM, . Primary and secondary prevention of cardiovascular disease: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012 Feb;141(2 Suppl):e637S-68S. doi: 10.1378/chest.11-2306. PMID: 22315274. Exclusion Code: X7.22315274
468 Vepsalainen T, Laakso M, Lehto S, . Prolonged P wave duration predicts stroke mortality among type 2 diabetic patients with prevalent non-major macrovascular disease. BMC Card iovasc Disord. 2014;14:168. doi: 10.1186/1471-2261-14-168. PMID: 25425321. Exclusion Code: X5.25425321
469 Verdecchia P, Reboldi G, Di Pasquale G, . Prognostic usefulness of left ventricular hypertrophy by electrocardiography in patients with atrial fibrillation (from the Randomized Evaluation of Long-Term Anticoagulant Therapy Study). Am J Cardiol. 2014 Feb 15;113(4):669-75. doi: 10.1016/j.amjcard.2013.10.045. PMID: 24359765. Exclusion Code: X2.24359765
470 Vergnaud AC, Bertrais S, Galan P, . Ten-year risk prediction in French men using the Framingham coronary score: results from the national SU.VI.M A X cohort. Prev Med. 2008 Jul;47(1):61-5. doi: 10.1016/j.ypmed.2008.02.023. PMID: 18456313. Exclusion Code: X3.18456313
471 Vinsonneau U, Pangnarind-Heinz V, Paleiron N, . Evolution of Early Repolarization Patterns after 5 Years in a Military Population at Low Cardiovascular Risk and Practical Implications in Military Medical Expertise. Ann Noninvasive Electrocardiol. 2015 Sep;20(5):420-5. doi: 10.1111/anec.12231. PMID: 25393741. Ex clusion Code: X5.25393741
472 Vliegenthart R, Oudkerk M, Hofman A, . Coronary calcification improves cardiovascular risk prediction in the elderly. Circulation. 2005 Jul 26;112(4):572-7. doi: 10.1161/CIRCULATIONAHA.104.488916. PMID: 16009800. Exclusion Code: X3.16009800
473 von Ziegler F, Greif M, Tittus J, . Distribution of coronary calcifications in patients with suspected coronary heart disease. Am Heart J. 2014 Apr;167(4):568-75. doi: 10.1016/j.ahj.2013.12.011. PMID: 24655707. Exclusion Code: X2.24655707
474 Waks JW, Sitlani CM, Soliman EZ, . Global Electric Heterogeneity Risk Score for Prediction of Sudden Cardiac Death in the General Population: The Atherosclerosis Risk in Communities (ARIC) and Cardiovascular Health (CHS) Studies. Circulation. 2016 Jun 07;133(23):2222-34. doi: 10.1161/circulationaha.116.021306. PMID: 27081116. Exclusion Code: X4.27081116
475 Waks JW, Soliman EZ, Henrikson CA, . Beat-to-b eat spatiotemporal variability in the T vector is associated with sudden cardiac death in participants without left ventricular hypertrophy: the Atherosclerosis Risk in Communities (ARIC) Study. J Am Heart Assoc. 2015 Jan;4(1):e001357. doi: 10.1161/jaha.114.001357. PMID: 25600143. Ex clusion Code: X3.25600143
476 Walsh JA, 3rd, Ilkhanoff L, Soliman EZ, . Natural history of the early repolarization pattern in a biracial cohort: CA RDIA (Coronary Artery Risk Development in Young Adults) Study. J Am Coll Cardiol. 2013 Feb 26;61(8):863-9. doi: 10.1016/j.jacc.2012.11.053. PMID: 23428218. Exclusion Code: X4.23428218
477 Walsh JA, 3rd, Soliman EZ, Ilkhanoff L, . Prognostic value of front al QRS-T angle in patients with out clinical evidence of cardiovascular disease (from the Multi-Ethnic Study of Atherosclerosis). Am J Cardiol. 2013 Dec 15;112(12):1880-4. doi: 10.1016/j.amjcard.2013.08.017. PMID: 24063831. Exclusion Code: X4.24063831
478 Wang Z, Hoy WE. Is the Framingham coronary heart disease absolute risk function applicable to Aboriginal people? Med J Aust. 2005 Jan 17;182(2):66-9. PMID: 15651963. Exclusion Code: X3.15651963
479 Wannamethee SG, Shaper AG, Lennon L, . Metabolic syndrome vs Framing ham Risk Score for prediction of coronary heart disease, stroke, and type 2 diabetes mellitus. Arch Intern Med. 2005 Dec 12-26;165(22):2644-50. doi: 10.1001/archinte.165.22.2644. PMID: 16344423. Exclusion Code: X3.16344423
480 Watanabe H, Makita N, Tanabe N, . Electrocardiographic abnormalities and risk of complete atrioventricular block. Int J Cardiol. 2012 Mar 22;155(3):462-4. doi: 10.1016/j.ijcard.2011.12.028. PMID: 22225759. Exclusion Code: X5.22225759
481 Waure C, Cadeddu C, Gualano MR, . Telemedicine for the reduction of myocardial infarction mortality: a systemati c review and a meta-analysis of published studies (Structured abstract). Telemedicine and e-Health. 2012;18(5):323-8. PMID: DARE-12012049125. Exclusion Code: X2.22468983
482 Weiner DE, Tighiouart H, Elsayed EF, . The Framingham predictive instrument in chronic kidney disease. J Am Coll Cardiol. 2007 Jul 17;50(3):217-24. doi: 10.1016/j.jacc.2007.03.037. PMID: 17631213. Exclusion Code: X3.17631213
483 Welsh P, Doolin O, Willeit P, . N-terminal pro-B-type natriuretic peptide and the prediction of primary cardiovascular events: res ults from 15-year follow-up of WOSCOPS. Eur Heart J. 2013 Feb;34(6):443-50. doi: 10.1093/eurheartj/ehs239. PMID: 22942340. Ex clusion Code: X3.22942340
484 Wen L, Sun ML, An P, . Frequency of supraventricular arrh ythmias in patients with idiopathic pulmonary arterial hypertension. Am J Cardiol. 2014 Nov 1;114(9):1420-25. doi: 10.1016/j.amjcard.2014.07.079. PMID: 25217453. Exclusion Code: X2.25217453
485 Wenger NK, Mischke JM, Schroeder R, . Electrocardiograms of menopausal women with coronary heart disease or at increased risk for its occurrence. Am J Cardiol. 2010 Dec 1;106(11):1580-7. doi: 10.1016/j.amjcard.2010.07.032. PMID: 21094358. Exclusion Code: X7.21094358
486 Whang W, Peacock J, Soliman EZ, . Relations between depressive symptoms, anxiety, and T Wave abnormalities in subjects with out clinically-apparent cardiovascular disease (from the Multi-Ethnic Study of Atherosclerosis [MESA]). Am J Cardiol. 2014 Dec 15;114(12):1917-22. doi: 10.1016/j.amjcard.2014.09.034. PMID: 25438922. Exclusion Code: X5.25438922
487 Wilcox JE, Rosenberg J, Vallakati A, . Usefulness of electrocardiographic QT intervalto predict left ventricular diastolic dysfunction. Am J Cardiol. 2011 Dec 15;108(12):1760-6. doi: 10.1016/j.amjcard.2011.07.050. PMID: 21907948. Exclusion Code: X2.21907948
488 Wilson PW, Bozeman SR, Burton TM, . Prediction of first events of coronary heart disease and stroke with consideration of adiposity. Circulation. 2008 Jul 8;118(2):124-30. doi: 10.1161/CIRCULATIONAHA.108.772962. PMID: 18591432. Exclusion Code: X3.18591432
489 Wilson PW, D’Agostino RB, Levy D, . Prediction of coronary heart disease using risk factor categories. Circulation. 1998 May 12;97(18):1837-47. PMID: 9603539. Exclusion Code: X3.9603539
490 Wirawan IM, Aldington S, Griffiths RF, . Cardiovascular investigations of airline pilots with excessive cardiovascular risk. Aviat Space Environ Med. 2013 Jun;84(6):608-12. PMID: 23745289. Exclusion Code: X4.23745289
491 Woodward M, Brindle P, Tuns tall-Pedoe H, . Adding social deprivation and family history to cardio vascular risk as sessment: the ASSIGN score from the Scottish Heart Health Ex tended Cohort (SHHEC). Heart. 2007 Feb;93(2):172-6. doi: 10.1136/hrt.2006.108167. PMID: 17090561. Exc lu sion Code: X3.17090561
492 Worthington JM, Gattellari M, Leung DY. ’Where there’s smoke...’: are premature ventricular complexes a new risk factor for stroke? Stroke. 2010 Apr;41(4):572-3. doi: 10.1161/strokeaha.109.574426. PMID: 20167909. Exclusion Code: X7.20167909
493 Wu Y, Liu X, Li X, . Estimation of 10-year risk of fatal and nonfatal ischemic cardiovascular diseases in Chinese adults. Circulation. 2006 Nov 21;114(21):2217-25. doi: 10.1161/CIRCULATIONAHA.105.607499. PMID: 17088464. Exclusion Code: X3.17088464
494 Wu YT, Chien CL, Wang SY, . Gender differences in myocardial perfusion defect in asymptomatic postmenopausal women and men with and without diabetes mellitus. J Womens Health (Larchmt). 2013 May;22(5):439-44. doi: 10.1089/jwh.2012.4055. PMID: 23600438. Exclusion Code: X4.23600438
495 Xanthakis V, Enserro DM, Murabito JM, . Ideal cardiovascular health: associations with biomarkers and subclinical disease and impact on incidence of cardiovascular disease in the Framingham Offspring Study. Circulation. 2014 Nov 4;130(19):1676-83. doi: 10.1161/circulationaha.114.009273. PMID: 25274000. Exclusion Code: X3.25274000
496 Yanagisawa S, Miki K, Yasuda N, . The prognostic value of treadmill exercise testing in very elderly patients: heart rate recovery as a predictor of mortality in octogenarians. Europace. 2011 Jan;13(1):114-20. doi: 10.1093/europace/euq422. PMID: 21084358. Exclusion Code: X2.21084358
497 Yang X, So WY, Kong AP, . Development and validation of stroke risk equation for Hong Kong Chinese patients with type 2 diabetes: the Hong Kong Diabetes Registry. Diabetes Care. 2007 Jan;30(1):65-70. doi: 10.2337/dc06-1273. PMID: 17192335. Exclusion Code: X3.17192335
498 Yang X, So WY, Kong AP, . Development and validation of a total coronary heart disease risk score in type 2 diabetes mellitus. Am J Cardiol. 2008 Mar 1;101(5):596-601. doi: 10.1016/j.amjcard.2007.10.019. PMID: 18308005. Exclusion Code: X3.18308005
499 Yoo WS, Kim HJ, Kim D, . Early detection of asymptomatic coronary artery disease in patients with type 2 diabetes mellitus. Korean J Intern Med. 2009 Sep;24(3):183-9. doi: 10.3904/kjim.2009.24.3.183. PMID: 19721853. Exclusion Code: X5.19721853
500 Zhang Y, Agnoletti D, Iaria P, . Gender difference in cardiovascular risk factors in the elderly with cardiovascular disease in the last stage of lifespan: the PROTEGER study. Int J Cardiol. 2012 Feb 23;155(1):144-8. doi: 10.1016/j.ijcard.2011.09.073. PMID: 22000269. Exclusion Code: X2.22000269
501 Zhang Y, Post WS, Dalal D, . QT-interval duration and mortality rate: results from the Third National Health and Nutrition Examination Survey. Arch Intern Med. 2011 Oct 24;171(19):1727-33. doi: 10.1001/archinternmed.2011.433. PMID: 22025428. Exclusion Code: X5.22025428
502 Zhang Y, Protogerou AD, Iaria P, . Prognosis in the hospitalized very elderly: the PROTEGER study. Int J Cardiol. 2013 Oct 3;168(3):2714-9. doi: 10.1016/j.ijcard.2013.03.021. PMID: 23578896. Exclusion Code: X2.23578896
503 Zhang ZM, Prineas RJ, Case D, . Gender differences between the Minnesota code and Novacode electrocardiographic prognostication of coronary heart disease in the cardiovascular health study. Am J Cardiol. 2011 Mar 15;107(6):817-20.e1. doi: 10.1016/j.amjcard.2010.11.004. PMID: 21247534. Exclusion Code: X5.21247534
504 Zhang ZM, Prineas RJ, Soliman EZ, . Prognostic significance of serial Q/ST-T changes by the Minnesota Code and Novacode in the Atherosclerosis Risk in Communities (ARIC) study. Eur J Prev Cardiol. 2012 Dec;19(6):1430-6. doi: 10.1177/1741826711426091. PMID: 21997257. Exclusion Code: X5.21997257
505 Zhang ZM, Rautaharju PM, Prineas RJ, . Bundle branch blocks and the risk of mortality in the Atherosclerosis Risk in Communities study. J Cardiovasc Med (Hagerstown). 2016 Jun;17(6):411-7. doi: 10.2459/jcm.0000000000000235. PMID: 25575277. Exclusion Code: X5.25575277
506 Zhang ZM, Rautaharju PM, Prineas RJ, . Race and Sex Differences in the Incidence and Prognostic Significance of Silent Myocardial Infarction in the Atherosclerosis Risk in Communities (ARIC) Study. Circulation. 2016 May 31;133(22):2141-8. doi: 10.1161/circulationaha.115.021177. PMID: 27185168. Exclusion Code: X5.27185168
507 Zulqarnain MA, Qureshi WT, O’Neal WT, . Risk of Mortality Associated With QT and JT Intervals at Different Levels of QRS Duration (from the Third National Health and Nutrition Examination Survey). Am J Cardiol. 2015 Jul 1;116(1):74-8. doi: 10.1016/j.amjcard.2015.03.038. PMID: 25929581. Exclusion Code: X5.25929581