# Appendix B Detailed Methods

## Appendix B1 Search Strategies

PubMed, 7/13/16

Search | Query | Items found
#1 | Search (“Electrocardiography”[Mesh] OR electrocardiography OR EKG OR ECG OR “Exercise Test”[Mesh] OR (treadmill AND test) OR (treadmill AND ett)) | 256656
#2 | Search (“Myocardial lschemia”[Mesh] OR “coronary heart disease”[tiab] OR “coronary disease”[tiab] OR “coronary disease”[mh] OR “coronary artery disease”[tiab] OR “Atherosclerosis”[Mesh] OR atherosclerosis[tiab]) | 500580
#3 | Search (#1 and #2) | 67866
#4 | Search ((“Mass Screening”[Mesh] OR screen*[tiab])) | 591681
#5 | Search (#3 and #4) | 1397
#6 | Search (#3 and #4) Filters: Humans | 1347
#7 | Search (#3 and #4) Filters: Humans; English | 1115
#8 | Search (#3 and #4) Filters: Humans; English; Adult: 19+ years | 843
#9 | Search (((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “Controlled Clinical Trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 642180
#10 | Search (#8 and #9) | 81
#11 | Search (#8 and #9) Filters: Humans | 81
#12 | Search (#8 and #9) Filters: Humans; English | 81
#13 | Search (#8 and #9) Filters: Publication date from 2009/01/01 to 2016/12/31; Humans; English | 13
#14 | Search (#3 and #4) Filters: Systematic Reviews; Humans; English; Adult: 19+ years | 18
#15 | Search (#3 and #4) Filters: Systematic Reviews; Meta-Analysis; Humans; English; Adult: 19+ years | 18
#16 | Search (#3 and #4) Filters: Systematic Reviews; Meta-Analysis; Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+years | 10
#17 | Search (“adverse effects” [Subheading] OR “Long Term Adverse Effects”[Mesh] OR “Patient Harm”[Mesh] OR “Mortality”[Mesh] OR “mortality” [Subheading] OR death[tiab] OR mortality[tiab] OR “medical errors”[mh] OR “iatrogenic disease”[mh] OR “false positive reactions”[mh] OR “Syncope”[Mesh] OR “Arrhythmias, Cardiac”[Mesh] OR “Myocardial lnfarction”[Mesh] OR “heart attack”[tiab] OR “Anxiety”[Mesh] OR labeling[tiab] OR labelling[tiab] OR “Coronary Angiography”[Mesh] OR “Myocardial Revascularization”[Mesh]) | 3631548
#18 | Search (#8 and #17) | 560
#19 | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) | 1903256
#20 | Search (#18 and #19) Publication date from 2009/01/01 to 2016/12/31 | 92
#21 | Search (#8 and #17) Filters: Systematic Reviews | 13
#22 | Search (#8 and #17) Filters: Systematic Reviews; Meta-Analysis | 13
#23 | Search (#8 and #17) Filters: Systematic Reviews; Meta-Analysis; Publication date from 2009/01/01 to 2016/12/31 | 8
#24 | Search (“Coronary Angiography”[Mesh] OR “Myocardial Revascularization”[Mesh]) | 121744
#25 | Search (#2 and #24) | 86047
#26 | Search (“adverse effects” [Subheading] OR “Long Term Adverse Effects”[Mesh] OR “Patient Harm”[Mesh] OR “Mortality”[Mesh] OR “mortality” [Subheading] OR death[tiab] OR mortality[tiab] OR “medical errors”[mh] OR “iatrogenic disease”[mh] OR “false positive reactions”[mh] OR “Syncope”[Mesh] OR “Arrhythmias, Cardiac”[Mesh] OR “Myocardial lnfarction”[Mesh] OR “heart attack”[tiab] OR “Anxiety”[Mesh] OR labeling[tiab] OR labelling[tiab]) | 3574617
#27 | Search (#25 and #26) | 49909
#28 | Search (#25 and #26) Filters: Humans | 49313
#29 | Search (#25 and #26) Filters: Humans; English | 42245
#30 | Search (#25 and #26) Filters: Humans; English; Adult: 19+years | 32017
#31 | Search (#25 and #26) Filters: Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+ years | 11463
#32 | Search (#25 and #26) Filters: Systematic Reviews; Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+years | 266
#33 | Search (#25 and #26) Filters: Systematic Reviews; Meta-Analysis; Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+years | 267
#34 | Search (letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt]) | 1511006
#35 | Search (#33 not #34) | 266

PubMed KQ 2-Risk/Harmssearch, 7/13/16

Search | Query | Items found
#1 | Search (“Electrocardiography”[Mesh] OR electrocardiography OR EKG OR ECG OR “Exercise Test”[Mesh] OR (treadmill AND test) OR (treadmill AND ett)) | 256656
#2 | Search (“Mortality”[Mesh] OR “mortality”[Subheading] OR death[tiab] OR mortality[tiab] OR “Myocardial lnfarction”[Mesh] OR “heart attack”[tiab] OR “Myocardial lschemia”[Mesh] OR “Cardiovascular Diseases”[Mesh:NoExp] OR “Coronary Disease”[MeSH] OR “Coronary Disease”[mh] OR “coronary heart disease”[tiab] OR “coronary artery disease”[tiab] OR “coronary disease”[tiab] OR “Heart Failure”[Mesh] OR “heart failure”[tiab] OR “Stroke”[Mesh]) | 1944815
#3 | Search (#1 and #2) | 95297
#4 | Search (“Risk”[Mesh:NoExp] OR “Logistic Models”[Mesh] OR “Risk Assessment”[Mesh] OR “Risk Factors”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “Kaplan-Meier Estimate”[Mesh] OR “risk prediction”[tiab] OR reclass*[tiab] OR Framingham[tiab] OR “risk score”[tiab] OR “risk scores”[tiab]) | 1099100
#5 | Search (#3 and #4) | 17436
#6 | Search (#3 and #4) Filters: Humans | 17238
#7 | Search (#3 and #4) Filters: Humans; English | 15162
#8 | Search (#3 and #4) Filters: Humans; English; Adult: 19+ years | 12007
#9 | Search (#3 and #4) Filters: Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+ years | 4971
#10 | Search (((randomized[title/abstract] OR randomised[title/abstract]) AND controlled [title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “Controlled Clinical Trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 642180
#11 | Search (#9 and #10) | 496
#12 | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[Mesh] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | 1903256
#13 | Search (#9 and #12) | 3135
#14 | Search (#3 and #4) Filters: Systematic Reviews; Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+years | 81
#15 | Search (#3 and #4) Filters: Systematic Reviews; Meta-Analysis; Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+years | 81

Cochrane Library Searches KQ 1 and KQ 3, 7/13/16

ID | Search | Hits
#1 | [mh Electrocardiography] or electrocardiography or EKG or ECG or [mh “Exercise Test”] or (treadmill and test) or (treadmill and ett) | 20976
#2 | [mh “Myocardial Ischemia”] or “coronary heart disease”:ti,ab or “coronary disease”:ti,ab or “coronary disease”:kw or “coronary artery disease”:ti,ab or [mh Atherosclerosis] or atherosclerosis:ti,ab | 32974
#3 | #1 and #2 | 5808
#4 | [mh “Mass Screening”] or screen*:ti,ab | 26321
#5 | #3 and #4 Publication Year from 2009 to 2016, in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 13
#6 | ((controlled:ti or controlled:ab) and (trial:ti or trial:ab)) or “controlled clinical trial” or “randomized controlled trial”:pt or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 574189
#7 | #5 and #6 | 9
#8 | [mh /AE] or [mh “Long Term Adverse Effects”] or [mh “Patient Harm”] or [mh Mortality] or [mh /MO] or death:ti,ab or mortality:ti,ab or “medical errors”:kw or “iatrogenic disease”:kw or “false positive reactions”:kw or [mh Syncope] or [mh “Arrhythmias, Cardiac”] or [mh “Myocardial Infarction”] or “heart attack”:ti,ab or [mh Anxiety] or labeling:ti,ab or labelling:ti,ab or [mh “Coronary Angiography”] or [mh “Myocardial Revascularization”] | 184054
#9 | #5 and #8 | 12
#10 | [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-up Studies”] or “prospective cohort” or [mh “prospective studies”] or (prospective* and cohort and (study or studies)) | 139076
#11 | #9 and #10 | 9
#12 | [mh “Coronary Angiography”] or [mh “Myocardial Revascularization”] | 11381
#13 | #2 and #12 | 7785
#14 | [mh /AE] or [mh “Long Term Adverse Effects”] or [mh “Patient Harm”] or [mh Mortality] or [mh /MO] or death:ti,ab or mortality:ti,ab or “medical errors”:kw or “iatrogenic disease”:kw or “false positive reactions”:kw or [mh Syncope] or [mh “Arrhythmias, Cardiac”] or [mh “Myocardial Infarction”] or “heart attack”:ti,ab or [mh Anxiety] or labeling:ti,ab or labelling:ti,ab | 179573
#15 | #13 and #14 Publication Year from 2009 to 2016, in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 215

Cochrane Library Searches KQ 2, Risk, 7/13/16

ID | Search | Hits
#1 | [mh Electrocardiography] or electrocardiography or EKG or ECG or [mh “Exercise Test”] or (treadmill and test) or (treadmill and ett) | 20976
#2 | [mh Mortality] or [mh /MO] or death:ti,ab or mortality:ti,ab or [mh “Myocardial Infarction”] or “heart attack”:ti,ab or [mh “Myocardial Ischemia”] or [mh ∧”Cardiovascular Diseases”] or [mh “Coronary Disease”] or “Coronary Disease”:kw or “coronary heart disease”:ti,ab or “coronary artery disease”:ti,ab or “coronary disease”:ti,ab or [mh “Heart Failure”] or “heart failure”:ti,ab or [mh Stroke] | 101003
#3 | #1 and #2 | 8278
#4 | [mh ^∧^Risk] or [mh “Logistic Models”] or [mh “Risk Assessment”] or [mh “Risk Factors”] or [mh “Predictive Value of Tests”] or [mh “Kaplan-Meier Estimate”] or “risk prediction”:ti,ab or reclass*:ti,ab or Framingham:ti,ab or “risk score”:ti,ab or “risk scores”:ti,ab | 44070
#5 | #3 and #4 | 1239
#6 | #3 and #4 Publication Year from 2009 to 2016 | 539
#7 | #6 in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 33
#8 | ((controlled:ti or controlled:ab) and (trial:ti or trial:ab)) or “controlled clinical trial” or “randomized controlled trial”:pt or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 574189
#9 | #6 and #8 | 493
#10 | [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-up Studies”] or “prospective cohort” or [mh “prospective studies”] or (prospective* and cohort and (study or studies)) | 139076
#11 | #6 and #10 | 281
#12 | #9 or #11 Publication Year from 2009 to 2016 | 209

PubMed KQ 1 and KQ 3, 5/30/17

Search | Query | Items Found
#1 | Search (“Electrocardiography”[Mesh] OR electrocardiography OR EKG OR ECG OR “Exercise Test”[Mesh] OR (treadmill AND test) OR (treadmill AND ett)) | 264065
#2 | Search (“Myocardial Ischemia”[Mesh] OR “coronary heart disease”[tiab] OR “coronary disease”[tiab] OR “coronary disease”[mh] OR “coronary artery disease”[tiab] OR “Atherosclerosis”[Mesh] OR atherosclerosis[tiab]) | 518274
#3 | Search (#1 and #2) | 69195
#4 | Search ((“Mass Screening”[Mesh] OR screen*[tiab])) | 630082
#5 | Search (#3 and #4) | 1445
#6 | Search (#3 and #4) Filters: Humans | 1390
#7 | Search (#3 and #4) Filters: Humans; English | 1156
#8 | Search (#3 and #4) Filters: Humans; English; Adult: 19+ years | 875
#9 | Search (((randomized[title/abstract] OR randomised[title/abstract]) AND controlled [title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “Controlled Clinical Trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 672674
#10 | Search (#8 and #9) | 84
#11 | Search (#8 and #9) Filters: Humans | 84
#12 | Search (#8 and #9) Filters: Humans; English | 84
#13 | Search (#8 and #9) Filters: Publication date from 2016/01/01 to 2017/12/31; Humans; English | 4
#14 | Search (#3 and #4) Filters: Systematic Reviews; Humans; English; Adult: 19+ years | 19
#15 | Search (#3 and #4) Filters: Systematic Reviews; Meta-Analysis; Humans; English; Adult: 19+ years | 19
#16 | Search (#3 and #4) Filters: Systematic Reviews; Meta-Analysis; Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+years | 1
#17 | Search (“adverse effects” [Subheading] OR “Long Term Adverse Effects”[Mesh] OR “Patient Harm”[Mesh] OR “Mortality”[Mesh] OR “mortality” [Subheading] OR death[tiab] OR mortality[tiab] OR “medical errors”[mh] OR “iatrogenic disease”[mh] OR “false positive reactions”[mh] OR “Syncope”[Mesh] OR “Arrhythmias, Cardiac”[Mesh] OR “Myocardial lnfarction”[Mesh] OR “heart attack”[tiab] OR “Anxiety”[Mesh] OR labeling[tiab] OR labelling[tiab] OR “Coronary Angiography”[Mesh] OR “Myocardial Revascularization”[Mesh]) | 3790291
#18 | Search (#8 and #17) | 577
#19 | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) | 2023668
#20 | Search (#18 and #19) Publication date from 2016/01/01 to 2017/12/31 | 14
#21 | Search (#8 and #17) Filters: Systematic Reviews | 13
#22 | Search (#8 and #17) Filters: Systematic Reviews; Meta-Analysis | 13
#23 | Search (#8 and #17) Filters: Systematic Reviews; Meta-Analysis; Publication date from2009/01/01 to 2016/12/31 | 0
#24 | Search (“Coronary Angiography”[Mesh] OR “Myocardial Revascularization”[Mesh]) | 125817
#25 | Search (#2 and #24) | 89049
#26 | Search (“adverse effects”[Subheading] OR “Long Term Adverse Effects”[Mesh] OR “Patient Harm”[Mesh] OR “Mortality”[Mesh] OR “mortality” [Subheading] OR death[tiab] OR mortality[tiab] OR “medical errors”[mh] OR “iatrogenic disease”[mh] OR “false positive reactions”[mh] OR “Syncope”[Mesh] OR “Arrhythmias, Cardiac”[Mesh] OR “Myocardial lnfarction”[Mesh] OR “heart attack”[tiab] OR “Anxiety”[Mesh] OR labeling[tiab] OR labelling[tiab]) | 3731590
#27 | Search (#25 and #26) | 51715
#28 | Search (#25 and #26) Filters: Humans | 51104
#29 | Search (#25 and #26) Filters: Humans; English | 43976
#30 | Search (#25 and #26) Filters: Humans; English; Adult: 19+years | 33495
#31 | Search (#25 and #26) Filters: Publication date from 2016/01/01 to 2017/12/31; Humans; English; Adult: 19+ years | 1221
#32 | Search (#25 and #26) Filters: Systematic Reviews; Publication date from 2016/01/01 to 2017/12/31; Humans; English; Adult: 19+years | 22
#33 | Search (#25 and #26) Filters: Systematic Reviews; Meta-Analysis; Publication date from 2016/01/01 to 2017/12/31; Humans; English; Adult: 19+years | 22
#34 | Search (letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt]) | 1566106
#35 | Search (#33 not #34) | 22

PubMed KQ2-Risk/Harms, 5/30/17

Search | Query | Items Found
#1 | Search (“Electrocardiography”[Mesh] OR electrocardiography OR EKG OR ECG OR “Exercise Test”[Mesh] OR (treadmill AND test) OR (treadmill AND ett)) | 264065
#2 | Search (“Mortality”[Mesh] OR “mortality”[Subheading] OR death[tiab] OR mortality[tiab] OR “Myocardial lnfarction”[Mesh] OR “heart attack”[tiab] OR “Myocardial Ischemia”[Mesh] OR “Cardiovascular Diseases”[Mesh:NoExp] OR “Coronary Disease”[MeSH] OR “Coronary Disease”[mh] OR “coronary heart disease”[tiab] OR “coronary artery disease”[tiab] OR “coronary disease”[tiab] OR “Heart Failure”[Mesh] OR “heart failure”[tiab] OR “Stroke”[Mesh]) | 2043386
#3 | Search (#1 and #2) | 97776
#4 | Search (“Risk”[Mesh:NoExp] OR “Logistic Models”[Mesh] OR “Risk Assessment”[Mesh] OR “Risk Factors”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “Kaplan-Meier Estimate”[Mesh] OR “risk prediction”[tiab] OR reclass*[tiab] OR Framingham[tiab] OR “risk score”[tiab] OR “risk scores”[tiab]) | 1099100
#5 | Search (#3 and #4) | 18197
#6 | Search (#3 and #4) Filters: Humans | 17983
#7 | Search (#3 and #4) Filters: Humans; English | 15883
#8 | Search (#3 and #4) Filters: Humans; English; Adult: 19+ years | 12604
#9 | Search (#3 and #4) Filters: Publication date from 2016/01/01 to 2017/12/31; Humans; English; Adult: 19+ years | 509
#10 | Search (((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “Controlled Clinical Trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 672674
#11 | Search (#9 and #10) | 51
#12 | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | 2023668
#13 | Search (#9 and #12) | 334
#14 | Search (#3 and #4) Filters: Systematic Reviews; Publication date from 2009/01/01 to 2016/12/31; Humans; English; Adult: 19+years | 8
#15 | Search (#3 and #4) Filters: Systematic Reviews; Meta-Analysis; Publication date from 2016/01/01 to 2017/12/31; Humans; English; Adult: 19+years | 8

Cochrane Library Searches KQ1 and KQ 3, 5/30/17

ID | Search | Hits
#1 | [mh Electrocardiography] or electrocardiography or EKG or ECG or [mh “Exercise Test”] or (treadmill and test) or (treadmill and ett) | 22891
#2 | [mh “Myocardial Ischemia”] or “coronary heart disease”:ti,ab or “coronary disease”:ti,ab or “coronary disease”:kw or “coronary artery disease”:ti,ab or [mh Atherosclerosis] or atherosclerosis:ti,ab | 35404
#3 | #1 and #2 | 6048
#4 | [mh “Mass Screening”] or screen*:ti,ab | 31391
#5 | #3 and #4 Publication Year from 2016 to 2017, in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 7
#6 | ((controlled:ti or controlled:ab) and (trial:ti or trial:ab)) or “controlled clinical trial” or “randomized controlled trial”:pt or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 663873
#7 | #5 and #6 | 6
#8 | [mh /AE] or [mh “Long Term Adverse Effects”] or [mh “Patient Harm”] or [mh Mortality] or [mh /MO] or death:ti,ab or mortality:ti,ab or “medical errors”:kw or “iatrogenic disease”:kw or “false positive reactions”:kw or [mh Syncope] or [mh “Arrhythmias, Cardiac”] or [mh “Myocardial Infarction”] or “heart attack”:ti,ab or [mh Anxiety] or labeling:ti,ab or labelling:ti,ab or [mh “Coronary Angiography”] or [mh “Myocardial Revascularization”] | 201669
#9 | #5 and #8 | 6
#10 | [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-up Studies”] or “prospective cohort” or [mh “prospective studies”] or (prospective* and cohort and (study or studies)) | 150064
#11 | #9 and #10 | 4
#12 | [mh “Coronary Angiography”] or [mh “Myocardial Revascularization”] | 11848
#13 | #2 and #12 | 8118
#14 | [mh /AE] or [mh “Long Term Adverse Effects”] or [mh “Patient Harm”] or [mh Mortality] or [mh /MO] or death:ti,ab or mortality:ti,ab or “medical errors”:kw or “iatrogenic disease”:kw or “false positive reactions”:kw or [mh Syncope] or [mh “Arrhythmias, Cardiac”] or [mh “Myocardial Infarction”] or “heart attack”:ti,ab or [mh Anxiety] or labeling:ti,ab or labelling:ti,ab | 197054
#15 | #13 and #14 Publication Year from 2016 to 2017, in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 4

Cochrane Library Searches KQ 2, Risk, 5/30/17

ID | Search | Hits
#1 | [mh Electrocardiography] or electrocardiography or EKG or ECG or [mh “Exercise Test”] or (treadmill and test) or (treadmill and ett) | 22891
#2 | [mh Mortality] or [mh /MO] or death:ti,ab or mortality:ti,ab or [mh “Myocardial Infarction”] or “heart attack”:ti,ab or [mh “Myocardial Ischemia”] or [mh ^∧^”Cardiovascular Diseases”] or [mh “Coronary Disease”] or “Coronary Disease”:kw or “coronary heart disease”:ti,ab or “coronary artery disease”:ti,ab or “coronary disease”:ti,ab or [mh “Heart Failure”] or “heart failure”:ti,ab or [mh Stroke] | 115133
#3 | #1 and #2 | 8800
#4 | [mh ^∧^Risk] or [mh “Logistic Models”] or [mh “Risk Assessment”] or [mh “Risk Factors”] or [mh “Predictive Value of Tests”] or [mh “Kaplan-Meier Estimate”] or “risk prediction”:ti,ab or reclass*:ti,ab or Framingham:ti,ab or “risk score”:ti,ab or “risk scores”:ti,ab | 47503
#5 | #3 and #4 | 1334
#6 | #3 and #4 Publication Year from 2009 to 2016 | 55
#7 | #6 in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 2
#8 | ((controlled:ti or controlled:ab) and (trial:ti ortrial:ab)) or “controlled clinical trial” or “randomized controlled trial”:pt or “randomized controlled trial as topic”:pt or “single-blind method”:pt or “double-blind method”:pt or “random allocation”:pt | 663874
#9 | #6 and #8 | 54
#10 | [mh “Cohort Studies”] or [mh “Epidemiologic Studies”] or [mh “Follow-up Studies”] or “prospective cohort” or [mh “prospective studies”] or (prospective* and cohort and (study or studies)) | 150064
#11 | #6 and #10 | 27
#12 | #9 or #11 Publication Year from 2016 to 2017 | 54

## Appendix B2 Eligibility Criteria

| Include | Exclude
Populations | Adults age ≥18 years without symptoms or a diagnosis of CVD; studies of mixed populations of asymptomatic and symptomatic persons are eligible if results are reported separately for asymptomatic persons or <20% of the sample is symptomatic^a^ | Persons with a history of atherosclerotic disease or symptoms suggesting coronary heart disease; children and adolescents
Screening tests | Resting ECG, exercise ECG | Radiology tests (e.g., thallium scan, scintigraphy, computed tomography), echocardiography, and vectorcardiography^b^
Comparisons | All KQs: Screened vs. nonscreened groups (i.e., risk stratification using ECG plus traditional risk factors vs. risk stratification using traditional risk factors alone) KQ 2: CVD risk assessment models that include ECG findings compared with those that do not KQ 3: For harms of subsequent procedures/interventions, studies that compare the procedure/intervention to no procedure/intervention are also eligible. For studies reporting rates of harms from exercise ECG or subsequent procedures/interventions, large registries or multicenter studies without a control group that report rates of harms for asymptomatic persons are also eligible. | No comparison, nonconcordant historical control, comparative studies with other novel risk factors (e.g., comparing ECG vs. C-reactive protein); studies that compare the risk for subsequent events between persons with and without ECG abnormalities and report associations (e.g., prospective cohort studies that report hazard ratios for outcomes associated with baseline T-wave abnormalities)
Outcomes | KQ 1: All-cause mortality, cardiovascular mortality, and cardiovascular events (myocardial infarction, angina, stroke, congestive heart failure, composite cardiovascular outcomes) KQ 2: Reclassification, calibration (the degree to w hich predicted and observed risk estimates agree, goodness-of-fit statistics), and discrimination (C-statistic/area under the curve) KQ 3: Mortality, arrhythmia, cardiovascular events, or injuries from exercise ECG; anxiety; labeling; harms of subsequent procedures or interventions initiated as a result of screening (e.g., subsequent angiography or revascularization procedures resulting in harm) | KQ 2: Studies assessing the association between ECG findings and outcomes (e.g., with adjusted hazard ratios)
Study designs | All KQs: Randomized, controlled trials or controlled clinical trials KQs 2, 3: Prospective cohort studies are also eligible KQ 3: Well-designed large retrospective cohort studies and well-designed case-control studies (only for rare events) are also eligible | All other designs, narrative reviews, systematic reviews^c^ case reports, case series, editorials, letters, cross-sectional studies
Setting | Studies performed in primary care or occupational medicine settings, studies that recruit participants from the general population | Studies performed in specialty settings, studies of patients undergoing preoperative evaluation
Country | Studies conducted in countries categorized as “Very High” on the 2014 Human Development Index (as defined by the United Nations Development Program)
Language | English | Non-English
Study quality | Good or fair | Poor (according to design-specific USPSTF criteria)

a The a priori plan for mixed populations was to include studies if the results were reported separately for asymptomatic persons or if less than 10 percent of the sample was symptomatic, and to systematically determine whether that approach would result in the exclusion of any studies in which 10 to 50 percent of the population was symptomatic that should be considered for inclusion. We only identified one such study (16.5% of participants had atypical chest pain^45^) and decided to include the study because of the uncertainty around the appropriate threshold (for proportion of symptomatic patients that would alter study findings and substantially limit their applicability for the review questions).

b Vectorcardiography is a method of recording the magnitude and direction of the electrical forces that are generated by the heart by means of a continuous series of vectors that form curving lines around a central point.

c We will not abstract data from systematic reviews and will not include them in the results, but we will conduct separate searches for systematic reviews and search the references lists of all potentially relevant systematic reviews to identify relevant primary studies that our electronic searches did not identify.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-totreat analysis is lacking for RCTs.

Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Sources: U.S. Preventive Services T ask Force, Procedure Manual, Appendix VI https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes Harris et al, 2001^46^

#### Specific Questions Used to Guide Assessment of Included Studies

Items used to assess quality of RCTs for KQs 1 and 3

1. Was randomization adequate?
2. Was allocation concealment adequate?
3. Were groups similar at baseline?
4. Was intervention fidelity adequate?
5. What was the reported adherence to the intervention?
6. What was the overall attrition?
7. What was the differential attrition?
8. Did the study have differential attrition or overall high attrition raising concern for bias?
9. Did the study have cross-overs or contamination raising concern for bias?
10. Were outcome measurements equal, valid, and reliable?
11. Were patients masked?
12. Were providers masked?
13. Were outcome assessors masked?
14. Was the duration of follow up adequate to assess the outcome?
15. What was the method used to handle missing data?
16. Did the study use accepTablestatistical methods?
17. Quality Rating

Additional Items used to assess quality of RCTs that address harms, KQ3

1. Were harms prespecified and defined?
2. Were ascertainment techniques for harms adequately described?
3. Were ascertainment techniques for harms equal, valid, and reliable?
4. Was duration of follow -up adequate for harms assessment?
5. Quality Rating

Items used to assess quality of relevant studies reporting reclassification, calibration, and discrimination, KQ 2

1. Does study sample adequately capture the population of interest (participant eligibility and recruitment)?
2. Was there selective inclusion of participants in the model based on data availability?
3. If participants are from a treatment RCT, is treatment accounted for?
4. Enrolled consecutive patients or a random sample?
5. Were selection criteria clearly described?
6. Is a valid and reliable definition and method for measurement of the outcomes reported?
7. Was the same outcome definition (and method for measurement) used in all patients?
8. Were the outcomes assessed without know ledge of the candidate predictors (i.e., blinded)?
9. Is a valid and reliable definition and method for measurement and classification of candidate predictor(s) (ECG and risk factors) reported?
10. Were predictors assessed blinded for the outcome, and for each other (if relevant)?
11. How was the predictor of interest (ECG) handled in the modelling?
12. Number (%) participants with missing data (include predictors and outcomes)
13. Did the study have high attrition raising concern for bias?
14. How was missing data handled?
15. Were multiple measures of performance used (e.g., global fit, discrimination, calibration, net reclassification)?
16. Were both calibration and discrimination measures reported? Were confidence intervals reported?
17. Were a priori cut points used for classification measures (e.g., sensitivity, specificity, predictive values, NRI)?
18. Was a bias-corrected NRI used?
19. If net reclassification was assessed, were appropriate clinical thresholds used to reclassify risk?
20. Method used for testing model performance: development dataset only or separate external validation?
21. In what way was the population a separate external validation from the FRS or PCE?
22. Was the FRS or PCE recalibrated in the population before ECG was added to the model?
23. Quality