# Appendix A Additional Background, Summary of Recommendations From Other Groups, and Contextual Questions

Appendix A Table 1 Recent Recommendations on Screening for CVD Using ECG

Organization | Population | Recommendation
ACP, 2015^1^ | Asymptomatic low-risk adults | Do not screen for cardiac disease in asymptomatic, low-risk adults with resting or stress ECG.
ACC Foundation/AHA/ASE/ASNC/HFSA/HRS/SCA1/SCCT/SCMFI/STS, 2014^2^ | Low global risk; regardless of ECG interpretability and ability to exercise Intermediate global risk; ECG interpretable and able to exercise | Exercise ECG is rarely an appropriate option because of the lack of a clear benefit/risk advantage. Exercise ECG may be an appropriate option because of variable evidence or agreement regarding the benefit/risk ratio, potential benefit based on practice experience in the absence of evidence, and/or variability in the population.
AAFP, 2012^3^ | Asymptomatic low-risk adults | Do not order annual ECGs or any other cardiac screening.
ACPM, 2011^4^ | General adult population | Do not routinely screen the general adult population using resting or exercise ECG.
ACC/AFIA, 2010^5^ | Asymptomatic adults with hypertension or diabetes Asymptomatic adults without hypertension or diabetes Intermediate-risk asymptomatic adults (including sedentary adults considering starting a vigorous exercise program) | A resting ECG is reasonable for cardiovascular risk assessment. A resting ECG may be considered for cardiovascular risk assessment. An exercise ECG may be considered for cardiovascular risk assessment, particularly when attention is paid to non-ECG markers such as exercise capacity.
AHA, 2005^6^ | Asymptomatic adults | There is insufficient evidence to recommend exercise testing as a routine screening modality.

Abbreviations: AAFP=American Academy of Family Physicians; ACC=American College of Cardiology; ACP=American College of Physicians; ACPM=American College of Preventive Medicine; AHA=American Fleart Association; ASA=American Stroke Association; ASE=American Society of Echocardiography; ASNC=American Society of Nuclear Cardiology; CVD=cardiovascular disease; ECG=electrocardiogram; FLFSA=Heart Failure Society of America; HRS=Heart Rhythm Society; Royal College of Physicians of Edinburgh; SCAI=Society for Cardiovascular Angiography and Interventions; SCCT=Society of Cardiovascular Computed Tomography; SCMR=Society for Cardiovascular Magnetic Resonance; STS=Society of Thoracic Surgeons.

Appendix A Table 2 Characteristics of Available and Recommended Cardiovascular and Coronary Risk Assessment Models

Risk Score and Recommending Body | Risk Factors Included in the Model | Time Horizon and Outcome | Derivation and External Validation Cohorts | Limitations
ACC/AHA Pooled Cohort Equation, 2013^7^ ACC/AHA^8^ | - Age; - Sex; - Race/ethnicity; - Treated or untreated SBP; - TC; - HDL-C; - Current smoking; - Dabetes; Other CVD risk factors evaluated but not included^a^ | 10-year risk First hard CVD event (nonfatal Ml, CHD death, fatal or nonfatal stroke) | [underlined: Derivation Cohorts:] ARIC, CHS, CARDIA, Framingham/Framingham Offspring [underlined: External Validation Cohorts:] REGARDS, MESA, Contemporary Cohort (ARIC, Framinghar/Framingham Offspring), Rotterdam Study, WHS, PHS, WHI Observational Study | Baseline exams for source cohorts conducted >25 years ago No equations for Hispanics or Asians; lack of large external datasets with needed covariate data to validate in these subpopulations Small numbers of events in validation cohorts, particularly in lower-riskgroups Possible overprediction across risk strata
Framingham CVD, 2008^9^ Canadian Cardiovascular Society^10^ | - Age; - Sex; - TC; - HDL-C; - SBP; - Antihypertensive medication use; - Smoking; - Dabetes; - (Family history)^b^ | 10-year risk Any CVD event (coronary death, Ml, coronary insufficiency, angina), cerebrovascular events, peripheral artery disease (intermittent claudication), and congestive heart failure | [underlined: Derivation Cohort:] Framingham [underlined: External Validation Cohorts:] MESA, WHI Observational Study | Not limited to “hard” outcomes Baseline exams for source cohorts conducted >40 years ago Derivation cohort predominately white with high proportion of smokers (~40%) Possible overprediction, potentially higher among men
QRISK2, 2008^11^ NICE^12^ | - Age; - Sex; - Race/ethnicity; - Smoking status; - SBP; - TC:HDL-C ratio; - Body mass index; - Family history of CHD in first-degree relative age <60 years; - Tow nsend deprivation score; - Treated hypertension; - Rheumatoid arthritis; - Chronic kidney disease; - Dabetes; - Atrial fibrillation | 10-year risk CVD event (angina, Ml, stroke, TIA) | [underlined: Derivation Cohort:] U.K. primary care database; 2/3 of participants randomly allocated to derivation dataset and 1/3 assigned to validation dataset [underlined: External Validation Cohort:] N/A | Not externally validated Derivation cohort predominantly white Recording of family history of CHD possibly not systematic Tow nsend deprivation score specific to the United Kingdom
Reynolds, men, 2008^13^ N/A | - Age; - SBP; - Smoking; - TC; - HDL-C; - hs-CRP; - Parental history of Ml at <60 years of age | 10-year risk CVD event (CVD death, Ml, stroke, coronary revascularization) | [underlined: Derivation Cohort:] PHS [underlined: External Validation Cohort:] MESA | Derivation cohort predominately white Derivation cohort health professionals; health behaviors, access to health care, and SES may not be generalizable Data on blood pressure, obesity, and family history based on self-report Uncertain applicability in men <50 years old and those with diabetes
Reynolds, women, 2007^14^ N/A | - Age; - SBP; - Smoking; - TC; - HDL-C; - hs-CRP; - Parental history of Ml at <60 years of age; - HbA1c if diabetic | 10-year risk CVD events (CVD death, Ml, stroke, coronary revascularization) | [underlined: Derivation Cohort:] WHS; 2/3 of participants assigned to model derivation dataset and 1/3 assigned to validation dataset [underlined: External Validation Cohorts:] MESA, WHI Observational Study | Derivation cohort predominately white Derivation cohort health professionals; health behaviors, access to health care, and SES may not be generalizable Data on blood pressure, obesity, and family history based on self-report Possible underprediction
ASSIGN, 2007^15^ SIGN^16^ | - TC; - HDL-C; - SBP; - Smoking; - Cigarettes per day; - Family history; - Dabetes; - Index of social status/deprivation | 10-year risk CVD events (CVD death, hospitalization for CHD or cerebrovascular disease, revascularization) | [underlined: Derivation Cohort:] SHHEC [underlined: External Validation Cohort:] U.K. general practice database | Not externally validated in the United States Baseline exams for source cohort conducted >30 years ago Social deprivation index specific to Scotland High prevalence of smoking (~40%) and family history (~20%) in source cohort
ARIC, 2003^17^ N/A | - Sex; - Race; - Cigarette smoking; - TC; - HDL-C; - SBP; - Antihypertensive medication use; - Dabetes; Other CVD risk factors evaluated but not included^c^ | 10-year risk CHD event (CHD death, Ml, unrecognized Ml defined by electrocardiogram readings, or coronary revascularization) | [underlined: Derivation Cohort:] ARIC [underlined: External Validation Cohort:] N/A | Not externally validated Baseline exams for source cohorts conducted >25 years ago Not limited to “hard” outcomes Race/ethnicity limited to blacks and whites Source cohort not inclusive of age <45 or >65 years
SCORE, 2003^18^ European Society of Cardiology^19^ | - Age; - Sex; - Smoking; - TC or TC:HDL ratio; - SBP; - Smoking; - High- and low-risk regions of Europe | 10-year risk Fatal CVD event (Ml, stroke, aortic aneurysm) | [underlined: Derivation Cohort:] Pooled dataset of population-based and occupational cohort studies from 12 European countries [underlined: External Validation Cohorts:] Externally validated in European cohorts (11 evaluation studies) | Not externally validated in the United States Baseline exams for source cohorts conducted >25 years ago Diabetes not included as a risk factor because it was not uniformly collected in source cohort
PROCAM, 2002^20^ N/A | - Age; - LDL-C; - HDL-C; - Triglycerides; - Smoking; - Dabetes; - Family history of Ml at age <60 years; - SBP | 10-year risk CHD event (sudden cardiac death, definite Ml) | [underlined: Derivation Cohort:] Prospective German cohort of men [underlined: External Validation Cohorts:] Externally validated in several European cohorts | Not externally validated in the United States Baseline exams for source cohort conducted >30 years ago Excludes women and adults >65 years old Source cohort ~30% smokers
ATP III modification of Wilson Framingham model, 2002^21^,^d^ ATP III^21^,^e^ | - Age; - Sex; - TC; - HDL-C; - SBP; - Treatment for hypertension; - Smoking | 10-year risk Hard CHD (Ml death, CHD death) | [underlined: Derivation Cohort:] Framingham [underlined: External Validation Cohorts:] ATP III: MESA, WHI Observational Study Wilson: wide range of cohorts in United States, Europe, and Australia, including ARIC, PHS, HHP, PR, SHS, CHS | Baseline exams for source cohorts conducted >40 years ago Derivation cohort predominately white with high proportion of smokers (~40%) Most validation cohorts have an upper age range of ages 64 or 74 years Recent external validations of ATP III model suggest substantial overestimation, particularly among men Older validations of the Wilson model show underprediction in high-risk groups (people who have diabetes, have a strong family history of premature CVD, reside in regions with high incidence, have low SES) and overprediction in low-riskgroups (Japanese American men, Hispanic men, Native American women)

a ACC/AHA recommends that if risk based treatment is uncertain using this tool, then consider one or more of the following: family history. hs-CRP. coronary artery calcium score, or ankle-brachial index. Do not use carotidintima-media thickness for risk assessment. No recommendation for or against use of chronic kidney disease, apolipoprotein B. microalbuminuria, and cardiorespiratory fitness.

b Canadian Cardiovascular Society recommends a modified version of the model that includes family history of premature CHD.^10^

c Other CVD risk factors explored: age. body mass index, waist-to-hip ratio, sport activity index, forced expiratory volume, plasma fibrinogen, factor VII. factor VIII. von Willebrand factor, lipoprotein a. heart rate. Keys score, pack-years smoking, carotidintima-media thickness, fasting triglycerides, apolipoprotein A. apolipoprotein B. albumin, white blood cell count, and creatinine.

d There are additional Framingham-based risk assessment models with variations in outcomes predicted and risk factors included.^22-25^ In this table we focused on models recommended by guideline bodies.^9,^ ^21^

e Replaced by 2014 recommendations from the ACC/AHA.^8^

Abbreviations: ACC=American College of Cardiology; AHA=American Heart Association; ARIC=Atherosclerosis Risk in Communities Study; ATP III=Adult T reatment Panel III; CARDIA=Coronary Artery Risk Development in Young Adults; CHD=coronary heart disease; CHS=Cardiovascular Health Study; CVD=cardiovascular disease; HbAlc=glycated hemoglobin; HDL-C=low-density lipoprotein cholesterol; HHP=HonoluluHeart Program; hs-CRP=high-sensitivity C-reactive protein; LDL-C=low-density lipoprotein cholesterol; MESA=Multi-Ethnic Study of Atherosclerosis; MI=myocardial infarction; N/A=not applicable; NICE=National Institute for Health and Care Excellence; PHS=Physician’s Health Study; PR=Puerto Rico Heart Health Program; PROCAM=Prospective Cardiovascular Müunster; REGARDS=Reasons for Geographic and Racial Differences in Stroke; SBP=systolic blood pressure; SCORE=Systematic Coronary Risk Evaluation; SES=socioeconomic status; SHHEC=Scottish Heart Health Extended Cohort;SHS=Strong Heart Study; SIGN=Scottish Intercollegiate Guidelines Network; TC=total cholesterol; TIA=transient ischemic attack; UK=UnitedKingdom; U.S.=United States; WHI=Women’s Health Initiative Observational Study; WHS=Women’s Health Study.

## Appendix A Contextual Questions

### CQ 1a. For People in Each CVD Risk Category (or Strata), What Medications (i.e., Aspirin, Lipid-Lowering Therapy) Are Recommended?

Several organizations have recommendations for primary prevention of CVD, including the USPSTF, the ACC/AHA, and the American Academy of Family Physicians. European organizations have also weighed in on the subject. Most organizations consider aspirin and statin therapy for primary prevention, while some groups have also considered dietary supplement use.

#### Aspirin

The USPSTF released their recommendation^26^ for the use of aspirin to prevent CVD in April 2016. They recommended initiating low-dose aspirin for adults ages 50 to 59 years with a 10-year CVD risk of 10 percent or greater and who are not at increased risk for bleeding, have a life expectancy of at least 10 years, and are willing to take daily aspirin for at least 10 years (B recommendation). The USPSTF recommended using the PCE for determination of 10-year risk. The USPSTF also has a C recommendation for adults ages 60 to 69 years (i.e., C recommendation indicating selectively offering this service based on professional judgment and patient preferences; at least moderate certainty that the net benefit is small). For adults less than age 50 years or 70 years or older, the USPSTF concluded there was ins uffic ient evidence to assess the balance of benefits and harms (I statement).

Recommendations from the American Academy of Family Physicians about aspirin use for primary prevention have been consistent with those of the USPSTF. The American College of Chest Physicians suggests that patients older than 50 years without symptomatic CVD use low-dose aspirin for primary CVD prevention.^27^ Both the ACC/AHA and the American Stroke Association recommend low-dose aspirin for adults with 10-year CVD risk greater than 6 percent,^28^ while the American Diabetes Association^29^ recommends low-dose aspirin in patients with both type 1 and 2 diabetes who have 10-year CVD risk greater than 10 percent and are not at increased risk for bleeding. The ADA does not recommend aspirin therapy in men younger than 50 years or most women younger than 60 years who have low CVD risk because the risk for bleeding outweighs the potential benefits of aspirin treatment.

#### Statins

In December 2016, the USPSTF^30^ recommended low - to moderate-dose statins for primary prevention for adults ages 40 to 75 years with one or more CVD risk factors and a 10-year CVD risk of 10 percent or greater (B recommendation). For adults with 10-year CVD risk between 7.5 and 10 percent, the USPSTF made a C recommendation, noting that the likelihood of benefit within this risk category was smaller but some adults might benefit. For adults older than 75 years, the USPSTF concluded the evidence was insufficient to assess the balance of benefits and harms (I statement).

The 2013 ACC/AHA guidelines^31^ recommend moderate- to high-intensity statin therapy for adults ages 40 to 75 years with LDL-C 70 to 189 mg/dL with a 10-year CVD risk greater than 7.5 percent as calculated by the PCE (strong recommendation) or if they have diabetes. For those with 10-year CVD risk of 5 percent to 7.5 percent, the ACC/AHA made a “weak recommendation” for using statins for primary prevention. For adults age 21 years or older with LDL-C greater than 190, they recommend statin therapy regardless of CVD risk (moderate recommendation).

The Canadian Cardiovascular Society recommends statins plus behavior modification for men age 40 years or older and women age 50 years or older without CVD risk factors and adults of any age with CVD risk factors who also have a 20 percent or greater 10-year CVD event risk (using FRS) or an LDL-C level of 135 to 19 0mg/dL and a 10 percent to 20 percent CVD event risk (based on the FRS).^10^ The recommended treatment strategy is treatment-to-target rather than by therapy dose (e.g., 50% reduction in LDL-C level).^10^

The UK National Institute for Health and Care Excellence (NICE) recommends atorvastatin (20 mg) for primary prevention in adults (with or without type 2 diabetes) age 40 years or older with 10 percent or greater 10-year CVD risk (based on the QRISK2 tool).^12,32^ They note that for adults age 85 years or older, statins may reduce the risk of nonfatal MI. They recommend statin treatment for adults with type 1 diabetes who are older than 40 years, have had diabetes more than 10 years, have nephropathy, or have other CVD risk factors.

#### Vitamin Supplements

The USPSTF recommends against the use of beta-carotene and vitamin E supplementation for CVD prevention (D recommendation). For multivitamin, single-, or paired-nutrient supplements, the USPSTF concluded there was insufficient evidence to assess the balance of benefits and harms for CVD prevention (I statement). In addition to beta-carotene and vitamin E, the AHA^33^ recommends against the use of antioxidant vitamin supplements (e.g., vitamin C) and folic acid for primary CVD prevention.

#### Omega-3 Fatty Acids

The AHA^34^ reported there were no RCTs to guide recommendations for the use of omega-3 fatty ac ids for primary CVD prevention in the general population. However, they found evidence there was no benefit for patients with or at risk for diabetes mellitus to prevent CVD. For patients with high CVD risk, the expert panel was split between recommending against omega-3 fatty ac ids use versus a weak recommendation that treatment in high-risk patients may be reasonable. NICE^35^ recommends against use of omega-3 fatty acids for primary CVD prevention.

### CQ 1b. What Is the Fidelity to Prescribing and Taking the Recommended Medications?

According to the National Ambulatory and National Hospital Ambulatory Medical Care Surveys from 2005 to 2008,^36^ few patients were recommended to take aspirin in concordance with guideline recommendations. For example, in 2007 to 2008, among the population identified by the USPSTF to receive aspirin for prevention of CVD and stroke, it was recommended at only 16 percent of vis its for males and 22 percent of visits for females.

In an analysis of the National Health and Nutrition Examination Survey (NHANES), 2011—2012,^37^ patients without CVD were classified into high and low risk based on FRSs Approximately 40 percent of the high-risk group and 26 percent of the low-risk group reported being told by their physician to take aspirin. Between 76 percent and 79 percent of patients advised to take aspirin reported complying. Using the same dataset, Malayala et al^38^ reported that about 35 percent of men ages 45 to 79 years who met USPSTF guideline recommendations for aspirin for primary prevention were advised by their providers to take aspirin and about 70 percent of that group reported compliance with the recommendation. Also using the 2011—2012 NHANES dataset, Fiscella et al^39^ reported a slightly higher rate of aspirin recommendations for eligible women (i.e., ages 55 to 79 years), 42 percent, for primary CVD prevention.

The Reduction of Atherothrombosis for Continued Health (REACH)^40^ Registry compiled data on over 25,000 U.S. outpatients with atherothrombosis or atherosclerotic risk factors between 2003 2004. Approximately 25 percent of the registry enrollees were asymptomatic and comprised the primary prevention cohort (n=6,600). For primary CVD prevention, 62 percent of the cohort were taking at least one antiplatelet agent, most often aspirin, and 77 percent were receiving a statin.

### CQ 2. What Are the Harms and Benefits of Revascularization Procedures for Adults Without Symptoms or a Prior Diagnosis of CVD?

Precise estimates of benefits and harms of revascularization for asymptomatic adults were not available. Available data come from studies with mostly symptomatic people. For example, population-based registries including people with symptoms estimate that the risk for any serious harms from angiography (which is often done at the same time as revascularization) is about 1.7 percent, including arrhythmia (0.4%), death (0.1%), stroke (0.07%), or MI (0.05%).^41^ After an abnormal screening ECG that is concerning for ischemia, some people without CHD would be sent for angiography without the possibility of benefit but would be subjected to potential harms. Even among a large sample undergoing elective angiography (about 400,000 participants) that was mostly symptomatic (70%), an estimated 39 percent had no CHD on angiography.^42^

One registry study published in JAMA Internal Medicine’s Less is More series reported data from a preoperative referral population (for noncardiac surgery) that describes data for a sample with a majority of asymptomatic participants (60%): the National Cardiovascular Data Registry CathPCI Registry. It is a large, national registry of patients undergoing diagnostic cardiac catheterizations and/or percutaneous coronary interventions (PCI) that captures about 85 percent of PCI procedures from approximately 1,400 U.S. hospitals. The registry^43^ contains data on nearly 195,000 patients who underwent preoperative evaluation prior to noncardiac surgery between July 2009 and December 2014. Approximately 60 percent of this cohort was reported to be clinically asymptomatic, although 58 percent had been taking antianginal medications within 2 weeks of the procedure; about 20 percent had atypical chest pain considered unlikely to be ischemic, and another 20 percent had stable angina. The sample excluded patients undergoing catheterization with suspected acute coronary syndrome, those who had unstable angina symptoms, and patients undergoing catheterization as part of a cardiac transplant evaluation.

The authors concluded that most patients undergoing diagnostic catheterization before noncardiac surgery are asymptomatic; the discovery of obstructive coronary artery disease is common; and although randomized, clinical trials have found no benefit in outcomes, revascularization is recommended in nearly half of these patients.

Obstructive disease was identified in 48 percent of the cohort overall, 40 percent of those who underwent diagnostic catheterization only, and 97 percent of those receiving PCI. Of patients with asymptomatic presentations, 48 percent were found to have obstructive disease. Approximately 16 percent of the cohort underwent PCI, and an additional 8 percent received CABG; revascularization was recommended in 23 percent of asymptomatic patients.

For the overall cohort, complications related to PCI were uncommon, including coronary artery dissection (1.3%), periprocedural MI (1.7%), vascular complications (0.4%), stroke (0.1%), and renal failure (0.4%). Death occurred in 14 patients on the same day as the procedure, eight of which occurred in the catheterization lab. Bleeding events within 72 hours of the procedure occurred in 371 patients (1.3%), primarily at the procedure access site. Adverse events for asymptomatic patients were not separately reported.

Benefits of revascularization in asymptomatic adults is uncommonly reported. Mc Falls et al^44^ randomized patients scheduled for vascular surgery at 18 Veterans Affairs medical centers to receive preoperative coronary artery revascularization or no revascularization. Of these, 510 participants were randomized, and 240 participants underwent either PCI (n=141) or CABG (n=99). Notably, about half of all participants had prior CAD. After 2.7 years of followup, mortality was no different between groups (RR, 0.97; 95% CI, 0.69 to 1.36). In high-risk subgroups of participants, CABG did not confer a survival benefit. The vast majority of participants were taking beta-blockers, aspirin, ACE inhibitors, and statins up to 24 months after randomization, and their use did not differ between groups.