# References

1 U.S. Preventive Services Task Force. Screening for osteoporosis: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2011 Mar 1;154(5):356-64. doi: searching 10.7326/0003-4819-154-5-201103010-00307. PMID: 21242341.21242341
2 Nelson HD, Haney EM, Dana T, . Screening for osteoporosis: an update for the U.S. Preventive Services Task Force. Ann Intern Med. 2010 Jul 20;153(2):99-111. doi: 10.7326/0003-4819-153-2-201007200-00262. PMID: 20621892.20621892
3 Nelson HD, Haney EM, Chou R, . Screening for Osteoporosis. Systematic Review to Update the 2002 U.S. Preventive Services Task Force Recommendation Evidence Synthesis No. 77. Report No.: 10-05145-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; July 2010.
4 American Congress of Obstetricians and Gynecologists. ACOG Practice Bulletin N. 129. Osteoporosis. Obstet Gynecol. 2012 Sep;120(3):718-34. doi: 10.1097/AOG.0b013e31826dc446. PMID: 22914492.22914492
5 Cosman F, de Beur SJ, LeBoff MS, . Clinician’s Guide to Prevention and Treatment of Osteoporosis. Osteoporos Int. 2014 Oct;25(10):2359-81. doi: 10.1007/s00198-014-2794-2. PMID: 25182228.25182228
6 Kanis JA, Melton LJ 3rd, Christiansen C, . The diagnosis of osteoporosis. J Bone Miner Res. 1994 Aug;9(8):1137-41. doi: 10.1002/jbmr.5650090802. PMID: 7976495.7976495
7 Link TM. Osteoporosis imaging: state of the art and advanced imaging. Radiology. 2012 Apr;263(1):3-17. doi: 10.1148/radiol.12110462; 10.1148/radiol.2633201203. PMID: 22438439.22438439
8 World Health Organization. WHO Scientific Group on the Assessment of Osteoporosis at Primary Health Care Level. Summary Meeting Report. Geneva, Switzerland: World Health Organization; 2004. http://www.who.int/chp/topics/Osteoporosis.pdf. Accessed 24 Aug, 2016.
9 Kanis JA on behalf of the World Health Organization Scientific Group. Assessment of Osteoporosis at the Primary Health Care Level. Technical Report. Sheffield, United Kingdom: World Health Organization Collaborating Centre for Metabolic Bone Diseases; 2008.
10 Ensrud KE. Epidemiology of fracture risk with advancing age. J Gerontol A Biol Sci Med Sci. 2013 Oct;68(10):1236-42. doi: 10.1093/gerona/glt092. PMID: 23833201.23833201
11 Wright NC, Looker AC, Saag KG, . The recent prevalence of osteoporosis and low bone mass in the United States based on bone mineral density at the femoral neck or lumbar spine. J Bone Miner Res. 2014 Nov;29(11):2520-6. doi: 10.1002/jbmr.2269. PMID: 24771492.24771492
12 Burge R, Dawson-Hughes B, Solomon DH, . Incidence and economic burden of osteoporosis-related fractures in the United States, 2005-2025. J Bone Miner Res. 2007 Mar;22(3):465-75. doi: 10.1359/jbmr.061113. PMID: 17144789.17144789
13 Brauer CA, Coca-Perraillon M, Cutler DM, . Incidence and mortality of hip fractures in the United States. JAMA. 2009 Oct 14;302(14):1573-9. doi: 10.1001/jama.2009.1462. PMID: 19826027.19826027
14 Abrahamsen B, van Staa T, Ariely R, . Excess mortality following hip fracture: a systematic epidemiological review. Osteoporos Int. 2009 Oct;20(10):1633-50. doi: 10.1007/s00198-009-0920-3 [doi]. PMID: 19421703.19421703
15 Haentjens P, Magaziner J, Colon-Emeric CS, . Meta-analysis: excess mortality after hip fracture among older women and men. Ann Intern Med. 2010 Mar 16;152(6):380-90. doi: 10.7326/0003-4819-152-6-201003160-00008. PMID: 20231569.20231569
16 Cauley JA, Thompson DE, Ensrud KC, . Risk of mortality following clinical fractures. Osteoporos Int. 2000;11(7):556-61. doi: 10.1007/s001980070075. PMID: 11069188.11069188
17 Center JR, Nguyen TV, Schneider D, . Mortality after all major types of osteoporotic fracture in men and women: an observational study. Lancet. 1999 Mar 13;353(9156):878-82. doi: 10.1016/s0140-6736(98)09075-8. PMID: 10093980.10093980
18 Leibson CL, Tosteson AN, Gabriel SE, . Mortality, disability, and nursing home use for persons with and without hip fracture: a population-based study. J Am Geriatr Soc. 2002 Oct;50(10):1644-50. PMID: 12366617.12366617
19 Bliuc D, Nguyen ND, Milch VE, . Mortality risk associated with low-trauma osteoporotic fracture and subsequent fracture in men and women. JAMA. 2009 Feb 4;301(5):513-21. doi: 10.1001/jama.2009.50. PMID: 19190316.19190316
20 Fitzpatrick LA. Secondary causes of osteoporosis. Mayo Clin Proc. 2002 May;77(5):453-68. doi: 10.4065/77.5.453. PMID: 12004995.12004995
21 Cranney A, Jamal SA, Tsang JF, . Low bone mineral density and fracture burden in postmenopausal women. CMAJ. 2007 Sep 11;177(6):575-80. doi: 10.1503/cmaj.070234. PMID: 17846439.17846439
22 Pasco JA, Seeman E, Henry MJ, . The population burden of fractures originates in women with osteopenia, not osteoporosis. Osteoporos Int. 2006;17(9):1404-9. doi: 10.1007/s00198-006-0135-9. PMID: 16699736.16699736
23 Schuit SC, van der Klift M, Weel AE, . Fracture incidence and association with bone mineral density in elderly men and women: the Rotterdam Study. Bone. 2004 Jan;34(1):195-202. PMID: 14751578.14751578
24 Stone KL, Seeley DG, Lui LY, . BMD at multiple sites and risk of fracture of multiple types: long-term results from the Study of Osteoporotic Fractures. J Bone Miner Res. 2003 Nov;18(11):1947-54. doi: 10.1359/jbmr.2003.18.11.1947. PMID: 14606506.14606506
25 Heaney RP. Bone mass, bone loss, and osteoporosis prophylaxis. Ann Intern Med. 1998 Feb 15;128(4):313-4. PMID: 9471936.9471936
26 Kanis JA, Johnell O, Oden A, . Ten year probabilities of osteoporotic fractures according to BMD and diagnostic thresholds. Osteoporos Int. 2001 Dec;12(12):989-95. doi: 10.1007/s001980170006 [doi]. PMID: 11846333.11846333
27 Richelson LS, Wahner HW, Melton LJ 3rd, . Relative contributions of aging and estrogen deficiency to postmenopausal bone loss. N Engl J Med. 1984 Nov 15;311(20):1273-5. doi: 10.1056/NEJM198411153112002. PMID: 6493283.6493283
28 Kleerekoper M. UpToDate. Screening for osteoporosis. The Netherlands: Wolters Kluwer; 2016. http://www.uptodate.com/contents/screening-for-osteoporosis?topicKey=ENDO%2F2046&...2016.
29 Cummings SR, Nevitt MC, Browner WS, . Risk factors for hip fracture in white women. Study of Osteoporotic Fractures Research Group. N Engl J Med. 1995 Mar 23;332(12):767-73. doi: 10.1056/nejm199503233321202. PMID: 7862179.7862179
30 Drake MT, Murad MH, Mauck KF, . Clinical review. Risk factors for low bone mass-related fractures in men: a systematic review and meta-analysis. J Clin Endocrinol Metab. 2012 Jun;97(6):1861-70. doi: 10.1210/jc.2011-3058. PMID: 22466344.22466344
31 Leslie WD. Clinical review: Ethnic differences in bone mass--clinical implications. J Clin Endocrinol Metab. 2012 Dec;97(12):4329-40. doi: 10.1210/jc.2012-2863. PMID: 23055542.23055542
32 Kanis JA, Oden A, Johnell O, . The use of clinical risk factors enhances the performance of BMD in the prediction of hip and osteoporotic fractures in men and women. Osteoporos Int. 2007 Aug;18(8):1033-46. doi: 10.1007/s00198-007-0343-y. PMID: 17323110.17323110
33 Kanis JA, Johansson H, Oden A, . The effects of a FRAX revision for the USA. Osteoporos Int. 2010 Jan;21(1):35-40. doi: 10.1007/s00198-009-1033-8 [doi]. PMID: 19705047.19705047
34 Raisz LG. Clinical practice. Screening for osteoporosis. N Engl J Med. 2005 Jul 14;353(2):164-71. doi: 10.1056/NEJMcp042092. PMID: 16014886.16014886
35 Bergot C, Laval-Jeantet AM, Hutchinson K, . A comparison of spinal quantitative computed tomography with dual energy X-ray absorptiometry in European women with vertebral and nonvertebral fractures. Calcif Tissue Int. 2001 Feb;68(2):74-82. PMID: 11310350.11310350
36 Greenspan SL, Bone HG, Ettinger MP, . Effect of recombinant human parathyroid hormone (1-84) on vertebral fracture and bone mineral density in postmenopausal women with osteoporosis: a randomized trial. Ann Intern Med. 2007 Mar 6;146(5):326-39. PMID: 17339618.17339618
37 Kanis JA. Welcome to FRAX®. UK: World Health Organization Collaborating Centre for Metabolic Bone Diseases, University of Sheffield, UK n.d. https://www.shef.ac.uk/FRAX/. Accessed 10 Aug, 2016.
38 Yates AJ, Ross PD, Lydick E, . Radiographic absorptiometry in the diagnosis of osteoporosis. Am J Med. 1995 Feb 27;98(2A):41S-7S. PMID: 7709934.7709934
39 Langdahl B, Ferrari S, Dempster DW. Bone modeling and remodeling: potential as therapeutic targets for the treatment of osteoporosis. Ther Adv Musculoskelet Dis. 2016 Dec;8(6):225-35. doi: 10.1177/1759720X16670154. PMID: 28255336.28255336
40 Radius Health. TYMLOS pen brochure. Reference ID: 4090621. Waltham, MA: Radius Health, Inc.; n.d.
41 Augustine M, Horwitz MJ. Parathyroid hormone and parathyroid hormone-related protein analogs as therapies for osteoporosis. Curr Osteoporos Rep. 2013 Dec;11(4):400-6. doi: 10.1007/s11914-013-0171-2. PMID: 24078470.24078470
42 Feurer E, Chapurlat R. Emerging drugs for osteoporosis. Expert Opin Emerg Drugs. 2014 Sep;19(3):385-95. doi: 10.1517/14728214.2014.936377. PMID: 24995794.24995794
43 Walsh N. Stroke Risk Dooms Once-Promising Bone Drug. New York, NY: MedPage Today, LLC; 2016. http://www.medpagetoday.com/meetingcoverage/asbmr/60324. Accessed October 31, 2016.
44 Gregg EW, Cauley JA, Seeley DG, . Physical activity and osteoporotic fracture risk in older women. Study of Osteoporotic Fractures Research Group. Ann Intern Med. 1998 Jul 15;129(2):81-8. PMID: 9669990.9669990
45 Kanis JA, Harvey NC, Cooper C, . A systematic review of intervention thresholds based on FRAX: A report prepared for the National Osteoporosis Guideline Group and the International Osteoporosis Foundation. Arch Osteoporos. 2016 Dec;11(1):25. doi: 10.1007/s11657-016-0278-z. PMID: 27465509.27465509
46 Tosteson AN, Melton LJ 3rd, Dawson-Hughes B, . Cost-effective osteoporosis treatment thresholds: the United States perspective. Osteoporos Int. 2008 Apr;19(4):437-47. doi: 10.1007/s00198-007-0550-6. PMID: 18292976.18292976
47 Scottish Intercollegiate Guidelines Network. Management of osteoporosis and the prevention of fragility fractures. (SIGN publication no. 142). Edinburgh: Scottish Intercollegiate Guidelines Network (SIGN); 2015. http://www.sign.ac.uk. Accessed 24 Aug, 2016.
48 North American Menopause Society (NAMS). Management of osteoporosis in postmenopausal women: 2010 position statement of The North American Menopause Society. Menopause. 2010;17:25-54.20061894
49 Jeremiah MP, Unwin BK, Greenawald MH, . Diagnosis and management of osteoporosis. Am Fam Physician. 2015 Aug 15;92(4):261-8. PMID: 26280231.26280231
50 Florence R, Allen S, Benedict L, . Health Care Guideline. Diagnosis and treatment of osteoporosis. Bloomington, MN: Institute for Clinical Systems Improvement (ICSI); 2013. https://www.icsi.org/guidelines__more/catalog_guidelines_and_more/catalog_guidelines/catalog_musculoskeletal_guidelines/osteoporosis/. Accessed 24 Aug, 2016.
51 National Committee for Quality Assurance. 2015 State of Health Care Quality Table of Contents. Washington, DC: National Committee for Quality Assurance; 2015. http://www.ncqa.org/report-cards/health-plans/state-of-health-care-quality/2015-table-of-contents/osteoporosis. Accessed 10 Aug, 2016.
52 Good Stewardship Working Group. The “top 5” lists in primary care: meeting the responsibility of professionalism. Arch Intern Med. 2011 Aug 08;171(15):1385-90. doi: 10.1001/archinternmed.2011.231. PMID: 21606090.21606090
53 Kale MS, Bishop TF, Federman AD, . “Top 5” lists top $5 billion. Arch Intern Med. 2011 Nov 14;171(20):1856-8. doi: 10.1001/archinternmed.2011.501. PMID: 21965814.21965814
54 Amarnath AL, Franks P, Robbins JA, . Underuse and Overuse of Osteoporosis Screening in a Regional Health System: a Retrospective Cohort Study. J Gen Intern Med. 2015 Dec;30(12):1733-40. doi: 10.1007/s11606-015-3349-8. PMID: 25986135.25986135
55 Fryar CD, Gu Q, Ogden CL. Anthropometric Reference Data for Children and Adults: United States 2007-2010 Vital and Health Statistics. Series 11, Number 252. Washington, DC: U.S. Department of Health and Human Services; October 2012. http://www.cdc.gov/nchs/data/series/sr_11/sr11_252.pdf
56 Bansal S, Pecina JL, Merry SP, . US Preventative Services Task Force FRAX threshold has a low sensitivity to detect osteoporosis in women ages 50-64 years. Osteoporos Int. 2015 Apr;26(4):1429-33. doi: 10.1007/s00198-015-3026-0. PMID: 25614141.25614141
57 Crandall CJ, Larson J, Gourlay ML, . Osteoporosis screening in postmenopausal women 50 to 64 years old: comparison of US Preventive Services Task Force strategy and two traditional strategies in the Women’s Health Initiative. J Bone Miner Res. 2014 Jul;29(7):1661-6. doi: 10.1002/jbmr.2174 [doi]. PMID: 24431262.24431262
58 Crandall CJ, Larson JC, Watts NB, . Comparison of fracture risk prediction by the US Preventive Services Task Force strategy and two alternative strategies in women 50-64 years old in the women’s health initiative. J Clin Endocrinol Metab. 2014;99(12):4514-22.25322268
59 United Nations Development Programme. Human Development Report 2015: Work for Human Development. Table 1: Human Development Index and its components n.d. http://hdr.undp.org/en/composite/HDI Accessed 24 Aug, 2016.
60 U.S. Preventive Services Task Force. Policies and Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. http://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes. Accessed 24 Aug, 2016.
61 Higgins JP, Green S. Cochrane Handbook for Systematic Reviews of Interventions. The Cochrane Collaboration; 2011. www.handbook.cochrane.org. Accessed 24 Aug, 2016.
62 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. 2012 Feb;65(2):163-78. doi: 10.1016/j.jclinepi.2011.05.008. PMID: 21959223.21959223
63 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529-36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
64 Wolf R. PROBAST. Kleijnen Systematic Reviews Ltd; 2014. www.systematic-reviews.com/probast. Accessed 7 January, 2015.
65 International Society for Clinical Densitometry. 2015 ISCD Official Positions Adult. Middletown, CT: International Society for Clinical Densitometry, Inc; 2015. http://www.iscd.org/official-positions/2015-iscd-official-positions-adult/ Accessed 10 Aug, 2016.
66 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014 Feb 18;160(4):267-70. doi: 10.7326/M13-2886. PMID: 24727843.24727843
67 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539-58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
68 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 6;327(7414):557-60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
69 Rucker G, Schwarzer G, Carpenter JR, . Undue reliance on I(2) in assessing heterogeneity may mislead. BMC Med Res Methodol. 2008;8:79. doi: 10.1186/1471-2288-8-79. PMID: 19036172.19036172
70 Wallace BC, Dahabreh IJ, Trikalinos TA, . Closing the gap between methodologists and end-users: R as a computational back-end. Journal of Statistical Software. 2012 Jun;49(5):1-15. PMID: WOS:000305990500001.
71 Comprehensive Meta Analysis. Version 3.3.070. Englewood, NJ; 2014.
72 Shepstone L, Lenaghan E, Cooper C, . Screening in the community to reduce fractures in older women (SCOOP): a randomised controlled trial. Lancet. 2018 Feb 24;391(10122):741-7. doi: 10.1016/s0140-6736(17)32640-5. PMID: 29254858.29254858
73 Nelson HD, Fu R, Humphrey L, . Comparative Effectiveness of Medications To Reduce Risk of Primary Breast Cancer in Women AHRQ Comparative Effectiveness Reviews. Rockville, MD: Agency for Healthcare Research and Quality; 2009. PMID: 2070404020704040.
74 Nelson HD, Fu R, Griffin JC, . Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann Intern Med. 2009 Nov 17;151(10):703-15, w-226-35. doi: 10.7326/0003-4819-151-10-200911170-00147. PMID: 19920271.19920271
75 Crandall CJ. Risk Assessment Tools for Osteoporosis Screening in Postmenopausal Women: A Systematic Review. Curr Osteoporos Rep. 2015 Oct;13(5):287-301. doi: 10.1007/s11914-015-0282-z. PMID: 26233285.26233285
76 Marques A, Ferreira RJ, Santos E, . The accuracy of osteoporotic fracture risk prediction tools: a systematic review and meta-analysis. Ann Rheum Dis. 2015 Nov;74(11):1958-67. doi: 10.1136/annrheumdis-2015-207907. PMID: 26248637.26248637
77 Adler RA, Tran MT, Petkov VI. Performance of the Osteoporosis Self-assessment Screening Tool for osteoporosis in American men. Mayo Clin Proc. 2003 Jun;78(6):723-7. doi: 10.4065/78.6.723. PMID: 12934782.12934782
78 Ben Sedrine W, Devogelaer JP, Kaufman JM, . Evaluation of the simple calculated osteoporosis risk estimation (SCORE) in a sample of white women from Belgium. Bone. 2001 Oct;29(4):374-80. PMID: 11595621.11595621
79 Gourlay ML, Miller WC, Richy F, . Performance of osteoporosis risk assessment tools in postmenopausal women aged 45-64 years. Osteoporos Int. 2005 Aug;16(8):921-7. doi: 10.1007/s00198-004-1775-2 [doi]. PMID: 16028108.16028108
80 Richy F, Gourlay M, Ross PD, . Validation and comparative evaluation of the osteoporosis self-assessment tool (OST) in a Caucasian population from Belgium. QJM. 2004 Jan;97(1):39-46. PMID: 14702510.14702510
81 Brenneman SK, Lacroix AZ, Buist DS, . Evaluation of decision rules to identify postmenopausal women for intervention related to osteoporosis. Dis Manag. 2003 Fall;6(3):159-68. doi: 10.1089/109350703322425509. PMID: 14570384.14570384
82 Cadarette SM, Jaglal SB, Murray TM, . Evaluation of decision rules for referring women for bone densitometry by dual-energy x-ray absorptiometry. JAMA. 2001 Jul 4;286(1):57-63. PMID: 11434827.11434827
83 Cadarette SM, McIsaac WJ, Hawker GA, . The validity of decision rules for selecting women with primary osteoporosis for bone mineral density testing. Osteoporos Int. 2004 May;15(5):361-6. doi: 10.1007/s00198-003-1552-7. PMID: 14730421.14730421
84 Cass AR, Shepherd AJ, Carlson CA. Osteoporosis risk assessment and ethnicity: validation and comparison of 2 clinical risk stratification instruments. J Gen Intern Med. 2006 Jun;21(6):630-5. doi: 10.1111/j.1525-1497.2006.00459.x. PMID: 16808748.16808748
85 Cass AR, Shepherd AJ. Validation of the Male Osteoporosis Risk Estimation Score (MORES) in a primary care setting. J Am Board Fam Med. 2013 Jul-Aug;26(4):436-44. doi: 10.3122/jabfm.2013.04.120182. PMID: 23833159.23833159
86 Chan SP, Teo CC, Ng SA, . Validation of various osteoporosis risk indices in elderly Chinese females in Singapore. Osteoporos Int. 2006;17(8):1182-8. doi: 10.1007/s00198-005-0051-4 [doi]. PMID: 16699739.16699739
87 Cook RB, Collins D, Tucker J, . Comparison of questionnaire and quantitative ultrasound techniques as screening tools for DXA. Osteoporos Int. 2005 Dec;16(12):1565-75. doi: 10.1007/s00198-005-1864-x [doi]. PMID: 15883661.15883661
88 D’Amelio P, Tamone C, Pluviano F, . Effects of lifestyle and risk factors on bone mineral density in a cohort of Italian women: suggestion for a new decision rule. Calcif Tissue Int. 2005 Aug;77(2):72-8. doi: 10.1007/s00223-004-0253-3. PMID: 16059776.16059776
89 D’Amelio P, Spertino E, Martino F, . Prevalence of postmenopausal osteoporosis in Italy and validation of decision rules for referring women for bone densitometry. Calcif Tissue Int. 2013;92(5):437-43.23334353
90 Geusens P, Hochberg MC, van der Voort DJ, . Performance of risk indices for identifying low bone density in postmenopausal women. Mayo Clin Proc. 2002 Jul;77(7):629-37. PMID: 12108600.12108600
91 Gnudi S, Sitta E. Clinical risk factor evaluation to defer postmenopausal women from bone mineral density measurement: an Italian study. J Clin Densitom. 2005 Summer;8(2):199-205. PMID: 15908708.15908708
92 Gourlay ML, Powers JM, Lui LY, . Clinical performance of osteoporosis risk assessment tools in women aged 67 years and older. Osteoporos Int. 2008 Aug;19(8):1175-83. doi: 10.1007/s00198-007-0555-1. PMID: 18219434.18219434
93 Harrison EJ, Adams JE. Application of a triage approach to peripheral bone densitometry reduces the requirement for central DXA but is not cost effective. Calcif Tissue Int. 2006 Oct;79(4):199-206. doi: 10.1007/s00223-005-0302-6. PMID: 16969598.16969598
94 Jimenez-Nunez FG, Manrique-Arija S, Urena-Garnica I, . Reducing the need for central dual-energy X-ray absorptiometry in postmenopausal women: efficacy of a clinical algorithm including peripheral densitometry. Calcif Tissue Int. 2013 Jul;93(1):62-8. doi: 10.1007/s00223-013-9728-4 [doi]. PMID: 23608922.23608922
95 Kung AW, Ho AY, Sedrine WB, . Comparison of a simple clinical risk index and quantitative bone ultrasound for identifying women at increased risk of osteoporosis. Osteoporos Int. 2003 Sep;14(9):716-21. doi: 10.1007/s00198-003-1428-x [doi]. PMID: 12897978.12897978
96 Kung AW, Ho AY, Ross PD, . Development of a clinical assessment tool in identifying Asian men with low bone mineral density and comparison of its usefulness to quantitative bone ultrasound. Osteoporos Int. 2005 Jul;16(7):849-55. doi: 10.1007/s00198-004-1778-z [doi]. PMID: 15611839.15611839
97 Lynn HS, Woo J, Leung PC, . An evaluation of osteoporosis screening tools for the osteoporotic fractures in men (MrOS) study. Osteoporos Int. 2008 Jul;19(7):1087-92. doi: 10.1007/s00198-007-0553-3. PMID: 18239959.18239959
98 Machado P, Coutinho M, da Silva JA. Selecting men for bone densitometry: performance of osteoporosis risk assessment tools in Portuguese men. Osteoporos Int. 2010 Jun;21(6):977-83. doi: 10.1007/s00198-009-1036-5 [doi]. PMID: 19727909.19727909
99 Martinez-Aguila D, Gomez-Vaquero C, Rozadilla A, . Decision rules for selecting women for bone mineral density testing: application in postmenopausal women referred to a bone densitometry unit. J Rheumatol. 2007 Jun;34(6):1307-12. PMID: 17552058.17552058
100 Mauck KF, Cuddihy MT, Atkinson EJ, . Use of clinical prediction rules in detecting osteoporosis in a population-based sample of postmenopausal women. Arch Intern Med. 2005 Mar 14;165(5):530-6. doi: 10.1001/archinte.165.5.530. PMID: 15767529.15767529
101 McLeod KM, Johnson S, Rasali D, . Discriminatory performance of the calcaneal quantitative ultrasound and osteoporosis self-assessment tool to select older women for dual-energy x-ray absorptiometry. J Clin Densitom. 2015 Apr-Jun;18(2):157-64. doi: 10.1016/j.jocd.2015.02.006. PMID: 25937306.25937306
102 Morin S, Tsang JF, Leslie WD. Weight and body mass index predict bone mineral density and fractures in women aged 40 to 59 years. Osteoporos Int. 2009 Mar;20(3):363-70. doi: 10.1007/s00198-008-0688-x [doi]. PMID: 18633665.18633665
103 Nguyen TV, Center JR, Pocock NA, . Limited utility of clinical indices for the prediction of symptomatic fracture risk in postmenopausal women. Osteoporos Int. 2004 Jan;15(1):49-55. doi: 10.1007/s00198-003-1511-3. PMID: 14593453.14593453
104 Oh SM, Nam BH, Rhee Y, . Development and validation of osteoporosis risk-assessment model for Korean postmenopausal women. J Bone Miner Metab. 2013 Jul;31(4):423-32. doi: 10.1007/s00774-013-0426-0 [doi]. PMID: 23420298.23420298
105 Oh SM, Song BM, Nam BH, . Development and validation of osteoporosis risk-assessment model for Korean men. Yonsei Med J. 2016 Jan;57(1):187-96. doi: 10.3349/ymj.2016.57.1.187. PMID: 26632400.26632400
106 Pang WY, Inderjeeth CA. FRAX without bone mineral density versus osteoporosis self-assessment screening tool as predictors of osteoporosis in primary screening of individuals aged 70 and older. J Am Geriatr Soc. 2014 Mar;62(3):442-6. doi: 10.1111/jgs.12696 [doi]. PMID: 24617899.24617899
107 Park HM, Sedrine WB, Reginster JY, . Korean experience with the OSTA risk index for osteoporosis: a validation study. J Clin Densitom. 2003 Fall;6(3):247-50. PMID: 14514994.14514994
108 Richards JS, Lazzari AA, Teves Qualler DA, . Validation of the osteoporosis self-assessment tool in US male veterans. J Clin Densitom. 2014;17(1):32-7.23489972
109 Rud B, Jensen JE, Mosekilde L, . Performance of four clinical screening tools to select peri- and early postmenopausal women for dual X-ray absorptiometry. Osteoporos Int. 2005 Jul;16(7):764-72. doi: 10.1007/s00198-004-1748-5. PMID: 15986263.15986263
110 Shepherd AJ, Cass AR, Carlson CA, . Development and internal validation of the male osteoporosis risk estimation score. Ann Fam Med. 2007 Nov-Dec;5(6):540-6. doi: 10.1370/afm.753. PMID: 18025492.18025492
111 Sinnott B, Kukreja S, Barengolts E. Utility of screening tools for the prediction of low bone mass in African American men. Osteoporos Int. 2006;17(5):684-92. doi: 10.1007/s00198-005-0034-5. PMID: 16523248.16523248
112 Zimering MB, Shin JJ, Shah J, . Validation of a novel risk estimation tool for predicting low bone density in Caucasian and African American men veterans. J Clin Densitom. 2007 Jul-Sep;10(3):289-97. doi: 10.1016/j.jocd.2007.03.001. PMID: 17459748.17459748
113 Leslie WD, Lix LM, Johansson H, . Selection of women aged 50-64 yr for bone density measurement. J Clin Densitom. 2013 Oct-Dec;16(4):570-8. doi: 10.1016/j.jocd.2013.01.004. PMID: 23452870.23452870
114 Cass AR, Shepherd AJ, Asirot R, . Comparison of the Male Osteoporosis Risk Estimation Score (MORES) With FRAX in Identifying Men at Risk for Osteoporosis. Ann Fam Med. 2016 Jul;14(4):365-9. doi: 10.1370/afm.1945. PMID: 27401426.27401426
115 Shepherd AJ, Cass AR, Ray L. Determining risk of vertebral osteoporosis in men: validation of the male osteoporosis risk estimation score. J Am Board Fam Med. 2010 Mar-Apr;23(2):186-94. doi: 10.3122/jabfm.2010.02.090027. PMID: 20207929.20207929
116 Boonen S, Nijs J, Borghs H, . Identifying postmenopausal women with osteoporosis by calcaneal ultrasound, metacarpal digital X-ray radiogrammetry and phalangeal radiographic absorptiometry: a comparative study. Osteoporos Int. 2005 Jan;16(1):93-100. doi: 10.1007/s00198-004-1660-z [doi]. PMID: 15197540.15197540
117 Minnock E, Cook R, Collins D, . Using risk factors and quantitative ultrasound to identify postmenopausal caucasian women at risk of osteoporosis. J Clin Densitom. 2008 Oct-Dec;11(4):485-93. doi: 10.1016/j.jocd.2008.04.002. PMID: 18539491.18539491
118 Richy F, Deceulaer F, Ethgen O, . Development and validation of the ORACLE score to predict risk of osteoporosis. Mayo Clin Proc. 2004 Nov;79(11):1402-8. doi: 10.4065/79.11.1402. PMID: 15544019.15544019
119 Nayak S, Edwards DL, Saleh AA, . Performance of risk assessment instruments for predicting osteoporotic fracture risk: a systematic review. Osteoporos Int. 2014 Jan;25(1):23-49. doi: 10.1007/s00198-013-2504-5. PMID: 24105431.24105431
120 Nayak S, Olkin I, Liu H, . Meta-analysis: accuracy of quantitative ultrasound for identifying patients with osteoporosis. Ann Intern Med. 2006 Jun 6;144(11):832-41. PMID: 16754925.16754925
121 Rubin KH, Friis-Holmberg T, Hermann AP, . Risk assessment tools to identify women with increased risk of osteoporotic fracture: complexity or simplicity? A systematic review. J Bone Miner Res. 2013 Aug;28(8):1701-17. doi: 10.1002/jbmr.1956. PMID: 23592255.23592255
122 Steurer J, Haller C, Hauselmann H, . Clinical value of prognostic instruments to identify patients with an increased risk for osteoporotic fractures: systematic review. PLoS One. 2011;6(5):e19994. doi: 10.1371/journal.pone.0019994. PMID: 21625596.21625596
123 Leslie WD, Morin S, Lix LM, . Fracture risk assessment without bone density measurement in routine clinical practice. Osteoporos Int. 2012 Jan;23(1):75-85. doi: 10.1007/s00198-011-1747-2 [doi]. PMID: 21850546.21850546
124 van Geel TA, Eisman JA, Geusens PP, . The utility of absolute risk prediction using FRAX(R) and Garvan Fracture Risk Calculator in daily practice. Maturitas. 2014 Feb;77(2):174-9. doi: 10.1016/j.maturitas.2013.10.021. PMID: 24287178.24287178
125 Azagra R, Roca G, Encabo G, . FRAX(R) tool, the WHO algorithm to predict osteoporotic fractures: the first analysis of its discriminative and predictive ability in the Spanish FRIDEX cohort. BMC Musculosk elet Disord. 2012;13:204. doi: 10.1186/1471-2474-13-204. PMID: 23088223.23088223
126 Henry MJ, Pasco JA, Merriman EN, . Fracture risk score and absolute risk of fracture. Radiology. 2011 May;259(2):495-501. doi: 10.1148/radiol.10101406. PMID: 21292868.21292868
127 Leslie WD, Lix LM, Johansson H, . A comparative study of using non-hip bone density inputs with FRAX(R). Osteoporos Int. 2012 Mar;23(3):853-60. doi: 10.1007/s00198-011-1814-8 [doi]. PMID: 22008881.22008881
128 Rubin KH, Abrahamsen B, Friis-Holmberg T, . Comparison of different screening tools (FRAX(R), OST, ORAI, OSIRIS, SCORE and age alone) to identify women with increased risk of fracture. A population-based prospective study. Bone. 2013 Sep;56(1):16-22. doi: 10.1016/j.bone.2013.05.002. PMID: 23669650.23669650
129 Ahmed LA, Nguyen ND, Bjornerem A, . External validation of the Garvan nomograms for predicting absolute fracture risk: the Tromso study. PLoS One. 2014;9(9):e107695. doi: 10.1371/journal.pone.0107695. PMID: 25255221.25255221
130 Hippisley-Cox J, Coupland C. Derivation and validation of updated QFracture algorithm to predict risk of osteoporotic fracture in primary care in the United Kingdom: prospective open cohort study. BMJ. 2012;344:e3427. PMID: 22619194.22619194
131 Leslie WD, Lix LM. Simplified 10-year absolute fracture risk assessment: a comparison of men and women. J Clin Densitom. 2010 Apr-Jun;13(2):141-6. doi: 10.1016/j.jocd.2010.02.002. PMID: 20435264.20435264
132 Iki M, Fujita Y, Tamaki J, . Trabecular bone score may improve FRAX(R) prediction accuracy for major osteoporotic fractures in elderly Japanese men: the Fujiwara-kyo Osteoporosis Risk in Men (FORMEN) Cohort Study. Osteoporos Int. 2015 Jun;26(6):1841-8. doi: 10.1007/s00198-015-3092-3. PMID: 25752623.25752623
133 Kalvesten J, Lui LY, Brismar T, . Digital X-ray radiogrammetry in the study of osteoporotic fractures: Comparison to dual energy X-ray absorptiometry and FRAX. Bone. 2016:30-5. doi: 10.1016/j.bone.2016.02.011. PMID: CN-01137905.
134 Ahmed LA, Schirmer H, Fonnebo V, . Validation of the Cummings’ risk score; how well does it identify women with high risk of hip fracture: the Tromso Study. Eur J Epidemiol. 2006;21(11):815-22. doi: 10.1007/s10654-006-9072-3. PMID: 17119878.17119878
135 Albertsson D, Mellstrom D, Petersson C, . Hip and fragility fracture prediction by 4-item clinical risk score and mobile heel BMD: a women cohort study. BMC Musculoskelet Disord. 2010;11:55. doi: 10.1186/1471-2474-11-55. PMID: 20334634.20334634
136 Albertsson DM, Mellstrom D, Petersson C, . Validation of a 4-item score predicting hip fracture and mortality risk among elderly women. Ann Fam Med. 2007 Jan-Feb;5(1):48-56. doi: 10.1370/afm.602. PMID: 17261864.17261864
137 van Staa TP, Geusens P, Kanis JA, . A simple clinical score for estimating the long-term risk of fracture in post-menopausal women. QJM. 2006 Oct;99(10):673-82. doi: 10.1093/qjmed/hcl094. PMID: 16998210.16998210
138 Leslie WD, Tsang JF, Lix LM. Simplified system for absolute fracture risk assessment: clinical validation in Canadian women. J Bone Miner Res. 2009 Feb;24(2):353-60. doi: 10.1359/jbmr.081012 [doi]. PMID: 19514851.19514851
139 Nguyen ND, Frost SA, Center JR, . Development of prognostic nomograms for individualizing 5-year and 10-year fracture risks. Osteoporos Int. 2008 Oct;19(10):1431-44. doi: 10.1007/s00198-008-0588-0. PMID: 18324342.18324342
140 Cummins NM, Poku EK, Towler MR, . clinical risk factors for osteoporosis in Ireland and the UK: a comparison of FRAX and QFractureScores. Calcif Tissue Int. 2011 Aug;89(2):172-7. doi: 10.1007/s00223-011-9504-2 [doi]. PMID: 21647704.21647704
141 Wei GS, Jackson JL. Postmenopausal bone density referral decision rules: correlation with clinical fractures. Mil Med. 2004 Dec;169(12):1000-4. PMID: 15646195.15646195
142 Sandhu SK, Nguyen ND, Center JR, . Prognosis of fracture: evaluation of predictive accuracy of the FRAX algorithm and Garvan nomogram. Osteoporos Int. 2010 May;21(5):863-71. doi: 10.1007/s00198-009-1026-7. PMID: 19633880.19633880
143 Colon-Emeric CS, Pieper CF, Artz MB. Can historical and functional risk factors be used to predict fractures in community-dwelling older adults? development and validation of a clinical tool. Osteoporos Int. 2002 Dec;13(12):955-61. doi: 10.1007/s001980200133 [doi]. PMID: 12459938.12459938
144 Nguyen TV, Center JR, Eisman JA. Bone mineral density-independent association of quantitative ultrasound measurements and fracture risk in women. Osteoporos Int. 2004 Dec;15(12):942-7. doi: 10.1007/s00198-004-1717-z [doi]. PMID: 15309384.15309384
145 Black DM, Steinbuch M, Palermo L, . An assessment tool for predicting fracture risk in postmenopausal women. Osteoporos Int. 2001;12(7):519-28. doi: 10.1007/s001980170072 [doi]. PMID: 11527048.11527048
146 Girman CJ, Chandler JM, Zimmerman SI, . Prediction of fracture in nursing home residents. J Am Geriatr Soc. 2002 Aug;50(8):1341-7. PMID: 12164989.12164989
147 Fraser LA, Langsetmo L, Berger C, . Fracture prediction and calibration of a Canadian FRAX(R) tool: a population-based report from CaMos. Osteoporos Int. 2011 Mar;22(3):829-37. doi: 10.1007/s00198-010-1465-1 [doi]. PMID: 21161508.21161508
148 Leslie WD, Lix LM, Johansson H, . Independent clinical validation of a Canadian FRAX tool: fracture prediction and model calibration. J Bone Miner Res. 2010 Nov;25(11):2350-8. doi: 10.1002/jbmr.123 [doi]. PMID: 20499367.20499367
149 Langsetmo L, Nguyen TV, Nguyen ND, . Independent external validation of nomograms for predicting risk of low-trauma fracture and hip fracture. CMAJ. 2011 Feb 8;183(2):E107-14. doi: 10.1503/cmaj.100458. PMID: 21173069.21173069
150 Hippisley-Cox J, Coupland C. Predicting risk of osteoporotic fracture in men and women in England and Wales: prospective derivation and validation of QFractureScores. BMJ. 2009;339:b4229. PMID: 19926696.19926696
151 Robbins J, Aragaki AK, Kooperberg C, . Factors associated with 5-year risk of hip fracture in postmenopausal women. JAMA. 2007 Nov 28;298(20):2389-98. doi: 10.1001/jama.298.20.2389. PMID: 18042916.18042916
152 Koh LK, Ben Sedrine W, Torralba TP, . A simple tool to identify Asian women at increased risk of osteoporosis. Osteoporos Int. 2001;12(8):699-705. doi: DOI10.1007/s001980170070. PMID: WOS:000171206900011. 11580084
153 Lydick E, Cook K, Turpin J, . Development and validation of a simple questionnaire to facilitate identification of women likely to have low bone density. Am J Manag Care. 1998 Jan;4(1):37-48. PMID: 10179905.10179905
154 Tanaka S, Yoshimura N, Kuroda T, . The Fracture and Immobilization Score (FRISC) for risk assessment of osteoporotic fracture and immobilization in postmenopausal women--A joint analysis of the Nagano, Miyama, and Taiji Cohorts. Bone. 2010 Dec;47(6):1064-70. doi: 10.1016/j.bone.2010.08.019. PMID: 20832514.20832514
155 Henry MJ, Pasco JA, Sanders KM, . Fracture Risk (FRISK) Score: Geelong Osteoporosis Study. Radiology. 2006 Oct;241(1):190-6. doi: 10.1148/radiol.2411051290. PMID: 16928979.16928979
156 Ettinger B, Hillier TA, Pressman A, . Simple computer model for calculating and reporting 5-year osteoporotic fracture risk in postmenopausal women. J Womens Health (Larchmt). 2005 Mar;14(2):159-71. doi: 10.1089/jwh.2005.14.159 [doi]. PMID: 15775734.15775734
157 Cadarette SM, Jaglal SB, Kreiger N, . Development and validation of the Osteoporosis Risk Assessment Instrument to facilitate selection of women for bone densitometry. CMAJ. 2000 May 2;162(9):1289-94. PMID: 10813010.10813010
158 Sedrine WB, Chevallier T, Zegels B, . Development and assessment of the Osteoporosis Index of Risk (OSIRIS) to facilitate selection of women for bone densitometry. Gynecol Endocrinol. 2002 Jun;16(3):245-50. doi: 10.1080/gye.16.3.245.250. PMID: 12192897.12192897
159 Lo JC, Pressman AR, Chandra M, . Fracture risk tool validation in an integrated healthcare delivery system. Am J Manag Care. 2011 Mar;17(3):188-94. . PMID: 21504255.21504255
160 Hundrup YA, Jacobsen RK, Andreasen AH, . Validation of a 5-year risk score of hip fracture in postmenopausal women. The Danish Nurse Cohort Study. Osteoporos Int. 2010 Dec;21(12):2135-42. doi: 10.1007/s00198-010-1176-7 [doi]. PMID: 20157806.20157806
161 Siminoski K, Leslie WD, Frame H, . Recommendations for bone mineral density reporting in Canada: a shift to absolute fracture risk assessment. J Clin Densitom. 2007 Apr-Jun;10(2):120-3. doi: 10.1016/j.jocd.2007.01.001. PMID: 17485028.17485028
162 Stewart A, Kumar V, Reid DM. Long-term fracture prediction by DXA and QUS: a 10-year prospective study. J Bone Miner Res. 2006 Mar;21(3):413-8. doi: 10.1359/jbmr.051205. PMID: 16491289.16491289
163 Bauer DC, Ewing SK, Cauley JA, . Quantitative ultrasound predicts hip and non-spine fracture in men: the MrOS study. Osteoporos Int. 2007 Jun;18(6):771-7. doi: 10.1007/s00198-006-0317-5 [doi]. PMID: 17273893.17273893
164 Iki M, Tamaki J, Kadowaki E, . Trabecular bone score (TBS) predicts vertebral fractures in Japanese women over 10 years independently of bone density and prevalent vertebral deformity: the Japanese Population-Based Osteoporosis (JPOS) cohort study. J Bone Miner Res. 2014 Feb;29(2):399-407. doi: 10.1002/jbmr.2048 [doi]. PMID: 23873699.23873699
165 Hans D, Goertzen AL, Krieg MA, . Bone microarchitecture assessed by TBS predicts osteoporotic fractures independent of bone density: the Manitoba study. J Bone Miner Res. 2011 Nov;26(11):2762-9. doi: 10.1002/jbmr.499 [doi]. PMID: 21887701.21887701
166 Leslie WD, Aubry-Rozier B, Lamy O, . TBS (trabecular bone score) and diabetes-related fracture risk. J Clin Endocrinol Metab. 2013 Feb;98(2):602-9. doi: 10.1210/jc.2012-3118. PMID: 23341489.23341489
167 Kwok T, Khoo CC, Leung J, . Predictive values of calcaneal quantitative ultrasound and dual energy X ray absorptiometry for non-vertebral fracture in older men: results from the MrOS study (Hong Kong). Osteoporos Int. 2012 Mar;23(3):1001-6. doi: 10.1007/s00198-011-1634-x [doi]. PMID: 21528361.21528361
168 Chan MY, Nguyen ND, Center JR, . Absolute fracture-risk prediction by a combination of calcaneal quantitative ultrasound and bone mineral density. Calcif Tissue Int. 2012 Feb;90(2):128-36. doi: 10.1007/s00223-011-9556-3 [doi]. PMID: 22179560.22179560
169 Tanaka S, Kuroda T, Saito M, . Urinary pentosidine improves risk classification using fracture risk assessment tools for postmenopausal women. J Bone Miner Res. 2011 Nov;26(11):2778-84. doi: 10.1002/jbmr.467 [doi]. PMID: 21773990.21773990
170 Sund R, Honkanen R, Johansson H, . Evaluation of the FRAX model for hip fracture predictions in the population-based Kuopio Osteoporosis Risk Factor and Prevention Study (OSTPRE). Calcif Tissue Int. 2014 Jul;95(1):39-45. doi: 10.1007/s00223-014-9860-9 [doi]. PMID: 24792689.24792689
171 Bolland MJ, Siu AT, Mason BH, . Evaluation of the FRAX and Garvan fracture risk calculators in older women. J Bone Miner Res. 2011 Feb;26(2):420-7. doi: 10.1002/jbmr.215. PMID: 20721930.20721930
172 Sornay-Rendu E, Munoz F, Delmas PD, . The FRAX tool in French women: How well does it describe the real incidence of fracture in the OFELY cohort? J Bone Miner Res. 2010 Oct;25(10):2101-7. doi: 10.1002/jbmr.106. PMID: 20499352.20499352
173 Tremollieres FA, Pouilles JM, Drewniak N, . Fracture risk prediction using BMD and clinical risk factors in early postmenopausal women: sensitivity of the WHO FRAX tool. J Bone Miner Res. 2010 May;25(5):1002-9. doi: 10.1002/jbmr.12. PMID: 20200927.20200927
174 Friis-Holmberg T, Rubin KH, Brixen K, . Fracture risk prediction using phalangeal bone mineral density or FRAX((R))?-A Danish cohort study on men and women. J Clin Densitom. 2014 Jan-Mar;17(1):7-15. doi: 10.1016/j.jocd.2013.03.014. PMID: 23623379.23623379
175 Tebe Cordomi C, Del Rio LM, Di Gregorio S, . Validation of the FRAX predictive model for major osteoporotic fracture in a historical cohort of Spanish women. J Clin Densitom. 2013 Apr-Jun;16(2):231-7. doi: 10.1016/j.jocd.2012.05.007. PMID: 22748778.22748778
176 Cheung EY, Bow CH, Cheung CL, . Discriminative value of FRAX for fracture prediction in a cohort of Chinese postmenopausal women. Osteoporos Int. 2012 Mar;23(3):871-8. doi: 10.1007/s00198-011-1647-5 [doi]. PMID: 21562875.21562875
177 Tamaki J, Iki M, Kadowaki E, . Fracture risk prediction using FRAX(R): a 10-year follow-up survey of the Japanese Population-Based Osteoporosis (JPOS) Cohort Study. Osteoporos Int. 2011 Dec;22(12):3037-45. doi: 10.1007/s00198-011-1537-x [doi]. PMID: 21279504.21279504
178 Ensrud KE, Lui LY, Taylor BC, . A comparison of prediction models for fractures in older women: is more better? Arch Intern Med. 2009 Dec 14;169(22):2087-94. doi: 10.1001/archinternmed.2009.404. PMID: 20008691.20008691
179 Lundin H, Torabi F, Saaf M, . Laser-supported dual energy x-ray absorptiometry (DXL) compared to conventional absorptiometry (DXA) and to FRAX as tools for fracture risk assessments. PLoS One. 2015;10(9):e0137535. doi: 10.1371/journal.pone.0137535. PMID: 26413715.26413715
180 Miller PD, Siris ES, Barrett-Connor E, . Prediction of fracture risk in postmenopausal white women with peripheral bone densitometry: evidence from the National Osteoporosis Risk Assessment. J Bone Miner Res. 2002 Dec;17(12):2222-30. doi: 10.1359/jbmr.2002.17.12.2222 [doi]. PMID: 12469916.12469916
181 Azagra R, Roca G, Encabo G, . Prediction of absolute risk of fragility fracture at 10 years in a Spanish population: validation of the WHO FRAX tool in Spain. BMC Musculoskelet Disord. 2011;12:30. doi: 10.1186/1471-2474-12-30. PMID: 21272372.21272372
182 Azagra R, Roca G, Martin-Sanchez JC, . [FRAX(R) thresholds to identify people with high or low risk of osteoporotic fracture in Spanish female population]. Med Clin (Barc). 2015 Jan 6;144(1):1-8. doi: 10.1016/j.medcli.2013.11.014. PMID: 24461732.24461732
183 Leslie WD, Brennan SL, Lix LM, . Direct comparison of eight national FRAX(registered trademark) tools for fracture prediction and treatment qualification in Canadian women. Arch Osteoporos. 2013;8(1-2).
184 Gonzalez-Macias J, Marin F, Vila J, . Probability of fractures predicted by FRAX(R) and observed incidence in the Spanish ECOSAP Study cohort. Bone. 2012 Jan;50(1):373-7. doi: 10.1016/j.bone.2011.11.006. PMID: 22129640.22129640
185 Premaor M, Parker RA, Cummings S, . Predictive value of FRAX for fracture in obese older women. J Bone Miner Res. 2013 Jan;28(1):188-95. doi: 10.1002/jbmr.1729 [doi]. PMID: 22890977.22890977
186 Borens O, Kloen P, Richmond J, . Complex open trauma of the shoulder: a case report. Am J Orthop (Belle Mead NJ). 2004 Mar;33(3):149-52. PMID: 15074463.15074463
187 Pressman AR, Lo JC, Chandra M, . Methods for assessing fracture risk prediction models: experience with FRAX in a large integrated health care delivery system. J Clin Densitom. 2011 Oct-Dec;14(4):407-15. doi: 10.1016/j.jocd.2011.06.006. PMID: 21958955.21958955
188 Chen CK, Chang HT, Chou HP, . Alendronate and risk of lower limb ischemic vascular events: a population-based cohort study. Osteoporos Int. 2014 Feb;25(2):673-80. doi: 10.1007/s00198-013-2478-3 [doi]. PMID: 23943167.23943167
189 Leslie WD, Lix LM, Johansson H, . Spine-hip discordance and fracture risk assessment: a physician-friendly FRAX enhancement. Osteoporos Int. 2011 Mar;22(3):839-47. doi: 10.1007/s00198-010-1461-5 [doi]. PMID: 20959961.20959961
190 Leslie WD, Lix LM. Absolute fracture risk assessment using lumbar spine and femoral neck bone density measurements: derivation and validation of a hybrid system. J Bone Miner Res. 2011 Mar;26(3):460-7. doi: 10.1002/jbmr.248 [doi]. PMID: 20839285.20839285
191 Ettinger B, Liu H, Blackwell T, . Validation of FRC, a fracture risk assessment tool, in a cohort of older men: the Osteoporotic Fractures in Men (MrOS) Study. J Clin Densitom. 2012 Jul-Sep;15(3):334-42. doi: 10.1016/j.jocd.2012.01.011. PMID: 22445858.22445858
192 Chan MY, Nguyen ND, Center JR, . Quantitative ultrasound and fracture risk prediction in non-osteoporotic men and women as defined by WHO criteria. Osteoporos Int. 2013 Mar;24(3):1015-22. doi: 10.1007/s00198-012-2001-2 [doi]. PMID: 22878531.22878531
193 Leening MJ, Vedder MM, Witteman JC, . Net reclassification improvement: computation, interpretation, and controversies: a literature review and clinician’s guide. Ann Intern Med. 2014 Jan 21;160(2):122-31. doi: 10.7326/M13-1522. PMID: 24592497.24592497
194 Hillier TA, Stone KL, Bauer DC, . Evaluating the value of repeat bone mineral density measurement and prediction of fractures in older women: the study of osteoporotic fractures. Arch Intern Med. 2007 Jan 22;167(2):155-60. doi: 10.1001/archinte.167.2.155. PMID: 17242316.17242316
195 Berry SD, Samelson EJ, Pencina MJ, . Repeat bone mineral density screening and prediction of hip and major osteoporotic fracture. JAMA. 2013 Sep 25;310(12):1256-62. doi: 10.1001/jama.2013.277817. PMID: 24065012.24065012
196 Gourlay ML, Fine JP, Preisser JS, . Bone-density testing interval and transition to osteoporosis in older women. N Engl J Med. 2012 Jan 19;366(3):225-33. doi: 10.1056/NEJMoa1107142 [doi]. PMID: 22256806.22256806
197 Frost SA, Nguyen ND, Center JR, . Timing of repeat BMD measurements: development of an absolute risk-based prognostic model. J Bone Miner Res. 2009 Nov;24(11):1800-7. doi: 10.1359/jbmr.090514. PMID: 19419321.19419321
198 Gourlay ML, Overman RA, Fine JP, . Baseline age and time to major fracture in younger postmenopausal women. Menopause. 2015 Jun;22(6):589-97. doi: 10.1097/GME.0000000000000356 [doi]. PMID: 25349960.25349960
199 Liberman UA, Weiss SR, Broll J, . Effect of oral alendronate on bone mineral density and the incidence of fractures in postmenopausal osteoporosis. The Alendronate Phase III Osteoporosis Treatment Study Group. N Engl J Med. 1995 Nov 30;333(22):1437-43. doi: 10.1056/nejm199511303332201. PMID: 7477143.7477143
200 Cummings SR, Black DM, Thompson DE, . Effect of alendronate on risk of fracture in women with low bone density but without vertebral fractures: results from the Fracture Intervention Trial. JAMA. 1998 Dec 23-30;280(24):2077-82. PMID: 9875874.9875874
201 Pols HA, Felsenberg D, Hanley DA, . Multinational, placebo-controlled, randomized trial of the effects of alendronate on bone density and fracture risk in postmenopausal women with low bone mass: results of the FOSIT study. Fosamax International Trial Study Group. Osteoporos Int. 1999;9(5):461-8. PMID: 10550467.10550467
202 Hosking D, Adami S, Felsenberg D, . Comparison of change in bone resorption and bone mineral density with once-weekly alendronate and daily risedronate: a randomised, placebo-controlled study. Curr Med Res Opin. 2003;19(5):383-94. doi: 10.1185/030079903125002009. PMID: 13678475.13678475
203 Chesnut CH 3rd, McClung MR, Ensrud KE, . Alendronate treatment of the postmenopausal osteoporotic woman: effect of multiple dosages on bone mass and bone remodeling. Am J Med. 1995 Aug;99(2):144-52. PMID: 7625419.7625419
204 Ascott-Evans BH, Guanabens N, Kivinen S, . Alendronate prevents loss of bone density associated with discontinuation of hormone replacement therapy: a randomized controlled trial. Arch Intern Med. 2003 Apr 14;163(7):789-94. doi: 10.1001/archinte.163.7.789. PMID: 12695269.12695269
205 Quandt SA, Thompson DE, Schneider DL, . Effect of alendronate on vertebral fracture risk in women with bone mineral density T scores of-1.6 to -2.5 at the femoral neck: the Fracture Intervention Trial. Mayo Clin Proc. 2005 Mar;80(3):343-9. PMID: 15757015.15757015
206 Black DM, Cummings SR, Karpf DB, . Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Fracture Intervention Trial Research Group. Lancet. 1996 Dec 7;348(9041):1535-41. PMID: 8950879.8950879
207 Dursun N, Dursun E, Yalcin S. Comparison of alendronate, calcitonin and calcium treatments in postmenopausal osteoporosis. Int J Clin Pract. 2001 Oct;55(8):505-9. PMID: 11695068.11695068
208 Cummings SR. Prevention of hip fractures in older women: a population-based perspective. Osteoporos Int. 1998;8 Suppl 1:S8-12. PMID: 9682790.9682790
209 McClung MR, Lewiecki EM, Cohen SB, . Denosumab in postmenopausal women with low bone mineral density. N Engl J Med. 2006 Feb 23;354(8):821-31. doi: 10.1056/NEJMoa044459. PMID: 16495394.16495394
210 Zein CO, Jorgensen RA, Clarke B, . Alendronate improves bone mineral density in primary biliary cirrhosis: a randomized placebo-controlled trial. Hepatology. 2005 Oct;42(4):762-71. doi: 10.1002/hep.20866. PMID: 16175618.16175618
211 de Nijs RN, Jacobs JW, Lems WF, . Alendronate or alfacalcidol in glucocorticoid-induced osteoporosis. N Engl J Med. 2006 Aug 17;355(7):675-84. doi: 10.1056/NEJMoa053569. PMID: 16914703.16914703
212 Ringe JD, Farahmand P, Schacht E, . Superiority of a combined treatment of Alendronate and Alfacalcidol compared to the combination of Alendronate and plain vitamin D or Alfacalcidol alone in established postmenopausal or male osteoporosis (AAC-Trial). Rheumatol Int. 2007 Mar;27(5):425-34. doi: 10.1007/s00296-006-0288-z. PMID: 17216477.17216477
213 Sato Y, Iwamoto J, Kanoko T, . Alendronate and vitamin D2 for prevention of hip fracture in Parkinson’s disease: a randomized controlled trial. Mov Disord. 2006 Jul;21(7):924-9. doi: 10.1002/mds.20825. PMID: 16538619.16538619
214 Papaioannou A, Kennedy CC, Freitag A, . Alendronate once weekly for the prevention and treatment of bone loss in Canadian adult cystic fibrosis patients (CFOS trial). Chest. 2008 Oct;134(4):794-800. doi: 10.1378/chest.08-0608. PMID: 18641106.18641106
215 Hosking D, Chilvers CE, Christiansen C, . Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. Early Postmenopausal Intervention Cohort Study Group. N Engl J Med. 1998 Feb 19;338(8):485-92. doi: 10.1056/nejm199802193380801. PMID: 9443925.9443925
216 Bone HG, Greenspan SL, McKeever C, . Alendronate and estrogen effects in postmenopausal women with low bone mineral density. Alendronate/Estrogen Study Group. J Clin Endocrinol Metab. 2000 Feb;85(2):720-6. doi: 10.1210/jcem.85.2.6393. PMID: 10690882.10690882
217 Reid IR, Brown JP, Burckhardt P, . Intravenous zoledronic acid in postmenopausal women with low bone mineral density. N Engl J Med. 2002 Feb 28;346(9):653-61. doi: 10.1056/NEJMoa011807. PMID: 11870242.11870242
218 Boonen S, Reginster JY, Kaufman JM, . Fracture risk and zoledronic acid therapy in men with osteoporosis. N Engl J Med. 2012 Nov;367(18):1714-23. doi: 10.1056/NEJMoa1204061. PMID: 23113482.23113482
219 Black DM, Delmas PD, Eastell R, . Once-yearly zoledronic acid for treatment of postmenopausal osteoporosis. N Engl J Med. 2007 May 3;356(18):1809-22. doi: 10.1056/NEJMoa067312. PMID: 17476007.17476007
220 Lyles KW, Colon-Emeric CS, Magaziner JS, . Zoledronic acid and clinical fractures and mortality after hip fracture. N Engl J Med. 2007 Nov 1;357(18):1799-809. doi: 10.1056/NEJMoa074941. PMID: 17878149.17878149
221 Crandall CJ, Newberry SJ, Diamant A, . Treatment To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis: Update of a 2007 Report Comparative Effectiveness Review No. 53. (Prepared by Southern California Evidence-based Practice Center under Contract No. HHSA-290-2007-10062-I.). AHRQ Publication No. 12-EHC023-EF. Rockville, MD: Agency for Healthcare Research and Quality; March 2012.
222 Chapman I, Greville H, Ebeling PR, . Intravenous zoledronate improves bone density in adults with cystic fibrosis (CF). Clin Endocrinol (Oxf). 2009 Jun;70(6):838-46. doi: 10.1111/j.1365-2265.2008.03434.x. PMID: 18823395.18823395
223 McClung MR, Geusens P, Miller PD, . Effect of risedronate on the risk of hip fracture in elderly women. Hip Intervention Program Study Group. N Engl J Med. 2001 Feb 1;344(5):333-40. doi: 10.1056/nejm200102013440503. PMID: 11172164.11172164
224 Mortensen L, Charles P, Bekker PJ, . Risedronate increases bone mass in an early postmenopausal population: two years of treatment plus one year of follow-up. J Clin Endocrinol Metab. 1998 Feb;83(2):396-402. doi: 10.1210/jcem.83.2.4586. PMID: 9467547.9467547
225 Valimaki MJ, Farrerons-Minguella J, Halse J, . Effects of risedronate 5 mg/d on bone mineral density and bone turnover markers in late-postmenopausal women with osteopenia: a multinational, 24-month, randomized, double-blind, placebo-controlled, parallel-group, phase III trial. Clin Ther. 2007 Sep;29(9):1937-49. doi: 10.1016/j.clinthera.2007.09.017. PMID: 18035193.18035193
226 Fogelman I, Ribot C, Smith R, . Risedronate reverses bone loss in postmenopausal women with low bone mass: results from a multinational, double-blind, placebo-controlled trial. BMD-MN Study Group. J Clin Endocrinol Metab. 2000 May;85(5):1895-900. doi: 10.1210/jcem.85.5.6603. PMID: 10843171.10843171
227 Hooper MJ, Ebeling PR, Roberts AP, . Risedronate prevents bone loss in early postmenopausal women: a prospective randomized, placebo-controlled trial. Climacteric. 2005 Sep;8(3):251-62. doi: 10.1080/13697130500118126. PMID: 16390757.16390757
228 Herd RJ, Balena R, Blake GM, . The prevention of early postmenopausal bone loss by cyclical etidronate therapy: a 2-year, double-blind, placebo-controlled study. Am J Med. 1997 Aug;103(2):92-9. PMID: 9274891.9274891
229 Meunier PJ, Confavreux E, Tupinon I, . Prevention of early postmenopausal bone loss with cyclical etidronate therapy (a double-blind, placebo-controlled study and 1-year follow-up). J Clin Endocrinol Metab. 1997 Sep;82(9):2784-91. doi: 10.1210/jcem.82.9.4073. PMID: 9284696.9284696
230 Pouilles JM, Tremollieres F, Roux C, . Effects of cyclical etidronate therapy on bone loss in early postmenopausal women who are not undergoing hormonal replacement therapy. Osteoporos Int. 1997;7(3):213-8. PMID: 9205633.9205633
231 Ettinger B, Black DM, Mitlak BH, . Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. Multiple Outcomes of Raloxifene Evaluation (MORE) Investigators. JAMA. 1999 Aug 18;282(7):637-45. PMID: 10517716.10517716
232 Delmas PD, Ensrud KE, Adachi JD, . Efficacy of raloxifene on vertebral fracture risk reduction in postmenopausal women with osteoporosis: four-year results from a randomized clinical trial. J Clin Endocrinol Metab. 2002 Aug;87(8):3609-17. doi: 10.1210/jcem.87.8.8750. PMID: 12161484.12161484
233 Barrett-Connor E, Mosca L, Collins P, . Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med. 2006 Jul 13;355(2):125-37. doi: 10.1056/NEJMoa062462. PMID: 16837676.16837676
234 Ensrud KE, Stock JL, Barrett-Connor E, . Effects of raloxifene on fracture risk in postmenopausal women: the Raloxifene Use for the Heart Trial. J Bone Miner Res. 2008 Jan;23(1):112-20. doi: 10.1359/jbmr.070904. PMID: 17892376.17892376
235 Gartlehner G, Patel S, Viswanathan M, . Hormone Therapy for the Primary Prevention of Chronic Conditions in Postmenopausal Women: An Evidence Review for the U.S. Preventive Services Task Force [Internet] (Prepared by the RTI International— University of North Carolina Evidence-based Practice Center under Contract No. HHSA-290-2012-00015-I.) U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews, Evidence Synthesis, No. 155. Report No.: 15-05227-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; December 2017. PMID: 2958988029589880. http://www.ahrq.gov/clinic/epcix.htm
236 Lewiecki EM, Miller PD, McClung MR, . Two-year treatment with denosumab (AMG 162) in a randomized phase 2 study of postmenopausal women with low BMD. J Bone Miner Res. 2007 Dec;22(12):1832-41. doi: 10.1359/jbmr.070809 [doi]. PMID: 17708711.17708711
237 Bone HG, Bolognese MA, Yuen CK, . Effects of denosumab on bone mineral density and bone turnover in postmenopausal women. J Clin Endocrinol Metab. 2008 Jun;93(6):2149-57. doi: 10.1210/jc.2007-2814. PMID: 18381571.18381571
238 Cummings SR, San Martin J, McClung MR, . Denosumab for prevention of fractures in postmenopausal women with osteoporosis. N Engl J Med. 2009 Aug 20;361(8):756-65. doi: 10.1056/NEJMoa0809493. PMID: 19671655.19671655
239 Nakamura T, Matsumoto T, Sugimoto T, . Dose-response study of denosumab on bone mineral density and bone turnover markers in Japanese postmenopausal women with osteoporosis. Osteoporos Int; 2012. p. 1131-40.
240 Orwoll ES, Scheele WH, Paul S, . The effect of teriparatide [human parathyroid hormone (1-34)] therapy on bone density in men with osteoporosis. J Bone Miner Res. 2003 Jan;18(1):9-17. doi: 10.1359/jbmr.2003.18.1.9. PMID: 12510800.12510800
241 Lasco A, Catalano A, Morabito N, . Adrenal effects of teriparatide in the treatment of severe postmenopausal osteoporosis. Osteoporos Int. 2011 Jan;22(1):299-303. doi: 10.1007/s00198-010-1222-5 [doi]. PMID: 20309523.20309523
242 Sontag A, Wan X, Krege JH. Benefits and risks of raloxifene by vertebral fracture status. Curr Med Res Opin. 2010 Jan;26(1):71-6. doi: 10.1185/03007990903427082 [doi]. PMID: 19908937.19908937
243 McClung MR, Boonen S, Torring O, . Effect of denosumab treatment on the risk of fractures in subgroups of women with postmenopausal osteoporosis. J Bone Miner Res. 2012 Jan;27(1):211-8. doi: 10.1002/jbmr.536 [doi]. PMID: 21976367.21976367
244 Boonen S, Adachi JD, Man Z, . Treatment with denosumab reduces the incidence of new vertebral and hip fractures in postmenopausal women at high risk. J Clin Endocrinol Metab. 2011 Jun;96(6):1727-36. doi: 10.1210/jc.2010-2784. PMID: 21411557.21411557
245 McCloskey EV, Johansson H, Oden A, . Denosumab reduces the risk of osteoporotic fractures in postmenopausal women, particularly in those with moderate to high fracture risk as assessed with FRAX. J Bone Miner Res. 2012 Jul;27(7):1480-6. doi: 10.1002/jbmr.1606 [doi]. PMID: 22431426.22431426
246 Johnell O, Scheele WH, Lu Y, . Additive effects of raloxifene and alendronate on bone density and biochemical markers of bone remodeling in postmenopausal women with osteoporosis. J Clin Endocrinol Metab. 2002 Mar;87(3):985-92. doi: 10.1210/jcem.87.3.8325. PMID: 11889149.11889149
247 Sorensen HT, Christensen S, Mehnert F, . Use of bisphosphonates among women and risk of atrial fibrillation and flutter: population based case-control study. BMJ. 2008 Apr 12;336(7648):813-6. doi: 10.1136/bmj.39507.551644.BE. PMID: 18334527.18334527
248 Cummings SR, Schwartz AV, Black DM. Alendronate and atrial fibrillation. N Engl J Med. 2007 May 3;356(18):1895-6. doi: 10.1056/NEJMc076132. PMID: 17476024.17476024
249 Greenspan SL, Resnick NM, Parker RA. Combination therapy with hormone replacement and alendronate for prevention of bone loss in elderly women: a randomized controlled trial. JAMA. 2003 May 21;289(19):2525-33. doi: 10.1001/jama.289.19.2525. PMID: 12759324.12759324
250 Adachi JD, Faraawi RY, O’Mahony MF, . Upper gastrointestinal tolerability of alendronate sodium monohydrate 10 mg once daily in postmenopausal women: a 12-week, randomized, double-blind, placebo-controlled, exploratory study. Clin Ther. 2009 Aug;31(8):1747-53. doi: 10.1016/j.clinthera.2009.08.016. PMID: 19808133.19808133
251 Bauer DC, Black D, Ensrud K, . Upper gastrointestinal tract safety profile of alendronate: the fracture intervention trial. Arch Intern Med. 2000 Feb 28;160(4):517-25. PMID: 10695692.10695692
252 Cryer B, Binkley N, Simonelli C, . A randomized, placebo-controlled, 6-month study of once-weekly alendronate oral solution for postmenopausal osteoporosis. Am J Geriatr Pharmacother. 2005 Sep;3(3):127-36. PMID: 16257815.16257815
253 Tucci JR, Tonino RP, Emkey RD, . Effect of three years of oral alendronate treatment in postmenopausal women with osteoporosis. Am J Med. 1996 Nov;101(5):488-501. PMID: 8948272.8948272
254 Greenspan S, Field-Munves E, Tonino R, . Tolerability of once-weekly alendronate in patients with osteoporosis: a randomized, double-blind, placebo-controlled study. Mayo Clin Proc. 2002 Oct;77(10):1044-52. doi: 10.4065/77.10.1044. PMID: 12374248.12374248
255 Eisman JA, Rizzoli R, Roman-Ivorra J, . Upper gastrointestinal and overall tolerability of alendronate once weekly in patients with osteoporosis: results of a randomized, double-blind, placebo-controlled study. Curr Med Res Opin. 2004 May;20(5):699-705. doi: 10.1185/030079904125003548. PMID: 15140336.15140336
256 Heckbert SR, Li G, Cummings SR, . Use of alendronate and risk of incident atrial fibrillation in women. Arch Intern Med. 2008 Apr 28;168(8):826-31. doi: 10.1001/archinte.168.8.826. PMID: 18443257.18443257
257 Office of Drug Safety. ODS Postmarketing Safety Review. Rockville, MD: U.S. Food and Drug Administration; 2004. www.fda.gov/ohrms/dockets/ac/05/briefing/2005-4095B2_03_04-FDA-TAB3.pdf. Accessed September 13, 2016.
258 Palomba S, Orio F Jr, Colao A, . Effect of estrogen replacement plus low-dose alendronate treatment on bone density in surgically postmenopausal women with osteoporosis. J Clin Endocrinol Metab. 2002 Apr;87(4):1502-8. doi: 10.1210/jcem.87.4.8323. PMID: 11932272.11932272
259 Chow CC, Chan WB, Li JK, . Oral alendronate increases bone mineral density in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab. 2003 Feb;88(2):581-7. doi: 10.1210/jc.2002-020890. PMID: 12574184.12574184
260 Saag KG, Emkey R, Schnitzer TJ, . Alendronate for the prevention and treatment of glucocorticoid-induced osteoporosis. Glucocorticoid-Induced Osteoporosis Intervention Study Group. N Engl J Med. 1998 Jul 30;339(5):292-9. doi: 10.1056/nejm199807303390502. PMID: 9682041.9682041
261 Adachi JD, Saag KG, Delmas PD, . Two-year effects of alendronate on bone mineral density and vertebral fracture in patients receiving glucocorticoids: a randomized, double-blind, placebo-controlled extension trial. Arthritis Rheum. 2001 Jan;44(1):202-11. doi: 10.1002/1529-0131(200101)44:1<202::aid-anr27>3.0.co;2-w. PMID: 11212161.11212161
262 Sambrook PN, Rodriguez JP, Wasnich RD, . Alendronate in the prevention of osteoporosis: 7-year follow-up. Osteoporos Int. 2004 Jun;15(6):483-8. doi: 10.1007/s00198-003-1571-4. PMID: 15205720.15205720
263 Lenart BA, Lorich DG, Lane JM. Atypical fractures of the femoral diaphysis in postmenopausal women taking alendronate. N Engl J Med. 2008 Mar 20;358(12):1304-6. doi: 10.1056/NEJMc0707493. PMID: 18354114.18354114
264 Odvina CV, Zerwekh JE, Rao DS, . Severely suppressed bone turnover: a potential complication of alendronate therapy. J Clin Endocrinol Metab. 2005 Mar;90(3):1294-301. doi: 10.1210/jc.2004-0952. PMID: 15598694.15598694
265 Ensrud KE, Barrett-Connor EL, Schwartz A, . Randomized trial of effect of alendronate continuation versus discontinuation in women with low BMD: results from the Fracture Intervention Trial long-term extension. J Bone Miner Res. 2004 Aug;19(8):1259-69. doi: 10.1359/jbmr.040326. PMID: 15231012.15231012
266 Uusi-Rasi K, Kannus P, Cheng S, . Effect of alendronate and exercise on bone and physical performance of postmenopausal women: a randomized controlled trial. Bone. 2003 Jul;33(1):132-43. PMID: 12919708.12919708
267 Chailurkit LO, Jongjaroenprasert W, Rungbunnapun S, . Effect of alendronate on bone mineral density and bone turnover in Thai postmenopausal osteoporosis. J Bone Miner Metab. 2003;21(6):421-7. doi: 10.1007/s00774-003-0438-2. PMID: 14586800.14586800
268 Barrett-Connor E, Swern AS, Hustad CM, . Alendronate and atrial fibrillation: a meta-analysis of randomized placebo-controlled clinical trials. Osteoporos Int. 2012 Jan;23(1):233-45. doi: 10.1007/s00198-011-1546-9. PMID: 21369791.21369791
269 Goh SK, Yang KY, Koh JS, . Subtrochanteric insufficiency fractures in patients on alendronate therapy: a caution. J Bone Joint Surg Br. 2007 Mar;89(3):349-53. doi: 10.1302/0301-620x.89b3.18146. PMID: 17356148.17356148
270 MacLean C, Newberry S, Maglione M, . Systematic review: comparative effectiveness of treatments to prevent fractures in men and women with low bone densityor osteoporosis. Ann Intern Med. 2008 Feb 5;148(3):197-213. PMID: 18087050.18087050
271 Rossini M, Gatti D, Girardello S, . Effects of two intermittent alendronate regimens in the prevention or treatment of postmenopausal osteoporosis. Bone. 2000 Jul;27(1):119-22. PMID: 10865218.10865218
272 Murphy MG, Weiss S, McClung M, . Effect of alendronate and MK-677 (a growth hormone secretagogue), individually and in combination, on markers of bone turnover and bone mineral density in postmenopausal osteoporotic women. J Clin Endocrinol Metab. 2001 Mar;86(3):1116-25. doi: 10.1210/jcem.86.3.7294. PMID: 11238495.11238495
273 Abrahamsen B, Eiken P, Eastell R. Cumulative alendronate dose and the long-term absolute risk of subtrochanteric and diaphyseal femur fractures: a register-based national cohort analysis. J Clin Endocrinol Metab. 2010 Dec;95(12):5258-65. doi: 10.1210/jc.2010-1571. PMID: 20843943.20843943
274 Grey A, Bolland M, Wattie D, . Prolonged antiresorptive activity of zoledronate: a randomized, controlled trial. J Bone Miner Res. 2010 Oct;25(10):2251-5. doi: 10.1002/jbmr.103. PMID: 20499349.20499349
275 McClung M, Miller P, Recknor C, . Zoledronic acid for the prevention of bone loss in postmenopausal women with low bone mass: a randomized controlled trial. Obstet Gynecol. 2009 Nov;114(5):999-1007. doi: 10.1097/AOG.0b013e3181bdce0a. PMID: 20168099.20168099
276 Hwang JS, Chin LS, Chen JF, . The effects of intravenous zoledronic acid in Chinese women with postmenopausal osteoporosis. J Bone Miner Metab. 2011 May;29(3):328-33. doi: 10.1007/s00774-010-0223-y. PMID: 20922438.20922438
277 Black DM, Kelly MP, Genant HK, . Bisphosphonates and fractures of the subtrochanteric or diaphyseal femur. N Engl J Med. 2010 May 13;362(19):1761-71. doi: 10.1056/NEJMoa1001086. PMID: 20335571.20335571
278 Grbic JT, Black DM, Lyles KW, . The incidence of osteonecrosis of the jaw in patients receiving 5 milligrams of zoledronic acid: data from the health outcomes and reduced incidence with zoledronic acid once yearly clinical trials program. J Am Dent Assoc. 2010 Nov;141(11):1365-70. PMID: 21037195.21037195
279 Colon-Emeric C, Nordsletten L, Olson S, . Association between timing of zoledronic acid infusion and hip fracture healing. Osteoporos Int. 2011 Aug;22(8):2329-36. doi: 10.1007/s00198-010-1473-1. PMID: 21153021.21153021
280 Crawford BA, Kam C, Pavlovic J, . Zoledronic acid prevents bone loss after liver transplantation: a randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2006 Feb 21;144(4):239-48. PMID: 16490909.16490909
281 Grbic JT, Landesberg R, Lin SQ, . Incidence of osteonecrosis of the jaw in women with postmenopausal osteoporosis in the health outcomes and reduced incidence with zoledronic acid once yearly pivotal fracture trial. J Am Dent Assoc. 2008 Jan;139(1):32-40. PMID: 18167382.18167382
282 Khan AA, Sandor GK, Dore E, . Bisphosphonate associated osteonecrosis of the jaw. J Rheumatol. 2009 Mar;36(3):478-90. doi: 10.3899/jrheum.080759. PMID: 19286860.19286860
283 Shiraki M, Fukunaga M, Kushida K, . A double-blind dose-ranging study of risedronate in Japanese patients with osteoporosis (a study by the Risedronate Late Phase II Research Group). Osteoporos Int. 2003 May;14(3):225-34. doi: 10.1007/s00198-002-1369-9. PMID: 12730746.12730746
284 Chapurlat RD, Laroche M, Thomas T, . Effect of oral monthly ibandronate on bone microarchitecture in women with osteopenia-a randomized placebo-controlled trial. Osteoporos Int. 2013 Jan;24(1):311-20. doi: 10.1007/s00198-012-1947-4 [doi]. PMID: 22402673.22402673
285 McClung MR, Wasnich RD, Recker R, . Oral daily ibandronate prevents bone loss in early postmenopausal women without osteoporosis. J Bone Miner Res. 2004 Jan;19(1):11-8. doi: 10.1359/jbmr.0301202. PMID: 14753731.14753731
286 Ravn P, Clemmesen B, Riis BJ, . The effect on bone mass and bone markers of different doses of ibandronate: a new bisphosphonate for prevention and treatment of postmenopausal osteoporosis: a 1-year, randomized, double-blind, placebo-controlled dose-finding study. Bone. 1996 Nov;19(5):527-33. PMID: 8922653.8922653
287 Reginster JY, Wilson KM, Dumont E, . Monthly oral ibandronate is well tolerated and efficacious in postmenopausal women: results from the monthly oral pilot study. J Clin Endocrinol Metab. 2005 Sep;90(9):5018-24. doi: 10.1210/jc.2004-1750. PMID: 15972582.15972582
288 Riis BJ, Ise J, von Stein T, . Ibandronate: a comparison of oral daily dosing versus intermittent dosing in postmenopausal osteoporosis. J Bone Miner Res. 2001 Oct;16(10):1871-8. doi: 10.1359/jbmr.2001.16.10.1871. PMID: 11585352.11585352
289 Tanko LB, Felsenberg D, Czerwinski E, . Oral weekly ibandronate prevents bone loss in postmenopausal women. J Intern Med. 2003 Aug;254(2):159-67. PMID: 12859697.12859697
290 Thiebaud D, Burckhardt P, Kriegbaum H, . Three monthly intravenous injections of ibandronate in the treatment of postmenopausal osteoporosis. Am J Med. 1997 Oct;103(4):298-307. PMID: 9382122.9382122
291 Sharma A, Einstein AJ, Vallakati A, . Risk of atrial fibrillation with use of oral and intravenous bisphosphonates. Am J Cardiol. 2014 Jun 1;113(11):1815-21. doi: 10.1016/j.amjcard.2014.03.008. PMID: 24837258.24837258
292 Sharma A, Chatterjee S, Arbab-Zadeh A, . Risk of serious atrial fibrillation and stroke with use of bisphosphonates: evidence from a meta-analysis. Chest. 2013 Oct;144(4):1311-22. doi: 10.1378/chest.13-0675. PMID: 23722644.23722644
293 Karam R, Camm J, McClung M. Yearly zoledronic acid in postmenopausal osteoporosis. N Engl J Med. 2007 Aug 16;357(7):712-3; author reply 4-5. PMID: 17703529.17703529
294 Barasch A, Cunha-Cruz J, Curro FA, . Risk factors for osteonecrosis of the jaws: A case-control study from the CONDOR dental PBRN. J Dent Res. 2011;90(4):439-44.21317246
295 Pazianas M, Miller P, Blumentals WA, . A review of the literature on osteonecrosis of the jaw in patients with osteoporosis treated with oral bisphosphonates: prevalence, risk factors, and clinical characteristics. Clin Ther. 2007 Aug;29(8):1548-58. doi: 10.1016/j.clinthera.2007.08.008. PMID: 17919538.17919538
296 Lo JC, O’Ryan FS, Gordon NP, . Prevalence of osteonecrosis of the jaw in patients with oral bisphosphonate exposure. J Oral Maxillofac Surg. 2010 Feb;68(2):243-53. doi: 10.1016/j.joms.2009.03.050. PMID: 19772941.19772941
297 Cartsos VM, Zhu S, Zavras AI. Bisphosphonate use and the risk of adverse jaw outcomes: a medical claims study of 714,217 people. J Am Dent Assoc. 2008 Jan;139(1):23-30. PMID: 18167381.18167381
298 Pazianas M, Blumentals WA, Miller PD. Lack of association between oral bisphosphonates and osteonecrosis using jaw surgery as a surrogate marker. Osteoporos Int. 2008 Jun;19(6):773-9. doi: 10.1007/s00198-007-0547-1. PMID: 17999023.17999023
299 Khan AA, Morrison A, Hanley DA, . Diagnosis and management of osteonecrosis of the jaw: a systematic review and international consensus. J Bone Miner Res. 2015 Jan;30(1):3-23. doi: 10.1002/jbmr.2405. PMID: 25414052.25414052
300 Yarnall AJ, Duncan GW, Khoo TK, . Falling short: underestimation of fracture risk in atypical parkinsonian syndromes. Parkinsonism Relat Disord. 2012 Jun;18(5):692-3. doi: 10.1016/j.parkreldis.2012.01.004. PMID: 22265139.22265139
301 Chen F, Wang Z, Bhattacharyya T. Absence of femoral cortical thickening in long-term bisphosphonate users: implications for atypical femur fractures. Bone. 2014 May;62:64-6. doi: 10.1016/j.bone.2014.01.011. PMID: 24468718.24468718
302 Gedmintas L, Solomon DH, Kim SC. Bisphosphonates and risk of subtrochanteric, femoral shaft, and atypical femur fracture: a systematic review and meta-analysis. J Bone Miner Res. 2013 Aug;28(8):1729-37. doi: 10.1002/jbmr.1893. PMID: 23408697.23408697
303 Lee S, Yin RV, Hirpara H, . Increased risk for atypical fractures associated with bisphosphonate use. Fam Pract. 2015 Jun;32(3):276-81. doi: 10.1093/fampra/cmu088. PMID: 25846215.25846215
304 Miyakoshi N, Aizawa T, Sasaki S, . Healing of bisphosphonate-associated atypical femoral fractures in patients with osteoporosis: a comparison between treatment with and without teriparatide. J Bone Miner Metab. 2015 Sep;33(5):553-9. doi: 10.1007/s00774-014-0617-3 [doi]. PMID: 25227287.25227287
305 U.S. Food and Drug Administration. FDA Drug Safety Communication: New contraindication and updated warning on kidney impairment for Reclast (zoledronic acid). Silver Spring, MD U.S. Food and Drug Administration; 2011. https://www.fda.gov/Drugs/DrugSafety/ucm270199.htm. Accessed March 12, 2018.
306 McClung MR, Siris E, Cummings S, . Prevention of bone loss in postmenopausal women treated with lasofoxifene compared with raloxifene. Menopause. 2006 May-Jun;13(3):377-86. doi: 10.1097/01.gme.0000188736.69617.4f. PMID: 16735934.16735934
307 Meunier PJ, Vignot E, Garnero P, . Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene Study Group. Osteoporos Int. 1999;10(4):330-6. PMID: 10692984.10692984
308 Miller PD, Chines AA, Christiansen C, . Effects of bazedoxifene on BMD and bone turnover in postmenopausal women: 2-yr results of a randomized, double-blind, placebo-, and active-controlled study. J Bone Miner Res. 2008 Apr;23(4):525-35. doi: 10.1359/jbmr.071206. PMID: 18072873.18072873
309 Morii H, Ohashi Y, Taketani Y, . Effect of raloxifene on bone mineral density and biochemical markers of bone turnover in Japanese postmenopausal women with osteoporosis: results from a randomized placebo-controlled trial. Osteoporos Int. 2003 Oct;14(10):793-800. doi: 10.1007/s00198-003-1424-1. PMID: 12955333.12955333
310 Barrett-Connor E, Cauley JA, Kulkarni PM, . Risk-benefit profile for raloxifene: 4-year data From the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. J Bone Miner Res. 2004 Aug;19(8):1270-5. doi: 10.1359/JBMR.040406 [doi]. PMID: 15231013.15231013
311 Barrett-Connor E, Grady D, Sashegyi A, . Raloxifene and cardiovascular events in osteoporotic postmenopausal women: four-year results from the MORE (Multiple Outcomes of Raloxifene Evaluation) randomized trial. JAMA. 2002 Feb 20;287(7):847-57. . PMID: 11851576.11851576
312 Keech CA, Sashegyi A, Barrett-Connor E. Year-by-year analysis of cardiovascular events in the Multiple Outcomes of Raloxifene Evaluation (MORE) trial. Curr Med Res Opin. 2005 Jan;21(1):135-40. PMID: 15881485.15881485
313 Cauley JA, Norton L, Lippman ME, . Continued breast cancer risk reduction in postmenopausal women treated with raloxifene: 4-year results from the MORE trial. Multiple outcomes of raloxifene evaluation. Breast Cancer Res Treat. 2001 Jan;65(2):125-34. PMID: 11261828.11261828
314 Watts NB, Roux C, Modlin JF, . Infections in postmenopausal women with osteoporosis treated with denosumab or placebo: coincidence or causal association? Osteoporos Int. 2012 Jan;23(1):327-37. doi: 10.1007/s00198-011-1755-2 [doi]. PMID: 21892677.21892677
315 Compston J, Cooper A, Cooper C, . Guidelines for the diagnosis and management of osteoporosis in postmenopausal women and men from the age of 50 years in the UK. Maturitas. 2009 Feb 20;62(2):105-8. doi: 10.1016/j.maturitas.2008.11.022. PMID: 19135323.19135323
316 National Institute for Health and Care Excellence. Osteoporosis: assessing the risk of fragility fracture NICE Clinical Guideline 146. London: National Institute for Health and Care Excellence; August 2012.
317 Barr RJ, Stewart A, Torgerson DJ, . Population screening for osteoporosis risk: a randomised control trial of medication use and fracture risk. Osteoporos Int. 2010 Apr;21(4):561-8. doi: 10.1007/s00198-009-1007-x [doi]. PMID: 19565176.19565176
318 Gourlay ML, Overman RA, Ensrud KE. Bone Density Screening and Re-screening in Postmenopausal Women and Older Men. Curr Osteoporos Rep. 2015 Dec;13(6):390-8. doi: 10.1007/s11914-015-0289-5. PMID: 26408154.26408154
319 Nayak S, Roberts MS, Greenspan SL. Cost-effectiveness of different screening strategies for osteoporosis in postmenopausal women. Ann Intern Med. 2011 Dec 6;155(11):751-61. doi: 10.7326/0003-4819-155-11-201112060-00007. PMID: 22147714.22147714
320 Nayak S, Greenspan SL. Cost-effectiveness of osteoporosis screening strategies for men. J Bone Miner Res. 2016 Jun;31(6):1189-99. doi: 10.1002/jbmr.2784. PMID: 26751984.26751984
321 Ito K, Hollenberg JP, Charlson ME. Using the osteoporosis self-assessment tool for referring older men for bone densitometry: a decision analysis. J Am Geriatr Soc. 2009 Feb;57(2):218-24. doi: 10.1111/j.1532-5415.2008.02110.x. PMID: 19207137.19207137
322 Schott AM, Ganne C, Hans D, . Which screening strategy using BMD measurements would be most cost effective for hip fracture prevention in elderly women? A decision analysis based on a Markov model. Osteoporos Int. 2007 Feb;18(2):143-51. doi: 10.1007/s00198-006-0227-6. PMID: 17039393.17039393
323 Schousboe JT, Ensrud KE, Nyman JA, . Universal bone densitometry screening combined with alendronate therapy for those diagnosed with osteoporosis is highly cost-effective for elderly women. J Am Geriatr Soc. 2005 Oct;53(10):1697-704. doi: 10.1111/j.1532-5415.2005.53504.x. PMID: 16181168.16181168
324 Jarvinen TL, Sievanen H, Khan KM, . Shifting the focus in fracture prevention from osteoporosis to falls. BMJ. 2008 Jan 19;336(7636):124-6. doi: 10.1136/bmj.39428.470752.AD. PMID: 18202065.18202065
325 U.S. Preventive Services Task Force. Draft Recommendation Statement. Falls prevention in community-dwelling older adults: interventions. Rockville, MD: U.S. Preventive Services Task Force; October 23 2017. https://www.uspreventiveservicestaskforce.org/Page/Document/draft-recommendation-statement/falls-prevention-in-older-adults-interventions 1
326 Shepstone L, Fordham R, Lenaghan E, . A pragmatic randomised controlled trial of the effectiveness and cost-effectiveness of screening older women for the prevention of fractures: rationale, design and methods for the SCOOP study. Osteoporos Int. 2012 Oct;23(10):2507-15. doi: 10.1007/s00198-011-1876-7 [doi]. PMID: 22314936.22314936
327 Camacho PM, Petak SM, Binkley N, . American Association of Clinical Endocrinologists and American College of Endocrinology Clinical Practice Guidelines for the Diagnosis and Treatment of Postmenopausal Osteoporosis-2016 Executive Summary. Endocr Pract. 2016 Sep;22(9):1111-8. doi: 10.4158/Ep161435.Esgl. PMID: WOS:000384279900011. 27643923
328 American Association of Family Physicians. Clinical Preventive Service Recommendation. Osteoporisis. Leawood, KS: American Academy of Family Physicians; 2011. http://www.aafp.org/patient-care/clinical-recommendations/all/osteoporosis.html. Accessed April 14, 2015.
329 American College of Obstetricians and Gynecologists. Osteoporosis American College of Obstetricians and Gynecologists (ACOG). ACOG Practice Bulletin; No. 129. Washington, DC: Sep 17 2012.
330 Lim LS, Hoeksema LJ, Sherin K, . Screening for osteoporosis in the adult U.S. population: ACPM position statement on preventive practice. Am J Prev Med. 2009 Apr;36(4):366-75. doi: 10.1016/j.amepre.2009.01.013. PMID: 19285200.19285200
331 American College of Radiology. ACR Appropriateness Criteria. Osteoporosis and Bone Mineral Density. Washington, DC: American College of Radiology; 1998. https://acsearch.acr.org/docs/69358/Narrative/ Accessed 9 Aug, 2016.
332 Watts NB, Adler RA, Bilezikian JP, . Osteoporosis in men: an Endocrine Society clinical practice guideline. J Clin Endocrinol Metab. 2012 Jun;97(6):1802-22. doi: 10.1210/jc.2011-3045. PMID: 22675062.22675062
333 National Clinical Guideline Centre (UK). Osteoporosis: fragility fracture risk: osteoporosis: assessing the risk of fragility fracture. London: Royal College of Physicians (UK); 2012.
334 North American Menopause Society. Management of osteoporosis in postmenopausal women: 2010 position statement of The North American Menopause Society. Menopause. 2010 Jan-Feb;17(1):25-54; quiz 5-6.20061894
335 Papaioannou A, Morin S, Cheung AM, . 2010 clinical practice guidelines for the diagnosis and management of osteoporosis in Canada: summary. CMAJ. 2010 Nov 23;182(17):1864-73. doi: 10.1503/cmaj.100771. PMID: 20940232.20940232
336 United Kingdom National Screening Committee. Summary and consultation responses for screening for Osteoporosis in postmenopausal women. Public Health England; 2013. http://www.screening.nhs.uk/osteoporosis. Accessed 15 April 2015.
337 4BoneHealth. World Health Organization — WHO Criteria for Diagnosis of Osteoporosis. NBHA, A Member of National Bone Health Alliance. http://www.4bonehealth.org/education/world-health-organization-criteria-diagnosis-osteoporosis/. Accessed April 12, 2015.
338 Ettinger B, Ensrud KE, Blackwell T, . Performance of FRAX in a cohort of community-dwelling, ambulatory older men: the Osteoporotic Fractures in Men (MrOS) study. Osteoporos Int. 2013 Apr;24(4):1185-93. doi: 10.1007/s00198-012-2215-3 [doi]. PMID: 23179575.23179575
339 Donaldson MG, Palermo L, Schousboe JT, . FRAX and risk of vertebral fractures: the fracture intervention trial. J Bone Miner Res. 2009 Nov;24(11):1793-9. doi: 10.1359/jbmr.090511 [doi]. PMID: 19419318.19419318
340 Sambrook PN, Flahive J, Hooven FH, . Predicting fractures in an international cohort using risk factor algorithms without BMD. J Bone Miner Res. 2011 Nov;26(11):2770-7. doi: 10.1002/jbmr.503. PMID: 21887705.21887705
341 Collins GS, Mallett S, Altman DG. Predicting risk of osteoporotic and hip fracture in the United Kingdom: prospective independent and external validation of QFractureScores. BMJ. 2011;342:d3651. doi: 10.1136/bmj.d3651. PMID: 21697214.21697214
342 Melton LJ 3rd, Atkinson EJ, Khosla S, . Evaluation of a prediction model for long-term fracture risk. J Bone Miner Res. 2005 Apr;20(4):551-6. doi: 10.1359/JBMR.041206 [doi]. PMID: 15765172.15765172
343 Kung AW, Yeung SS, Chu LW. The efficacy and tolerability of alendronate in postmenopausal osteoporotic Chinese women: a randomized placebo-controlled study. Calcif Tissue Int. 2000 Oct;67(4):286-90. PMID: 11000341.11000341
344 Rhee CW, Lee J, Oh S, . Use of bisphosphonate and risk of atrial fibrillation in older women with osteoporosis. Osteoporos Int. 2012 Jan;23(1):247-54. doi: 10.1007/s00198-011-1608-z [doi]. PMID: 21431993.21431993
345 Samelson EJ, Miller PD, Christiansen C, . RANKL inhibition with denosumab does not influence 3-year progression of aortic calcification or incidence of adverse cardiovascular events in postmenopausal women with osteoporosis and high cardiovascular risk. J Bone Miner Res. 2014;29(2):450-7.23873632
346 Simon JA, Recknor C, Moffett AH Jr, . Impact of denosumab on the peripheral skeleton of postmenopausal women with osteoporosis: bone density, mass, and strength of the radius, and wrist fracture. Menopause. 2013 Feb;20(2):130-7. doi: 10.1097/gme.0b013e318267f909 [doi]. PMID: 23010883.23010883
347 van Staa T, Abenhaim L, Cooper C. Upper gastrointestinal adverse events and cyclical etidronate. Am J Med. 1997 Dec;103(6):462-7. PMID: 9428828.9428828
348 Vestergaard P, Schwartz K, Pinholt EM, . Gastric and esophagus events before and during treatment of osteoporosis. Calcif Tissue Int. 2010 Feb;86(2):110-5. doi: 10.1007/s00223-009-9323-x [doi]. PMID: 19957165.19957165
349 Vestergaard P, Schwartz K, Pinholt EM, . Stroke in relation to use of raloxifene and other drugs against osteoporosis. Osteoporos Int. 2011 Apr;22(4):1037-45. doi: 10.1007/s00198-010-1276-4 [doi]. PMID: 20449570.20449570
350 Vestergaard P. Acute myocardial infarction and atherosclerosis of the coronary arteries in patients treated with drugs against osteoporosis: calcium in the vessels and not the bones? Calcif Tissue Int. 2012 Jan;90(1):22-9. doi: 10.1007/s00223-011-9549-2 [doi]. PMID: 22120197.22120197
351 Vestergaard P, Schwartz F, Rejnmark L, . Risk of femoral shaft and subtrochanteric fractures among users of bisphosphonates and raloxifene. Osteoporos Int. 2011 Mar;22(3):993-1001. doi: 10.1007/s00198-010-1512-y [doi]. PMID: 21165600.21165600
352 Vestergaard P, Schwartz K, Rejnmark L, . Oral bisphosphonate use increases the risk for inflammatory jaw disease: a cohort study. J Oral Maxillofac Surg. 2012 Apr;70(4):821-9. doi: 10.1016/j.joms.2011.02.093. PMID: 21764202.21764202
353 Alexandersen P, de Terlizzi F, Tanko LB, . Comparison of quantitative ultrasound of the phalanges with conventional bone densitometry in healthy postmenopausal women. Osteoporos Int. 2005 Sep;16(9):1071-8. doi: 10.1007/s00198-004-1810-3. PMID: 15719153.15719153
354 Anderson GL, Judd HL, Kaunitz AM, . Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women’s Health Initiative randomized trial. JAMA. 2003 Oct 1;290(13):1739-48. doi: 10.1001/jama.290.13.1739. PMID: 14519708.14519708
355 Anderson GL, Limacher M, Assaf AR, . Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women’s Health Initiative randomized controlled trial. JAMA. 2004 Apr 14;291(14):1701-12. doi: 10.1001/jama.291.14.1701. PMID: 15082697.15082697
356 Bauer DC, Gluer CC, Cauley JA, . Broadband ultrasound attenuation predicts fractures strongly and independently of densitometry in older women. A prospective study. Study of Osteoporotic Fractures Research Group. Arch Intern Med. 1997 Mar 24;157(6):629-34. PMID: 9080917.9080917
357 Cadarette SM, Katz JN, Brookhart MA, . Relative effectiveness of osteoporosis drugs for preventing nonvertebral fracture. Ann Intern Med. 2008 May 6;148(9):637-46. PMID: 18458276.18458276
358 Varenna M, Sinigaglia L, Adami S, . Association of quantitative heel ultrasound with history of osteoporotic fractures in elderly men: the ESOPO study. Osteoporos Int. 2005 Dec;16(12):1749-54. doi: 10.1007/s00198-005-1914-4. PMID: 15976988.15976988
359 Chesnut CH 3rd, Silverman S, Andriano K, . A randomized trial of nasal spray salmon calcitonin in postmenopausal women with established osteoporosis: the prevent recurrence of osteoporotic fractures study. PROOF Study Group. Am J Med. 2000 Sep;109(4):267-76. PMID: 10996576.10996576
360 Chesnut CH 3rd, Skag A, Christiansen C, . Effects of oral ibandronate administered daily or intermittently on fracture risk in postmenopausal osteoporosis. J Bone Miner Res. 2004 Aug;19(8):1241-9. doi: 10.1359/jbmr.040325. PMID: 15231010.15231010
361 Chlebowski RT, Hendrix SL, Langer RD, . Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative Randomized Trial. JAMA. 2003 Jun 25;289(24):3243-53. doi: 10.1001/jama.289.24.3243. PMID: 12824205.12824205
362 Crabtree NJ, Kroger H, Martin A, . Improving risk assessment: hip geometry, bone mineral distribution and bone strength in hip fracture cases and controls. The EPOS study. European Prospective Osteoporosis Study. Osteoporos Int. 2002 Jan;13(1):48-54. PMID: 11883408.11883408
363 Cranney A, Tugwell P, Zytaruk N, . Meta-analyses of therapies for postmenopausal osteoporosis. VI. Meta-analysis of calcitonin for the treatment of postmenopausal osteoporosis. Endocr Rev. 2002 Aug;23(4):540-51. doi: 10.1210/er.2001-6002. PMID: 12202469.12202469
364 Cryer B, Bauer DC. Oral bisphosphonates and upper gastrointestinal tract problems: what is the evidence? Mayo Clin Proc. 2002 Oct;77(10):1031-43. doi: 10.4065/77.10.1031. PMID: 12374247.12374247
365 Cummings SR, Cawthon PM, Ensrud KE, . BMD and risk of hip and nonvertebral fractures in older men: a prospective study and comparison with older women. J Bone Miner Res. 2006 Oct;21(10):1550-6. doi: 10.1359/jbmr.060708 [doi]. PMID: 16995809.16995809
366 Curb JD, Prentice RL, Bray PF, . Venous thrombosis and conjugated equine estrogen in women without a uterus. Arch Intern Med. 2006 Apr 10;166(7):772-80. doi: 10.1001/archinte.166.7.772. PMID: 16606815.16606815
367 Cushman M, Kuller LH, Prentice R, . Estrogen plus progestin and risk of venous thrombosis. JAMA. 2004 Oct 6;292(13):1573-80. doi: 10.1001/jama.292.13.1573. PMID: 15467059.15467059
368 Dargent-Molina P, Piault S, Breart G. A comparison of different screening strategies to identify elderly women at high risk of hip fracture: results from the EPIDOS prospective study. Osteoporos Int. 2003 Dec;14(12):969-77. doi: 10.1007/s00198-003-1506-0. PMID: 14520511.14520511
369 Diez-Perez A, Gonzalez-Macias J, Marin F, . Prediction of absolute risk of non-spinal fractures using clinical risk factors and heel quantitative ultrasound. Osteoporos Int. 2007 May;18(5):629-39. doi: 10.1007/s00198-006-0297-5 [doi]. PMID: 17235664.17235664
370 Frediani B, Acciai C, Falsetti P, . Calcaneus ultrasonometry and dual-energy X-ray absorptiometry for the evaluation of vertebral fracture risk. Calcif Tissue Int. 2006 Oct;79(4):223-9. doi: 10.1007/s00223-005-0098-4. PMID: 16969597.16969597
371 Gennari C, Chierichetti SM, Bigazzi S, . Comparative effects on bone mineral content of calcium plus salmon calcitonin given in two different regimens in postmenopausal osteoporosis. Curr Ther Res. 1985;38:455-62.
372 Gluer CC, Barkmann R. Quantitative ultrasound: use in the detection of fractures and in the assessment of bone composition. Curr Osteoporos Rep. 2003 Dec;1(3):98-104. PMID: 16036071.16036071
373 Gonnelli S, Cepollaro C, Gennari L, . Quantitative ultrasound and dual-energy X-ray absorptiometry in the prediction of fragility fracture in men. Osteoporos Int. 2005 Aug;16(8):963-8. doi: 10.1007/s00198-004-1771-6. PMID: 15599495.15599495
374 Greenfield DM, Walters SJ, Coleman RE, . Prevalence and consequences of androgen deficiency in young male cancer survivors in a controlled cross-sectional study. J Clin Endocrinol Metab. 2007 Sep;92(9):3476-82. doi: 10.1210/jc.2006-2744. PMID: 17579201.17579201
375 Greenspan DL, Bone H, Marriott TB, . Preventing the first vertebral fracture in postmenopausal women with low bone mass using PTH (I-84): results from the TOP study. J Bone Miner Res. 2005;20(Suppl 1):S56.
376 Hans D, Dargent-Molina P, Schott AM, . Ultrasonographic heel measurements to predict hip fracture in elderly women: the EPIDOS prospective study. Lancet. 1996 Aug 24;348(9026):511-4. PMID: 8757153.8757153
377 Hans D, Durosier C, Kanis JA, . Assessment of the 10-year probability of osteoporotic hip fracture combining clinical risk factors and heel bone ultrasound: the EPISEM prospective cohort of 12,958 elderly women. J Bone Miner Res. 2008 Jul;23(7):1045-51. doi: 10.1359/jbmr.080229. PMID: 18302507.18302507
378 Harris ST, Blumentals WA, Miller PD. Ibandronate and the risk of non-vertebral and clinical fractures in women with postmenopausal osteoporosis: results of a meta-analysis of phase III studies. Curr Med Res Opin. 2008 Jan;24(1):237-45. doi: 10.1185/030079908x253717. PMID: 18047776.18047776
379 Hizmetli S, Elden H, Kaptanoglu E, . The effect of different doses of calcitonin on bone mineral density and fracture risk in postmenopausal osteoporosis. Int J Clin Pract. 1998 Oct;52(7):453-5. PMID: 10622084.10622084
380 Hsia J, Criqui MH, Herrington DM, . Conjugated equine estrogens and peripheral arterial disease risk: the Women’s Health Initiative. Am Heart J. 2006 Jul;152(1):170-6. doi: 10.1016/j.ahj.2005.09.005. PMID: 16824852.16824852
381 Kaufman JM, Orwoll E, Goemaere S, . Teriparatide effects on vertebral fractures and bone mineral density in men with osteoporosis: treatment and discontinuation of therapy. Osteoporos Int. 2005 May;16(5):510-6. doi: 10.1007/s00198-004-1713-3. PMID: 15322742.15322742
382 Khaw KT, Reeve J, Luben R, . Prediction of total and hip fracture risk in men and women by quantitative ultrasound of the calcaneus: EPIC-Norfolk prospective population study. Lancet. 2004 Jan 17;363(9404):197-202. doi: 10.1016/s0140-6736(03)15325-1. PMID: 14738792.14738792
383 Kurland ES, Cosman F, McMahon DJ, . Parathyroid hormone as a therapy for idiopathic osteoporosis in men: effects on bone mineral density and bone markers. J Clin Endocrinol Metab. 2000 Sep;85(9):3069-76. doi: 10.1210/jcem.85.9.6818. PMID: 10999788.10999788
384 Lacroix AZ, Buist DS, Brenneman SK, . Evaluation of three population-based strategies for fracture prevention: results of the osteoporosis population-based risk assessment (OPRA) trial. Med Care. 2005 Mar;43(3):293-302. PMID: 15725986.15725986
385 Manson JE, Hsia J, Johnson KC, . Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003 Aug 7;349(6):523-34. doi: 10.1056/NEJMoa030808. PMID: 12904517.12904517
386 Masoni A, Morosano M, Pezzotto SM, . Construction of two instruments for the presumptive detection of post-menopausal women with low spinal bone mass by means of clinical risk factors. Maturitas. 2005 Jul 16;51(3):314-24. doi: 10.1016/j.maturitas.2004.08.015. PMID: 15978976.15978976
387 Mulleman D, Legroux-Gerot I, Duquesnoy B, . Quantitative ultrasound of bone in male osteoporosis. Osteoporos Int. 2002 May;13(5):388-93. doi: 10.1007/s001980200044. PMID: 12086349.12086349
388 Neer RM, Arnaud CD, Zanchetta JR, . Effect of parathyroid hormone (1-34) on fractures and bone mineral density in postmenopausal women with osteoporosis. N Engl J Med. 2001 May 10;344(19):1434-41. doi: 10.1056/nejm200105103441904. PMID: 11346808.11346808
389 Overgaard K, Hansen MA, Jensen SB, . Effect of salcatonin given intranasally on bone mass and fracture rates in established osteoporosis: a dose-response study. BMJ. 1992 Sep 5;305(6853):556-61. PMID: 1393035.1393035
390 Richards JS, Amdur RL, Kerr GS. Osteoporosis risk factor assessment increases the appropriate use of dual energy X-ray absorptiometry in men and reduces ethnic disparity. J Clin Rheumatol. 2008 Feb;14(1):1-5. doi: 10.1097/RHU.0b013e31816356be. PMID: 18431089.18431089
391 Rico H, Revilla M, Hernandez ER, . Total and regional bone mineral content and fracture rate in postmenopausal osteoporosis treated with salmon calcitonin: a prospective study. Calcif Tissue Int. 1995 Mar;56(3):181-5. PMID: 7750020.7750020
392 Rossouw JE, Anderson GL, Prentice RL, . Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women’s Health Initiative randomized controlled trial. JAMA. 2002 Jul 17;288(3):321-33. PMID: 12117397.12117397
393 Rossouw JE, Prentice RL, Manson JE, . Postmenopausal hormone therapy and risk of cardiovascular disease by age and years since menopause. JAMA. 2007 Apr 4;297(13):1465-77. doi: 10.1001/jama.297.13.1465. PMID: 17405972.17405972
394 Rud B, Hilden J, Hyldstrup L, . Performance of the Osteoporosis Self-Assessment Tool in ruling out low bone mineral density in postmenopausal women: a systematic review. Osteoporos Int. 2007 Sep;18(9):1177-87. doi: 10.1007/s00198-006-0319-3 [doi]. PMID: 17361324.17361324
395 Russell AS, Morrison RT. An assessment of the new “SCORE” index as a predictor of osteoporosis in women. Scand J Rheumatol. 2001;30(1):35-9. PMID: 11252690.11252690
396 Salaffi F, Silveri F, Stancati A, . Development and validation of the osteoporosis prescreening risk assessment (OPERA) tool to facilitate identification of women likely to have low bone density. Clin Rheumatol. 2005 Jun;24(3):203-11. doi: 10.1007/s10067-004-1014-4. PMID: 15549501.15549501
397 Sawka AM, Papaioannou A, Adachi JD, . Does alendronate reduce the risk of fracture in men? A meta-analysis incorporating prior knowledge of anti-fracture efficacy in women. BMC Musculoskelet Disord. 2005;6:39. doi: 10.1186/1471-2474-6-39. PMID: 16008835.16008835
398 Stefanick ML, Anderson GL, Margolis KL, . Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA. 2006 Apr 12;295(14):1647-57. doi: 10.1001/jama.295.14.1647. PMID: 16609086.16609086
399 Tracz MJ, Sideras K, Bolona ER, . Testosterone use in men and its effects on bone health. A systematic review and meta-analysis of randomized placebo-controlled trials. J Clin Endocrinol Metab. 2006 Jun;91(6):2011-6. doi: 10.1210/jc.2006-0036. PMID: 16720668.16720668
400 Van der Klift M, De Laet CE, McCloskey EV, . The incidence of vertebral fractures in men and women: the Rotterdam Study. J Bone Miner Res. 2002 Jun;17(6):1051-6. doi: 10.1359/jbmr.2002.17.6.1051. PMID: 12054160.12054160
401 Vestergaard P, Jorgensen NR, Mosekilde L, . Effects of parathyroid hormone alone or in combination with antiresorptive therapy on bone mineral density and fracture risk--a meta-analysis. Osteoporos Int. 2007 Jan;18(1):45-57. doi: 10.1007/s00198-006-0204-0. PMID: 16951908.16951908
402 Wallace LS, Ballard JE, Holida y D, . Evaluation of decision rules for identifying low bone density in postmenopausal African-American women. J Natl Med Assoc. 2004 Mar;96(3):290-6. PMID: 15040510.15040510
403 Wassertheil-Smoller S, Hendrix SL, Limacher M, . Effect of estrogen plus progestin on stroke in postmenopausal women: the Women’s Health Initiative: a randomized trial. JAMA. 2003 May 28;289(20):2673-84. doi: 10.1001/jama.289.20.2673. PMID: 12771114.12771114
404 Wells GA, Cranney A, Peterson J, . Alendronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008(1):Cd001155. doi: 10.1002/14651858.CD001155.pub2. PMID: 18253985.18253985
405 Wells GA, Cranney A, Peterson J, . Etidronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008(1):Cd003376. doi: 10.1002/14651858.CD003376.pub3. PMID: 18254018.18254018
406 Wells G, Cranney A, Peterson J, . Risedronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008(1):Cd004523. doi: 10.1002/14651858.CD004523.pub3. PMID: 18254053.18254053