# Acknowledgments

The authors acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Evelyn Whitlock, MD, MPH, former Director, Kaiser Permanente Research Affiliates EPC; Jennifer S. Lin, MD, Director, Kaiser Permanente Research Affiliates EPC; RTI International—University of North Carolina at Chapel Hill EPC staff Kathleen N. Lohr, PhD, Lynn Whitener, DrPH, Linda Lux, MPA, Andrew Kraska, BA, Janice Handler, BA, Stephanie Scope, BS, Carol Woodell, BSPH, Rachel Weber, PhD, Linda J. Lux, MPA, and Loraine Monroe; and peer reviewers: Rosanne Leipzig, MD, PhD, Diana Pettiti, MD, MPH, Margaret Gourlay, MD, MPH, Carolyn Crandall, MD, MS, Mary Roary, PhD, and four anonymous reviewers.