# 4 Discussion

This chapter begins with a summary of review findings for each key question (KQ); Table 9 provides additional details. Our synthesis also addressed two contextual questions on the (1) different fracture risk thresholds for identifying patients for further evaluation or treatment and (2) the effectiveness of screening strategies using different ages to start and stop screening and screening intervals (see Methods for detailed contextual questions). The introduction chapter includes information on contextual question 1; we address contextual question 2 after the summary of findings for the various KQs in this chapter. Following those sections, we present limitations of the evidence and our update review, and then end with conclusions.

Table 9 Summary Of Evidence

Key Question | Population, Intervention | No. of Studies; No. of Observations | Summary of Findings by Outcome | Consistency/Precision | Reporting Bias | Overall Quality of Studies | Body of Evidence Limitations | EPC Assessmentof Strength of Evidence: For Outcome | Applicability
KQ1: Effectiveness of screening | Women | 1; 12,483 | Osteoporotic fratures: 12.9% vs. 13.6%; HR, 0.94; 95% CI, 0.85 to 1.03 All clinical fractures: 15.3% vs. 16.0%; HR: 0.94; 95% CI, 086 to 103 Mortality: 8.8% vs. 8.4%; HR 1.05, 95% CI, 0.93 to 1.19 Hip fractures: 2.6% vs. 3.5%; HR 0.72; 95% CI, 0.59 to 0.89 | Single study, consistency unknow n/precise for hip fractures, imprecise for other outcomes | No evidence of reporting bias | Fair | Potential for contamination | Low for benefit for hip fractures, insufficient for other outcomes | Unclear whether findings apply to men or younger women
KQ 2a Accuracy of clinical risk assessment instruments for identifying osteoporosis | Women^a^ | 27; 55,898 | AUCs range from 0.32 to 0.87 for all included instruments (pooled AUCs range from 0.65 to 0.76) | Inconsistent/precise | No evidence of reporting bias | Fair | Heterogeneity in included studies | Moderate | Unclear whether findings apply to subgroups defined by age or race
KQ 2a Accuracy of clinical risk assessment instruments for identifying osteoporosis | Men | 11; 14,052 | AUCs range from 0.62 to 0.89 for all included instruments (pooled AUCs range from 0.76 to 0.80]) | Inconsistent/imprecise | No evidence of reporting bias | Fair | Heterogeneity in included studies | Low | Unclear whether findings apply to subgroups defined by age
KQ 2a Accuracy of machine-based tests for identifying osteoporosis | Women | 7; 1,969 | BMD tests for identifying osteoporosis: AUCs range from 0.67 to 0.94 for all included machine-based tests^b^ (pooled AUC for calcaneal QUS: 0.77 [95% CI, 0.72 to 0.81]) | Inconsistent/precise | No evidence of reporting bias | Fair | Heterogeneity in included studies | Moderate | Unclear whether findings apply to subgroups defined by age or race
KQ 2a Accuracy of machine-based tests for identifying osteoporosis | Men | 3; 5,142 | BMD tests for identifying osteoporosis for calcaneal QUS: 0.80 [95% CI, 0.67 to 0.94]) | Inconsistent/imprecise | No evidence of reporting bias | Fair | Ultrasound imaging only; heterogeneity in size, estimate of effect, and applicability of included studies | Low | Unclear whether findings apply to subgroups defined by age
KQ 2a Accuracy of machine-based tests for fracture prediction | Women | Varies by type of imaging test and site of test | Centrally measured DXA BMD, TBS, or a combination of both predicting fractures from 14 studies, N=46,036: AUCs range from 0.59 to0.86 For other machine-based tests or combination of tests, 2 studies with N=712 QUS alone predicting fractures: AUCs range from 0.66 to 0.72. QUS + DXA BMD predicting fractures: AUCs range from 0.72 to 0.81. | Inconsistent/precise | No evidence of reporting bias | Fair | Inconsistent control for baseline variables | Moderate | Unclear whether findings apply to nonwhite subgroups
KQ 2a Accuracy of machine-based tests for fracture prediction | Men | 3; 7,972 | Centrally measured DXA BMD or TBS predicting fractures: AUCs range from 0.68 to 0.85 QUS alone predicting fractures: AUCs range from 0.64 to 0.84. QUS + DXA BMD predicting fractures: AUCs range from 0.69 to 0.85. | Inconsistent/precise | No evidence of reporting bias | Fair to good | Inconsistent control for baseline variables | Moderate | Unclear whether findings apply to nonwhite, non-east Asian subgroups
KQ 2a Accuracy of machine-based tests for fracture prediction | Women and Men combined | 2; 46,300 | Centrally measured DXA BMD predicting fractures: AUCs range from 0.66 to 0.80 | Inconsistent/precise | No evidence of reporting bias | Fair to good | None identified | Moderate | Findings limited to Canadian samples, unclear whether results are applicable to other populations
KQ 2a Accuracy of fracture risk prediction instruments | Women | Varies by instrument | AUCs for fracture risk prediction instruments range from 0.53 to 0.89, and vary by instrument, type of fracture, and whether BMD is used in the prediction. Within this range, prediction of hip fractures and predictions that use BMD report higher AUCs. Pooled AUC for FRAX prediction of hip fractures without BMD: 0.76 (95% CI, 0.72 to 0.82, I^2^=99.8%, 12 studies, 190,795 women) and with BMD: 0.79 (95% CI, 0.76 to 0.81, I^2^=99.1%, 10 studies, 161,984 women) Pooled AUC for FRAX prediction of MOF without BMD: 0.67 (95% CI, 0.65 to 0.68, I^2^=99.2%, 17 studies, 158,897 women) and with BMD: 0.70 (95% CI, 0.68 to 0.71, I^2^=92.1%, 12 studies, 62,054 women) | Inconsistent/precise | No evidence of reporting bias | Fair | Some studies did not follow subjects for the entire duration of the prediction interval (i.e., 10 years). Heterogenous study populations, that may have included subjects with osteoporosis, with prior fracture, or receiving treatment. | Moderate | Other than FRAX, most instruments have not been calibrated for use in U.S. populations. Unclear whether findings apply to nonwhite subgroups.
KQ 2a Accuracy of fracture risk prediction instruments | Men | Varies by instrument | AUCs for fracture risk prediction instruments range from 0.62 to 0.88, and vary by instrument, type of fracture, and whether BMD is used in the prediction.Within this range, prediction of hip fractures and predictions that use BMD report higher AUCs Pooled AUC for FRAX prediction of hip fractures without BMD: 0.73 (95% CI, 0.68 to 0.77, I^2^=96.7%, 3 studies, 13,970 men) and with BMD: 0.76 (95% CI, 0.72 to 0.80, I^2^=96.7%, 3 studies, 13,970 men) Pooled AUC for FRAX prediction of MOF without BMD: 0.62 (95% CI, 0.61 to 0.64, I^2^=40.5%, 3 studies, 13,970 men) and with BMD: 0.67 (95% CI, 0.66 to 0.68, I^2^=0%, 4 studies, 15,842 men) | Inconsistent/precise | No evidence of reporting bias | Fair | Some studies did not follow subjects for the entire duration of the prediction interval (i.e., 10 years). Heterogenous study populations, that may have included subjects with osteoporosis, with prior fracture, or receiving treatment. | Moderate | Other than FRAX, most instruments have not been calibrated for use in U.S. populations. Unclear whether findings apply to nonwhite subgroups.
KQ 2b | Women and men (1 study each) | 2; 4,926 | Similar accuracy of predicting fracture with repeat BMD when compared with baseline BMD alone | Consistent/precise | No evidence of reporting bias | Fair | Limited number of studies, followup period inadequate for women, small N for men, inconsistent screening intervals | Insufficient | Unclear whether all findings apply to subgroups by age, sex, or race
KQ3: Harms of screening | Women | 1; 12,483 | Anxiety: p value for repeated measures: 0.154 (variance NR) Quality of life: p value for repeated measures for Euroquol 5-Dimension and SF 12>0.10 (variance NR) | Single study, consistency and precision unknown | No evidence of reporting bias | Fair | Potential for contamination and reporting bias | Insufficient | Unclear whether findings apply to men or younger women
KQ 4a | Women and men | Varies by outcome | Bisphosphonates for women RR for vertebral fractures: 0.57 (95% CI, 0.41-0.78), 5 trials, N=5,433, 2.1% vs. 3.8% RR for nonvertebral fracures:0.84 (95% CI, 0.76 to 0.92); 8 trials, N=16,438, 8.9% vs. 10.6% RR for hip fractures: 0.70 (95% CI, 0.44 to 1.11); 3 trials, N=8,988, 0.7% vs. 0.96% Zoledronic acid for men RR for morphometric vertebral fracures: 0.33 (95% CI, 0.16 to 0.70); 1 trial, N=1,199, 1.5% vs. 4.6% RR for nonvertebral fractures, 0.65 (95% CI, 0.21 to 1.97), 1 trial, N=1,199, 0.9% vs. 1.3% RR for clinical fractures (vertebral or nonvertebral), 0.57 (95% CI, 0.21 to 1.52), 1 trial, N=1,199, 1.0% vs. 1.8% | Consistent/precise for vertebral and nonvertebral fractures, consistent and imprecise for hip outcomes | No evidence of reporting bias | Fair | Evidence dominated by one big study for each drug | Moderate for benefit for bisphosphonates for vertebral and nonvertebral fractures, low for hip fractures | Unclear whether all findings apply to subgroups by age, sex, or race
| Women | 1; 7,705 | Raloxifene RR for vertebral fractures: 0.64 (95% CI, 0.53 to 0.76), 7.5% vs. 12.5% RR for nonvertebral fractures: 0.93 (0.81-1.06^c^, 12.1% vs. 12.9% | Consistency unknown (single trial)/precise for vertebral fractures, imprecise for nonvertebral fractures | No evidence of reporting bias | Good | Single large trial | Moderate for benefit for vertebral fractures, low for nonvertebral fractures | Unclear whether findings apply to other sub-populations defined by age, sex, or race
| Women | Varies by outcome | Denosumab RR for vertebral fractures: 0.32 (95% CI, 0.26 to 0.41), 2 trials, 8,020 participants, 2.3% vs. 7.2% in trial with events RR for nonvertebral fractures: 0.80 (95% CI, 0.67 to 0.95), 1 trial, 7,808 participants, 6.1% vs. 7.5% RR for hip fractures: 0.60 (0.37 to 0.97), 1 trial, 7,808 participants, 0.7% vs. 1.1% | Consistency unknown (single trial for most outcomes)/precise | No evidence of reporting bias | Fair | Single large trial for most outcomes | Low for benefit for vertebral, nonvertebral, and hip fractures | Unclear whether findings apply to subgroups by age, sex, or race
| Women and men | 2; 2,830 | Parathyroid hormone For women (1 trial, N=2,532) RR for vertebral fractures: 0.32 (95% CI: 0.14 to 0.75), 0.7% vs. 2.1%, RR for nonvertebral fractures: 0.97 (95% CI, 0.71 to 1.33), 5.6% vs. 5.8% For men (1 trial, N=298) RR for nonvertebral fractures: 0.65 (95% CI, 0.11 to 3.83), 1.3% vs. 2.0% | Consistency unknown (single trial/ precise for women for vertebral fractures Consistency unknown (single trial)/ imprecise for men for vertebral fractures | No evidence of reporting bias | Fair | Single trial each for men and women; small trial in men | Low for benefit for vertebral fractures for women, insufficient for men for vertebral fractures | Unclear whether findings apply to subgroups by age, sex, or race
KQ 4b | Women | 4; N varies by drug | Similar results by subgroup for Alendronate for baseline BMD (1 trial, N=3,737) Risedronate for age (1 trial, N=2,648) Raloxifene (prior fractures, 1 trial, N=5,114) Denosumab for age, baseline BMD, and a combination of risk factors (1 trial, N=7,868) | Consistency unknown (single trial)/ precise | No evidence of reporting bias | Fair | Single trial for each drug | Low for no differences | No information on variations by menopausal status
KQ 5 | Women and men | Varies by outcome | Bisphosphonates^d^ RR for discontinuations: RR, 0.99 (95% CI, 0.91 to 1. 07) 20 trials, N=17,369^e^, 11. 5% vs. 11.8% RR for serious adverse events: RR, 0.98 (95% CI, 0.92 to 1.04), 17 trials, N=11,745^e^, 21.0% vs. 23.4% RR for upper GI events: 1.01 (95% CI, 0.98 to 1.05); 13 trials, N=20,485^e^, 35.3% vs. 35.6% No statistically significant differences for cardiovascular outcomes No reports of osteonecrosis of the jaw No reports of atypical femur fracture No reports of kidney failure 3 trials combining results for men and women or included men only had results consistent with trials of women only for discontinuations, serious adverse events, and upper GI events | Consistent/ precise for discontinuations, serious adverse events, and upper gastrointestinal events; inconsistent and imprecise for cardiovascular outcomes, osteonecrosis and atypical femur fractures | No evidence of reporting bias | Fair | Evidence dominated by one big study for each drug | Moderate for no harms bisphosphonates for discontinuation, serious adverse events, and upper gastrointestinal events; insufficient for cardiovascular events, osteonecrosis and atypical femur fractures | Unclear whether findings for all drugs apply to sub-populations defined by age, sex, or race
| Women | Varies by outcome | Raloxifene RR for discontinuations: RR, 1.12 (95% CI, 0.98 to 1.28); 6 trials, N=6,438, 12.6% vs. 11.2% RR for deep vein thrombosis: 2.14 (95% CI, 0.99 to 4.66); 3 trials, N=5,839, 0.7% vs. 0.3% RR for hot flashes: 1.42 (95% CI, 1.22 to 1.66); 5 trials; N=6,249, 11.2% vs. 7.6% RR for leg cramps: 1.41 (95% CI: 0.92 to 2.14); 3 trials; N=6,000, 8.0% vs. 4.8% | Inconsistent/ precise for deep vein thrombosis, leg cramps, and hot flashes; consistent/ imprecise for discontinuation | No evidence of reporting bias | Good | Single large trial dominating results | Low for harm for deep vein thrombosis and hot flashes; low for no harm discontinuation and leg cramps | Unclear whether findings apply to other sub-populations defined by age, sex, or race
| Women | Varies by outcome | Denosumab RR for discontinuations: 1.14 (95% CI, 0.85 to 1.52), 2.4% vs. 2.1% RR for serious adverse events: 1.12 (95% CI, 0.88 to 1.44), 23.8% vs. 23.9% RR for serious infections: 1.89 (95% CI, 0.61 to 5.91), 4.0% vs. 3.3% | Inconsistent/ imprecise for discontinuations, consistent/ imprecise for serious adverse events and serious infections | No evidence of reporting bias | Fair | Single large trial dominating results | Insufficient for discontinuation; low for no harm for serious adverse events and serious infections | Unclear whether findings apply to subgroups by age, sex, or race
| Women and men | 2; 2,830 | Parathyroid hormone For women (1 trial, N=2,532) RR for discontinuations: 1.23 (1.08-1.40), 30.2% vs. 24.6% For men (1 trial, N=298 for 20 pg [FDA approved dose] vs. placebo) RR for discontinuations: 1.94 (0.81-4.69), 9.2% vs. 4.8% RR for cancers: 0.97 (0.2-4.74), 2.0 vs. 2.0% | Consistency unknown (single trial)/precise Consistency unknown (single trial)/ imprecise for men | No evidence of reporting bias | Fair | Single trial each for men and women; small trial in men | Low for harm for women for discontination; insufficient for men for discontinuations and serious adverse events | Unclear whether findings apply to subgroups by age or race

a One study (not included in strength of evidence ratings; N=282) evaluated the accuracy of FRAX and OST in a mixed population with 45.1% women. AUCs ranged from 0.68 to 0.76 and is consistent with findings in men and women separately.

b Included studies evaluated calcaneal quantitative ultrasound, peripheral dual energy X-ray absorptiometry, digital X-ray radiogrammetry, and radiographic absorptiometry.

c Data available only for combined group of participants receiving dosages of 60 mg/day or 120 mg/day. Recommended dosage is 60 mg/day.

d Pooled estimates include men, women, and combined estimates (one study did not provide adverse events by sex).^254^

e Sum of N in trials in meta-analysis, after accounting for the duplication in patients in the placebo arm for a 3-arm study.^202^

Abbreviations: AUC=area under the curve; BMD=bone mineral density; CI=confidence interval; DXA=dual-energy X-ray absorptiometry; EPC=Evidence-based Practice Center; FDA=Food and Drug Administration; FRAX=Fracture Risk Assessment Tool; KQ=key question; MOF=major osteoporotic fractures; N=number; QUS=quantitative ultrasound; RR=relative risk; TBS=trabecular bone score; U.S.=United States.

## Summary of Review Findings

### Effectiveness of Screening Approaches (Key Question 1)

One trial (SCOOP) addressed the gap identified in the 2010 review on the effectiveness of screening on morbidity and mortality associated with osteoporotic fracture risk. The trial found evidence of benefit for a secondary outcome only—the incidence of hip fractures. For all other outcomes (osteoporosis-related fractures, clinical fractures, and mortality), the trial did not report benefits. The discrepancy in results between the hip fracture outcomes and other outcomes, coupled with the lack of the significance of the primary outcome, points to the need for caution in interpreting the results. A few potential explanations include changes in usual care standards and the threshold used to identify those at risk. Identification and treatment in the usual care may have changed over time with the release of guidelines during the trial recruitment^315^ and observation^316^ periods, and as a result, differences between the intervention and usual care arms may have been diminished. SCOOP investigators also note that the use of the 10-year risk of hip fracture (rather than the risk of any major osteoporotic fracture) as the threshold for further intervention may have increased the likelihood of effectiveness of the screening in preventing hip rather than other fractures, given that risks of hip and other fractures are correlated but not identical^72^. The authors also note a potential bias toward selection of healthy participants. However, participants also had a higher risk of parental history of fractures than nonparticipants, and the effect of these differences in baseline characteristics on outcomes is unclear.

Women in the intervention arm received universal screening, whereas women in the usual care arm received risk-based identification and treatment. However, the factors described above (under-treatment, under-reporting, the absence of primary care guidelines at the start of the trial, and the release of guidelines during the trial) imply that usual care could have varied across facilities and may have changed somewhat over the period of the trial. These variations could explain the results of the SCOOP trial.

Results from studies that did not meet our quality or design criteria are consistent with the SCOOP trial in demonstrating reductions in hip fractures and no effects on major osteoporotic fractures, but confidence in these results is limited. Results from one high risk-of-bias RCT of 4,800 women ages 45 to 54 years in Aberdeen, Scotland, indicated no difference in the rate of incident major osteoporotic fractures (MOF) (3.96% [47/1841] vs. 4.03% [50/1241]; RR, 1.00, 95% CI, 0.983 to 1.02)^317^ but the study’s attrition exceeded 40 percent.^317^ A cohort study with a nonconcurrent control (which did not meet our design criteria), evaluated the effectiveness of screening for osteoporosis on reducing hip fractures in 3,107 women and men age 65 years or older.^78^ This study was part of a nested study on bone density within the Cardiovascular Health Study. Participants in two of four counties were offered DXA screening while the remaining received usual care. The study reported an adjusted hazard of hip fracture of 0.64 (2.32% [33/1,422] vs. 4.09% [69/1,685]; 95% CI, 0.41 to 0.99) for the screened group compared with the usual care group.

### Accuracy and Reliability of Screening Approaches (Key Question 2a)

Our findings are consistent with the 2010 review on this topic:^3^ Nelson et al concluded that the accuracy of screening approaches is moderate. We did not observe differences by sex; predictions of hip fractures were more accurate than prediction of fractures at other sites or composite fracture outcomes (i.e., major osteoporotic fractures).

Using centrally measured dual-energy X-ray absorptiometry (DXA) as the reference standard for identifying osteoporosis, the pooled estimate of accuracy as measured by the area under the curve (AUC) for clinical risk assessment instruments for women ranges from 0.65 to 0.76 and for men from 0.76 to 0.80. Studies of machine-based tests for screening to identify osteoporosis generally compared calcaneal quantitative ultrasound to central dual energy X-ray absorptiometry (DXA); pooled areas under the curve (AUCs) ranged from 0.77 for women to 0.80 for men.

Studies of machine-based tests to predict fractures used a variety of machine-based tests (areal bone mineral density [BMD] with central DXA, trabecular bone score, and quantitative ultrasound [QUS]) and did not show differences by sex, type of test, or age. For these tests, predictions of hip fractures had higher range of accuracy (AUC of 0.80 to 0.85) in eight of twelve studies than predictions of fractures at other sites (AUC, 0.54 to 0.77).

The evidence base for fracture risk prediction instruments is dominated by studies of Fracture Risk Assessment Tool (FRAX) but also includes studies of other prediction instruments. Instruments differ by the number of risks included but they commonly include age, sex (if developed for use with both sexes), weight or body mass index (BMI), and a variety of medical conditions or historical events (e.g., prior fracture or fall). Some of the evaluated instruments can incorporate BMD results into the risk prediction, most commonly BMD of the femoral neck. Pooled analysis of FRAX AUCs in men ranged from a low of 0.62 for predicting major osteoporotic fractures without the inclusion of BMD to a high of 0.76 for predicting hip fractures with BMD included. Pooled AUCs in women for FRAX similarly range from a low of 0.67 for predicting major osteoporotic fractures without the inclusion of BMD to a high of 0.79 for predicting hip fractures with BMD. Garvan, QFracture, and Fracture Risk Calculator were the only other instruments validated for use in men. We identified no published studies that met our eligibility criteria that assessed calibration of the U.S. version of FRAX or calibration of other risk assessment instruments in U.S. populations. Overall, the accuracy of clinical risk assessment tools for identifying osteoporosis or predicting fractures generally ranges from very poor (0.50) to good (0.90). Table 10 recapitulates results for the instruments for which we found evidence on the accuracy of identifying osteoporosis as well as the accuracy of predicting fractures. FRAX predicts fractures over a 10-year time horizon, though not all studies reported 10 complete years of participant followup for reporting accuracy. The other instrument (SCORE, ORAI, OSIRIS, OST) were not developed as fracture risk prediction instruments; the length of followup reported by studies who evaluated these instruments as risk prediction instruments ranged from 3 to 10 years.

Table 10 Accuracy Of Clinical Risk Prediction Instruments With Evidence On Identifying Osteoporosis And Predicting Fractures

Instrument | Risk Factors | Sex | Accuracy in Identifying Osteoporosis (at Femoral Neck or Any Skeletal Site as Indicated); N of Studies; N of Participants | Accuracy in Predicting Fractures
FRAX without BMD | Age, sex, weight, height, previous fracture, parental hip fracture, current smoking, glucocorticoid steroid use, rheumatoid arthritis, secondary osteoporosis, alcohol use | Men and women | Men: MOF: 0.79 (0.74 to 0.84); 1; 1,498 Hip: NR Women: MOF: Ranges from 0.58 to 0.82; (any site or hip) 4; 22,141 Hip: 0.82 (any site); 1; 505 Both sexes^†^ (any site): MOF: 0.68 (95% CI, 0.63 to 0.74); 1; 626 Hip: 0.70 (95% CI, 0.64 to 0.75); 1; 626 | [underlined: Men] MOF: 0.62 (95% CI, 0.61 to 0.64); 3; 13,970 Hip: 0.73 (95% CI, 0.68 to 0.77); 3; 13,970 [underlined: Women] MOF: 0.67 (95% CI, 0.65 to 0.68); 17; 158,897 Hip: 0.76 (95% CI, 0.72 to 0.81); 12; 190,795 [underlined: Both Sexes] MOF: 0.67 (95% CI, 0.66 to 0.67); 3; 66,777 Hip: 0.77 (95% CI, 0.73 to 0.79); 1; 6,697 0.79 (95% CI, 0.78 to 0.82); 1; 39,603
SCORE | Age, weight, race, rheumatoid arthritis, prior nontraumatic fracture, prior estrogen use | Women | Pooled AUC (any site): 0.70, (95% CI, 0.69 to 0.71); 8; 15,362 | MOF (10-year risk): 0.53 (95% CI, 0.53 to 0.54); 1; 62,492 MOF (3-year risk): 0.70 (95% CI, 0.66 to 0.74);1; 3,614
ORAI | Age, weight, current estrogen use | Women | Pooled AUC (any site): 0.65 (95% CI, 0.60 to 0.71); 10; 16,780 | MOF(3-year risk): 0.71 (95% CI, 0.68 to 0.75); 1; 3,614 Any OF (3-year risk): 0.69 (95% CI, 0.66 to 0.72); 1; 3,614
OSIRIS | Age, weight, current hormone therapy use, prior fracture | Women | Pooled AUC (any site): 0.68 (95% CI 0.64 to 0.72); 5; 5,649 | MOF (3-year risk): 0.70 (95% CI, 0.66 to 0.74); 1; 3,614 Any OF (3-year risk): 0.68 (95% CI, 0.65 to 0.72); 1; 3,614
OST | Age, weight | Women | Pooled AUC (any site): 0.65 (95% CI, 0.60 to 0.69); 13; 44,323; without outlier,^88,^ ^89^ pooled AUC: 0.71, 95% CI, 0.70 to 0.72; 11; 42,802 | MOF (3-year risk): 0.56 (95% CI, 0.52 to 0.60, 8,254 women) 0.71 (95% CI, 0.68 to 0.75, 3,614 women) MOF (10-year risk): 0.52 (95% CI, 0.52 to 0.53, 62,492 women)

† Study population was 45.5% women.

Abbreviations: AUC=area under the curve; BMD=bone mineral density; CI=confidence interval; FRAX=Fracture Risk Assessment Tool; MOF=major osteoporotic fracture defined as fractures of the proximal femur, distal radius, proximal humerus, and clinical vertebral fractures; OF=osteoporotic fracture; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=Osteoporosis Index of Risk; OST=osteoporosis self-assessment tool; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool.

### Evidence to Determine Screening Intervals for Osteoporosis and Low Bone Density (Key Question 2b)

The 2010 review noted the paucity of evidence on this topic,^3^ with a single study indicating no advantage to repeated measures (8 years apart).^194^ A second study, identified by our update, does not alter this conclusion: it also suggests similar accuracy in predicting fractures with repeat BMD (3.7 years apart) when compared with baseline BMD.^195^ Both studies included participants with a wide spectrum of baseline BMD from normal to osteoporosis. However, three studies that developed prognostic models suggested that the optimal screening interval varies by baseline BMD.^196-198^ Age and hormone replacement therapy use also influence optimal screening intervals.^196,^ ^197^

### Harms of Screening (Key Question 3)

One trial addresses the gap identified in the previous report on the harms of screening. The study found no evidence of harms on anxiety or quality of life.

### Benefits of Pharmacotherapy (Key Question 4a)

Our findings about medications align with those of the 2010 review. For women, the risk of vertebral fractures can be reduced by bisphosphonates, parathyroid hormone, raloxifene, and denosumab. The risk of nonvertebral fractures can be reduced by bisphosphonates and denosumab. The risk of hip fractures can be reduced by denosumab (relative risk [RR]: 0.60). Two of three studies of bisphosphonates that reported hip fractures were not powered to detect effects on hip fractures; the pooled evidence did not demonstrate a statistically significant benefit. Evidence is very limited for men. The risk of morphometric vertebral fractures can be reduced by zoledronic acid (RR, 0.33).^218^ One study, which was underpowered, found no statistically significant reductions in risk of clinical vertebral fractures or nonvertebral for men.^218^ The study of parathyroid hormone in men also demonstrated a trend toward benefit in nonvertebral fractures, consistent with the finding in women, but was not sta tistic a lly significant, possibly because it was stopped early.^240^ We found no studies reporting on hip fractures, fracture-related morbidity, or mortality.

### Variation in Benefits of Pharmacotherapy in Subgroups (Key Question 4b)

One trial each offered further analyses on subgroups for alendronate, risedronate, raloxifene, denosumab, and parathyroid hormone. We found no evidence from included studies on differences in effectiveness by age, baseline BMD, prior fractures, or a combination of risk factors.

### Harms of Pharmacotherapy (Key Question 5)

Although several trials reported on harms, they varied substantially in definitions. We found no consistent evidence of harms with bisphosphonates (discontinuation due to adverse events, serious adverse events, gastrointestinal events, and cardiovascular events). We found no bisphosphonate trials with reported cases of osteonecrosis of the jaw, atypical femur fractures, or kidney failure, although evidence from excluded studies of populations, designs, and comparators outside the purview of this review suggests a rare but increased risk with bisphosphonates for some harms. Specifically, raloxifene produced a higher risk of deep vein thrombosis (0.7% vs. 0.3%; pooled RR, 2.14; 95% confidence interval [CI], 0.99 to 4.66; I^2^=0%, 3 trials, N=5,839) and hot flashes (11.2% vs. 7.6%; pooled RR, 1.42; 95% CI, 1.22 to 1.66; I^2^=0%, 5 trials; N=6,249), but not discontinuations or leg cramps. One trial of parathyroid hormone reported a higher risk of discontinuation due to adverse events (29.7% vs. 24.6%; RR, 1.22; 95% CI, 1.08 to 1.40) for women; the trial in men did not report a higher risk of discontinuation. We found no statistically significantly increased of discontinuations, serious adverse events, or serious infections with denosumab. The evidence on harms in men was very limited—but consistent, when available—with harms for women.

## Contextual Considerations

We addressed Contextual Question 1 in the introduction chapter, in the section on the use and accuracy of fracture risk instruments for identifying patients for further evaluation. Below we discuss Contextual Question 2 on the effectiveness of screening strategies using different ages to start and start screening and screening intervals.

### Effectiveness of Screening Strategies Using Different Ages to Start and Stop Screening

#### Initiation of Screening: Women

Although the USPSTF and other guidelines recommend screening in average-risk women age 65 years or older, debate continues as to whether to recommend a standard age for mass screening. Studies suggest that mass screening and treatment of postmenopausal women under 60 years of age is likely to be very inefficient.^3,^ ^318^ One study concluded that women with a negative screening between the ages of 50 and 64 years are unlikely to benefit from frequent screenings because the population is less likely to experience a fracture before age 65.^198^ No studies have examined the long-term benefits of early treatment initiation.^318^ A modeling study examining the initiation of screening women at ages 55, 60, 65, 70, 75, and 80 years found that all screening strategies (e.g., DXA, prescreen with QUS before DXA; prescreened with Simple Calculated Osteoporosis Risk Estimation [SCORE] before DXA) were more effective than no screening in increasing quality-adjusted life-years (QALY).^319^ No screening was more expensive and less effective than multiple screening strategies starting at age 65 or older. However, no single strategy emerged clearly as best at willingness-to-pay thresholds of $50,000 per QALY or $100,000 per QALY, suggesting that differences between strategies are likely to be small.

#### Initiation of Screening: Men

No standard osteoporosis screening schedules for average-risk men exist,^196^ leading to continued uncertainty about starting and stopping ages. A study^320^ that examined the effectiveness of the DXA, Osteoporosis Self-Assessment Tool (OST), Vertebral Fracture Risk Assessment, and no screening found that all screening strategies, regardless of test used, screening initiation age (e.g., 50, 60, 70, or 80 years), or repeat screening interval (5 years or 10 years) were more effective than no screening in increasing QALYs. A study of community-dwelling 70-year old white men with no history of fractures found that selective DXA using an OST prescreen was most cost-effective relative to universal DXA screening at the lowest OST cutoff score of -2. Selective DXA using the OST was also more effective and less costly than no DXA screening among men age 84 or older.^321^

#### Discontinuation of Screening

Currently, no evidence examines the age to stop BMD testing and no guidelines recommend cessation of screening at a specific age for women or men.^318^ Cost-effectiveness studies suggest benefits from continuing to screen women in older age groups.^322,^ ^323^ Using a Markov model with women ages 70 to 80 years, one study showed greater cost-effectiveness when screening all women compared with screening women with at least one risk factor.^322^ Another modeling study found that universal DXA is more cost-effective with increasing age because the prevalence of low BMD (femoral neck T-score of <2.5 or less) increases substantially with age, as does associated fracture risk.^323^

### Effectiveness of Screening Strategies Using Different Screening Intervals

The effectiveness of using different screening intervals to identify osteoporosis was discussed under the results for KQ 2b.

## Limitations and Future Research

### Limitations

One eligible study addresses the direct question of the benefits and harms of screening for osteoporotic fractures. Given the limited direct evidence, strong links along the indirect evidence pathway are necessary. A major constraint in ensuring these strong links is that the operational definitions of osteoporosis (i.e., BMD T-scores) and the resulting thresholds for screening and treatment that are established based on these definitions capture only one aspect of osteoporotic fracture risk. Although osteoporotic fractures can arise from loss of bone mass, microarchitectural deterioration of bone tissue and decline in bone quality also contribute to fracture risk and are not captured by BMD measurement.^29^ As a consequence, screening approaches that rely on BMD measurement wholly or in part may not be the most accurate approaches for predicting risk of osteoporotic fractures.

Another important limitation of this evidence base is that it focuses on one of many approaches to averting osteoporotic fractures. The task of screening for and subsequently treating low bone density is only one aspect of fracture prevention: preventing falls is another critical component^24,^ ^29,^ ^324^ and is addressed by another USPSTF recommendation.^325^ A comprehensive approach may rely on screening, counseling, medication, physical therapy, and other interventions to prevent falls and improve physical function in older adults.

Clinical risk assessment instruments that can potentially capture a wider array of factors beyond BMD measurement also have serious constraints on utility for treatment decisions. No trials thus far have established efficacy of treatment based on identifying risk using clinical risk assessment tools: individuals enrolled in treatment trials are typically enrolled on the basis of their BMD level, not on fracture risk.

In the absence of strong evidence linking screening approaches to fracture risk, uncertainties persist in understanding who requires screening and how often. In particular, evidence on effectiveness of screening and treatment by age, baseline BMD, and baseline fracture risk continues to be lacking. Long-term studies on harms continue to be lacking. Evidence is limited on the value of repeat BMD screening. These gaps are particularly evident for younger postmenopausal women. Few studies compare strategies^57,^ ^58,^ ^113^ in this age group. One study shows that a FRAX threshold of 9.3% for a 10-year major osteoporotic fracture performs no better than chance in identifying osteoporosis^57^ and is inferior to OST and SCORE. All three performed poorly in predicting fractures.^58^

Other limitations of the evidence base pertain to the underlying heterogeneity of included studies. Screening studies differ in the strictness of their inclusion criteria, particularly with regard to baseline fractures, baseline BMD, and prior treatment. They also differ in the length of followup and in their applicabilit y to U.S. primary care populations. Studies of 10-year fracture risk did not always observe participants for 10 years. Further, most instruments were not calibrated for U.S. populations. The majority of both treatment and screening studies focused on women, and reported very limited results on the outcomes of screening and treatment in men. Some treatment studies included mixed populations of subjects with and without a history of prior osteoporotic fracture.

### Future Research

Identifying the optimal screening strategy to reduce osteoporotic fractures requires accounting for variations in patient baseline characteristics, multiple potential pathways into screening, and the multiple cascade of interventions that follow screening. Randomized controlled trials cannot fully address all these components, but decision analyses may offer some clarity. Decision analyses may also help frame a comprehensive approach to integrating multiple strategies relevant to preventing osteoporotic fractures beyond screening for osteoporotic risk, such as counseling and interventions for falls prevention and improvement in physical function.

Innovations in the measurement of bone quality that are followed by studies of implementation in and translation to primary care settings will help improve accuracy of screening approaches. Measurements of bone density other than central DXA require better evidence of accuracy and applicability in the context of treatments that target patients with centrally measured BMD. Evidence is lacking on the harms of screening, even for routine and widely available screening approaches.

Treatment trials focusing on or including men will help to fill gaps in our understanding of the benefits and harms of treatment in men. Notably, no randomized controlled trial of osteoporosis treatment in men has demonstrated reduction of hip fracture or clinical vertebral fractures. Evidence on an array of harms is not consistently available for long-term outcomes or for all medications.

Reanalyses of existing trials or new studies employing prospective observational data or fracture registries can help fill gaps on how treatment benefits and harms might vary by differences in baseline risk, including age and BMD status.

The evidence on optimal screening intervals is also scant. The present recommendation to repeat DXA screening at 2 years is based on the amount of time to observe a reliable change in BMD, although further research is necessary to determine the optimal interval of repeat screening associated with reduced fracture risk.

### Ongoing and Unpublished Studies

An ongoing, pragmatic trial in the United Kingdom (U.K.) is randomizing more than 11,000 women ages 70 to 85 years to screening or usual care. Women in the screening arm will have a 10-year fracture risk calculated using FRAX based on information obtained through questionnaires. The investigators propose to compare the probability of a hip fracture with age-based BMD testing and osteoporosis treatment thresholds established from existing U.K. cost-effectiveness data. No further action will be taken for women below these thresholds in the treatment arm; women with fracture risks above these thresholds will be offered BMD testing, followed by recalculation of their fracture risk and treatment as needed. Women will be followed for 5 years. The study is powered to detect an 18 percent reduction in fractures.^326^

Additionally, a search of trial registries yielded information about several completed and ongoing trials that have yet to publish results, but these trials can be expected to expand the evidence base on treatments (Appendix G). These include parathyroid hormone (3 trials, women, United States, N>90 [N not reported for 1 trial]), risedronate (2 trials, women, South Korea and United States, N=1,150), raloxifene (2 trials, women, multisite and United States respectively, N not reported), zoledronic acid (1 trial, women, United States, N=1000) and denosumab (1 trial, men and women, United States, N=212)

## Conclusions

Evidence from one trial of screening to prevent osteoporotic fractures suggests a reduction in hip fractures. The accuracy of screening ranges from very poor to good. Treatments reduce the risk of vertebral and nonvertebral fractures in women, and studies do not consistently demonstrate an increased risk of harms for drugs. Studies of raloxifene suggest a trend toward higher risk of deep vein thrombosis. Rare harms, such as osteonecrosis of the jaw and atypical femur fractures were not reported in this body of evidence but they may occur. The evidence is limited or not available for other regimens and outcomes among the populations included in this review.