# 3 Results

## Literature Search

We identified 5,207 unique records and assessed 842 full texts for eligibility (Figure 2). We excluded 674 studies for various reasons detailed in Appendix C and included 168 published articles of good or fair quality in our main analyses. One article was included for key question (KQ) 1, 103 articles were relevant for KQ 2a, 2 articles were relevant for KQ 2b, one article was relevant for KQ 3, 25 articles were relevant for KQ 4, and 50 articles were relevant for KQ 5. In addition to the previous report,^2,^ ^3^ we drew from reference lists and data from other systematic reviews.^73-76^ Details of quality assessments of included studies and studies excluded based on poor quality are provided in Appendix D. Appendix E lists the inclusion and exclusion status of studies included in the previous review. Appendix F presents details for included studies in Evidence Tables. Appendix G describes ongoing trials, and Appendix H presents forest plots for meta-analyses.

Figure 2 PRISMA Tree

a: Due to overlap in studies across populations and results sections, only article counts are reported. Citation counts by KQ are not unique; studies may contribute to multiple KQ.

b: Not included in individual study counts at the bottom level of the diagram.

c: KQ1 and KQ3: 1 study (1 article article)

d: KQ 2a Accuracy of Clinical Risk Assessment Tools for Identifying Osteoporosis: 38 studies (41 articles); Accuracy of Bone Measurement Tests Used to Identify Low Bone Mass and Osteoporosis: 11 studies (11 articles); Accuracy of Fracture Risk Prediction Instruments: 5 systematic reviews supplemented by 13 studies; Accuracy of Bone Measurement Tests Used to Predict Fracture: 23 studies (24 articles); Calibration of Fracture Risk Prediction Instruments: 14 studies (14 articles); Reclassification Risk: 10 studies (10 articles)

e: KQ 2b: 2 studies (2 articles)

f: KQ 4a: Alendronate: 7 studies (7 articles); Zolendronic Acid: 2 studies (2 articles); Risedronate: 4 4 studies (4 articles); Etidronate: 2 studies (2 articles); Ibandronate: 0 studies; Raloxifine: 1 study (2 articles); Estrogen: 0 studies; Denosumab: 4 studies (5 articles); Parathyroid Hormone: 2 studies (2 articles articles). KQ 4b: 4 studies (5 articles)

g: Alendronate: 16 studies (16 articles); Zolendronic Acid: 4 studies (4 articles); Risedronate: 6 studies (6 articles); Etidronate: 2 studies (2 articles); Ibandronate: 7 studies (7 articles); Raloxifine: 6 studies (12 articles); Estrogen: 0 studies; Denosumab: 4 studies (5 articles); Parathyroid Hormone: 2 studies (2 articles)

FDA= Food and Drug Administration; HDI= human development index; KQ= key question

Abbreviations: FDA=Food and Drug Administration; HDI=human development index; KQ=key question.

2 This figure is a Preferred Reporting of Systematic Reviews and Meta-Analysis (PRISMA) tree showing the flow of articles through the systematic review process. In the identification section of the PRISMA, it shows that after duplicates were removed, 4,969 records were identified through database searching. Additionally, 238 records were identified through other sources. 5,207 records were screened and 4,365 records were excluded. 842 full-text articles were assessed for eligibility and 674 full-text articles were excluded. The reason for exclusion and number of articles excluded is as follows: not original research (23), ineligible population(s) (130), ineligible study design (40), ineligible geographic setting (22), ineligible clinical setting (3), ineligible or no screening/intervention(s) (86), ineligible or no comparator(s) (80), ineligible or no outcome(s) (186), could not obtain the full text article (3), bone measurement occurred after the outcome (19), the screening tool is not commercially available (16), the screening tool is not FDA approved (2), study is not in an externally validated cohort (25), study not conducted in a very high HDI country (11), the study is superseded by new evidence (4), the study was used for hand search only (4), the article was retracted (1), there was insufficient information for abstraction (1), or the study was poor quality (18). There were 168 articles included in the systematic review. 2 articles were publications of the previous review.

### Key Question 1 Does Screening (Clinical Risk Assessment, Bone Density Measurement, or Both) for Osteoporotic Fracture Risk Reduce Fractures and Fracture-Related Morbidity and Mortality in Adults?

We found one eligible study. The Screening for Osteoporosis in Older Women for the Prevention of Fracture (SCOOP) trial randomized 12,483 women ages 70 to 85 years to screening with the FRAX or usual care.^72^ In this fair-quality trial, participants in the intervention arm who were identified as high risk based on FRAX-generated 10-year hip fracture risk were invited to undergo DXA testing. The investigators recalculated the FRAX risk for those who undertook DXA screening and communicated the results to the participant’s general practitioner, who then offered treatment as appropriate.^72^ At 5 years followup, the study found no difference in the primary outcome of any osteoporotic fracture in the intervention arm when compared with the usual care arm (12.9% vs. 13.6%; HR, 0.94; 95% CI, 0.85 to 1.03). The study also did not find any difference in the overall incidence of all clinical fractures (15.3% vs. 16.0%; HR:0.94; 95% CI, 0·86 to 1·03) or mortality (8.8% vs. 8.4%; HR 1.05, 95% CI, 0.93 to 1.19). However, the study reported a statistically significant difference in hip fracture incidence (2.6% vs. 3.5%; HR 0.72; 95% CI, 0.59 to 0.89).

### Key Question 2a What Is the Accuracy and Reliability of Screening Approaches to Identify Adults Who Are at Increased Risk for Osteoporotic Fracture?

This section is organized as follows: evidence on the accuracy of (1) clinical risk assessment tools for identifying osteoporosis, (2) bone measurement tests screening for identifying low bone mass and osteoporosis, (3) fracture risk prediction instruments for predicting fracture, and (4) bone measurement tests for predicting fracture. Each section includes an overview of the evidence, followed by findings. We then discuss calibration of fracture risk prediction instruments and other measures of test performance, specifically, reclassification.

#### Accuracy of Clinical Risk Assessment Tools for Identifying Osteoporosis: Overview of the Evidence

Thirty-eight studies (comprising 41 publications)^56,^ ^57,^ ^77-115^ provide information on the accuracy of 16 clinical risk assessment instruments in identifying osteoporosis (bone mineral density [BMD] T-score ≤−2.5) (summary in Table 3; details in Appendix F Tables 1-5). We restricted inclusion to validated instruments. Studies were conducted in the United States (14 studies), Canada (5 studies), the United Kingdom (2 studies), Australia (2 studies), Republic of Korea (3 studies), Italy (3 studies), Spain (2 studies), Hong Kong (2 studies), Belgium (1 study), Denmark (1 study), Singapore (1 study), Portugal (1 study), and one study conducted data in the United States and Hong Kong. Thirty-seven reported area under the curve (AUC) and 34 reported sensitivity or specificity. A smaller subset reported on positive (19 studies) or negative (17 studies) predictive values. The evidence base is characterized by heterogeneity in included risk factors (ranging from 2 to 17), clinical (19 in clinics, 19 in community settings,) and geographic settings, measurement of osteoporosis (studies measured osteoporosis at spine, total hip, femoral neck, other sites [thoracic vertebra, lumbar vertebra, arms, ribs, or legs], or combinations of sites), thresholds used to calculate sensitivity and specificity, reference ranges, and baseline osteoporosis rates (4.4%110 to 47.4%^88^). Studies on five instruments (Mscore,^112^ Male Osteoporosis Risk Estimation Score (MORES),^85,^ ^110,^ ^114,^ ^115^ Male Osteoporosis Screening Tool (MOST),^97^ Osteoporosis Screening Test [OST], and FRAX^114^) reported results in men-only samples, with OST reported separately in predominantly Asian (Osteoporosis Screening Tool for Asians [OSTA])^96,^ ^98,^ ^104,^ ^105^ and other populations (OST).^77,^ ^97,^ ^98,^ ^108,^ ^111,^ ^112^ One study reported results for men and women for FRAX and OST.^106^ All other studies reported results in women-only samples. Although the range of mean ages in included studies varied from 50.5^109^ to 78.2,^106^ among those reporting a mean age (33 studies), the mean in most studies (22 studies, 67%) ranged between 60 and 70 years.

Table 3 Characteristics and Accuracy of Clinical Risk Assessment Tools in Identifying Osteoporosis

Instrument | Mean Age | Sex | Race/ethnicity | Clinical and Geographic Setting | Components | Pooled AUC (95% CI) or Range of AUCs;^a^ No. of Studies; No. of Participants | Threshold,^b^ Range of Sensitivity; No. of Studies; Participants | Threshold, ^b^ Range of Specificity; No. of Studies; No. of Participants | Threshold, ^b^ Range of Positive Predictive Values; No. of Studies; No. of Participants | Threshold,^b^ Range of Negative Predictive Values; No. of Studies; No. of Participants
ABONE^82,^ ^86^ | 66. to 68.4 | All women | White and Chinese | General population; Canada Singapore | Age, body size, no estrogen use for at least 6 months | Ranges from 0.70 to 0.72 (femoral neck); 2; 2,500 | ≥2: 83.3 (78.5-88.0); 1; 2,365 | ≥2: 47.7 (45.6-49.8); 1; 2,365 | Not reported | Not reported
AMMEB^88,^ ^89^ | 65 | All women | NR | General practices; Italy | Age, BMI, age at menarche, postmenopausal period | Ranges from 0.63 to 0.71; 2; 1,520 | NR | NR | NR | NR
DOEScore^103^ | 70.5 | All women | 98.6% Caucasian; 1.4% Aboriginal (overall cohort, NR for included sample) | Population-based cohort; Dubbo, Australia | Age, body weight, and history of fracture | Any site: 0.75 (95% CI, 0.691 to 0.809); 1; 410 | >10: 82% (NR); 1; 410 | >10: 52% (NR); 1; 410 | NR | >10: 55% (NR); 1; 410
FRAX without BMD for 10-year risk of hip fracure^94^ | 61 | All women | 100% Caucasian | General practice, Spain | Age, race, rheumatoid arthritis, history of prior fracture, medication use, smoking, alcohol intake, and parental history of hip fracture | Any site: 0.82 (NR); 1; 505 | NR | NR | NR | NR
FRAX without BMD for 10-year risk of hip fracure^106^ | 78.2 | 45.1% women | Not reported | General practice; Australia | Age, race, rheumatoid arthritis, history of prior fracture, medication use, smoking, alcohol intake, and parental history of hip fracture | Any site: 0.70 (95% CI, 0.64 to 0.75); 1; 626 | Hip≥3% 92.2 (NR); 1; 626 | Hip≥3% 37.7 (NR); 1; 626 | Hip≥3% 17.1 (NR); 1; 626 | Hip≥3% 97.1 (NR); 1; 626
FRAX without BMD for 10-year risk of major osteoporotic fracure^56,^ ^57,^ ^94,^ ^113^ | 57 to 57.7 | All women | 72% white, 17% black, 8% Hispanic in one study^57^; 97%-100% white in 2 studies;^56,^ ^94^ NR^113^ | General practice; USA, Spain; Population-based cohort, Canada | Age, race, rheumatoid arthritis, history of prior fracture, medication use, smoking, alcohol intake, and parental history of hip fracture | Ranges from 0.58^56^ to 0.82^56^, 2 had thresholds specified as ≥9.3% risk^56,57^ two did not specify^113^; 4; 22,141 | MOF ≥9.3% Ranges from 33.3% to 37%; 2; 3,321 | MOF ≥9.3% Ranges from 74% to 86.4% (85.1-87.7); 2; 3,321 | MOF ≥9.3% 13.7 (10.4-17.0); 1; 2,857 | Not reported
FRAX without BMD for 10-year risk of major osteoporotic fracure^114^ | 64.2 | All men | 88.5% white, 8.5% black, 2.9% Mexican-American | Community-based sample, USA | Age, race, rheumatoid arthritis, history of prior fracture, medication use, smoking, alcohol intake, and parental history of hip fracture | 0.79 (95% CI, 0.74 to 0.84); 1; 1,498 | FRAX MOF risk ≥9.3% 39% (27-51); 1; 1,498 | FRAX MOF risk ≥9.3% 89% (87-91); 1; 1,498 | FRAX MOF risk ≥9.3% 14% (9-20) | FRAX MOF risk ≥9.3% 97% (96-98)
FRAX without BMD for 10-year risk of major osteoporotic fracure^106^ | 78.2 | 45.1% women | Not reported | General practice; Australia | Age, race, rheumatoid arthritis, history of prior fracture, medication use, smoking, alcohol intake, and parental history of hip fracture | Any site: 0.68 (95% CI, 0.63 to 0.74); 1; 626 | MOF≥6.5% 89.6 (NR); 1; 626 | MOF≥6.5% 35 (NR); 1; 626 | MOF≥6.5% 16.8 (NR); 1; 626 | MOF≥6.5% 96.2 (NR); 1; 626
Gnudi et al, 2005^91^ | 64.3 | All women | 100% white | Women requiring a DXA scan at “a center,” Italy | Age at menarche, weight, years since menopause, previous fracture, weight, fracture in subject’s mother, arm help to get up from sitting | Any site: 0.74 (95% CI, 0.70 to 0.79); 1; 478 | Predicted probability of low BMD at 0.132^c^: 95.5%; 1; 478 | Predicted probability of low BMD at 0.132^c^: 27.7%; 1; 478 | Predicted probability of low BMD at 0.132^c^; 0.156 91.2%; 1; 478 | Predicted probability of low BMD at 0.132^c^: 43.9%; 1; 478
Mscore^112^ | 60.9 to 68.4 | All men | Caucasian and African-American subgroups | Clinic-based | 2 models: Age and weight (reduced Mscore) or Age, weight, gastrectomy, COPD, two or more prior fractures (Mscore) | Femoral neck: Age-weight model: Caucasian 0.81 (95% CI, 0.69 to 0.92); 1; 197 African-American^e^ 0.99 (95% CI, 0.98 to 1.01); 1; 134 5-variable model Caucasian 0.84 (95% CI, 0.74 to 0.95); 1; 197 NR for African-American | Age-weight model <9 Caucasian 85%; 1; 197 African-American^e^ 93%; 1; 134 5-variable model<9 Caucasian 88%; 1; 197 NR for African- American | Age-weight model <9 Caucasian 58%; 1; 197 African-American^e^ 79%; 1; 134 5-variable model<9 Caucasian 57%; 1; 197 NR for African- American | Age-weight model <9 Caucasian 18%; 1; 197 African-American^e^ 34%; 1; 134 5-variable model<9 Caucasian 16%; 1; 197 NR for African- American | Age-weight model <9 Caucasian 97%; 1; 197 African-American^e^ 99%; 1; 134 5-variable model<9 Caucasian 98%; 1; 197 NR for African- American
MORES^85,^ ^110,^ ^115^ | 63 to 70.2 | All men | NR | 1 clinic sample, 2 population-based samples | Age, weight, history of COPD | Pooled AUC (total hip or hip in combination with other measures)^d^: 0.80 (95% CI, 0.71 to 0.88); 3; 4,828 | ≥6: 66-95%; 3; 4,828 | ≥6: 61-70%; 3; 4,828 | ≥6 (hip) 10-11%, 2; 1,844 | ≥6 (hip) 99-100%; 2; 1,844
MOST^97^ | 65 and older | All men | 71% Caucasian 29% Chinese | Cohort of community-dwelling, ambulatory men; US and Hong Kong | QUI, body weight | US Any site: 0.80 (95% CI, 0.78 to 0.82), 1; 4,658 Hong Kong Any site: 0.83 (95% CI, 0.80 to 0.86); 1; 1,914 | NR | NR | NR | NR
NOF guidelines^82,^ ^88,^ ^89,^ ^100^ | 57.3 to 69.2 | All women | Predominantly white | Majority of studies general population or general practice; USA Canada Italy | Age, weight, personal history of fracture with minimal trauma >40 years, family history of fracture, current cigarette smoking | Lowest T score: 0.60; 2; 1,520 | ≥1: 96-100% | ≥1: 10-18%; 2; 2,567 | ≥1: 37%; 2; 202 | ≥1: 100%; 2; 202
ORA^79,^ ^80,^ ^82-84,^ ^86-90,^ ^92-94,^ ^99,^ ^100,^ ^103,^ ^109^ | 50.5 to 70.5 | All women | White participants in majority of studies | Half of studies conducted in general practice or population settings Countries: USA Australia Belgium Canada Denmark England Italy Singapore Spain | Age, weight in pounds, current estrogen use | Pooled AUC for any site: 0.65 (95% CI, 0.60 to 0.71); 10;16,780 | ≥9: 50-100%; 9; 7,830 | ≥9: 10-75%; 9 7,830 | ≥9: 20-98%; 4; 3,079 | ≥9: 25-94%; 4; 3,079
OSIRIS^72,^ ^80,^ ^87,^ ^93,^ ^94,^ ^99^ | 54.1 to 61.5 | All women | Predominantly Causasian | All clinic-based, all in Europe | Age, weight, HRT use, history of low trauma fracture | Pooled AUC (any site): 0.68 (95% CI 0.64 to 0.72) 5; 5,649 | <1: 64%; 1; 4,035 | <1: 69%; 1; 4,035 | <1: 50%; 2; 2,701 | <1: 80%; 2; 2,701
OST^77,^ ^97,^ ^98,^ ^108,^ ^111,^ ^112^ | 64 to 68 | All men | Predominantly Caucasian | 4 clinic-based, 2 community-based; 5 in US and 1 in Portugal | Age and weight | Pooled AUC (any site or femoral neck): 0.76 (95%CI, 0.71 to 0.80); 6; 7798 | <2: 61.8% to 87.6%; 5; 5,366 | <2: 36.1 to 74%; 5; 5,366 | <2: 9.7 to 38%; 5; 5,366 | <2: 89.2 to 9%; 5; 5,366
OST^57,^ ^83,^ ^87-90,^ ^92-94,^ ^99,^ ^101,^ ^102,^ ^72,^ ^80,^ ^109,^ ^113^ | 51 to 62 | All women | Predominantly Caucasian | 9 clinic-based and 6 community based; 3 in US, 4 in Canada, 8 in Northern/Western Europe | Age and weight | Pooled AUC (any site): 0.65 (95% CI, 0.60 to 0.69); 13; 44,323; without outlier,^88,^ ^89^ pooled AUC: 0.71, 95% CI, 0.70 to 0.72; 11; 42,802 | <2: 69% to 95.3% 7 studies; 11,486 participants | <2: 34% to 71%; 11; 42,802 | <2: 2% to 41%; 4; 9,566 | <2: 86% to 100%; 3; 6,709
OST^106^ | 78 | 45.1% men | Predominantly Caucasian | Clinic-based, Australia | Age and weight | Any site: 0.76 (95% CI, 0.71 to 0.82); 1; 626 | ≤0: 90.9% | ≤0: 39.9% | ≤0: 17.5% | ≤0: 96.9%
OSTA^96,^ ^98,^ ^104^ | 63.4 to 54 | All men | Asian | Community-based, Hong Kong and S. Korea | Age and weight | Any site: AUCs range from 0.627 to 0.72; 2; 1,911 | Varies by study, no common cutoff | Varies by study, no common cutoff | Varies by study, no common cutoff | Varies by study, no common cutoff
OSTA^86,^ ^89,^ ^95,^ ^103,^ ^104,^ ^107^ | 59.1 to 70.5 | All women | Caucasian and Asian | 1 clinic-based and 4 community-based studies; Australia, Singapore, Hong Kong, South Korea | Age and weight | Pooled AUC: 0.76 (95% CI, 0.63 to 0.90); 4; 2,962 | ≤-1: 41% to 97%; 5; 3,414 | ≤-1: 24% to 67.1%; 5; 3,414 | ≤-1: 24% to 49.4%; 3; 2,557 | ≤-1: 87% to 98%; 2; 2,147
SCORE^57,^ ^79-82,^ ^84,^ ^86,^ ^87,^ ^90,^ ^93,^ ^94,^ ^100,^ ^109^ | 57.7 to 69.2 | All women | Predominantly white | 4 clinic-based, 7 community-based US: 4; UK: 2; Spain: 1; Singapore: 1; Belgium: 1; Denmark: 1; Canada: 1 | Age, weight, and estrogen replacement therapy, the SCORE instrument includes race/ethnicity, history of rheumatoid arthritis, and history of nontraumatic fractures after age 45 | Pooled AUC (any site): 0.70 (95% CI, 0.69 to 0.71); 8; 15,362 | ≥6: 54% to 100%; 6; 7,455 | ≥6: 17.9% to 72%; 6; 7,455 | ≥6: 89.1% to 100%; 3; 4,440 | ≥6: 19% to 41%; 3 studies; 4,440
SOF^81^ | 69.3 | All women | 93.5% white | OPRA study, Group Health participant; US | Prior fracture after age 50; age 60-64 with t-score <-2.5 or age 65 or older with z-score <-0.43; and 5 or more risk factors (first-degree relative with hip fracture, current weight less than at age 25, dementia, using corticosteroids or seizure medication or benzodiazepines, had a fracture age 50+, not taking HRT, on feet <4 h/day, heart rate >80 beats/min, was >5′7 at age 25, 80+ years old; subtract 1 point each for race (African American); walk for exercise; can rise from chair without arms | Any site: 0.54 (SE 0.03); 1; 416 | ≥ 5: 32.6 (26.6, 38.6); 1; 416 | ≥ 5: 76.0 (63.5, 88.6); 1; 416 | NR | NR
SOFSURF^87,^ ^90,^ ^103^ | 59.7 to 70.5 | All women | Mostly white | Population-based cohort; Dubbo, Australia Scanning clinics; UK | Age, weight, smoking and history of postmenopausal fracture | NR in 2 studies;^90,^ ^103^ Any site: 0.717 (95% CI, 0.777 to 0.670); 1; 208^87^ | Varies by study, no common cutoff | Varies by study, no common cutoff | Varies by study, no common cutoff | Varies by study, no common cutoff

a Presented for any site when available (femoral neck, lumbar spine, total hip); if not available, presented for femoral neck.

b Sensitivity, specificity, NPV, and PPV presented for the most commonly reported threshold across studies.

c Study presents multiple predicted probabilities of low BMD; the study notes that the threshold offered the highest number of DXA-deferred cases and the lowest number of low-BMD missed cases.

d Studies present results for three different sites of BMD measurement: total hip,^110^ total hip or femoral neck,^85^ or thoracic vertebra, lumbar vertebra, arms, ribs, pelvis, or legs.^115^

e The African-American sample includes data from 95 new subjects and 39 subjects from development cohort and is therefore not a pure validation cohort.

Abbreviations: ABONE=assessing age, body size, and estrogen use; AMMEB=Age, years after Menopause, age at MEnarche, Body mass index; AUC=area under the curve; BMD=bone mineral density; BMI=body mass index; CI=confidence interval; COPD=chronic obstructive pulmonary disease; DOEScore=Dubbo Osteoporosis Epidemiology Score; DXA=Dual-energy X-ray absorptiometry; FN=Femoral neck; FRAX=Fracture Risk Assessment tool; HRT=hormone replacement therapy; MOF=Melton Osteoporotic Fracture study; MORE=Multiple Outcomes of Raloxifene T rial; MOST=Male Osteoporosis Screening Tool; NOF=National Osteoporosis Foundation; NR=not reported; OPRA=osteoporosis population-based risk assessment; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=Osteoporosis Index of Risk; OST=osteoporosis self-assessment tool; OSTA=Osteoporosis Self-assessment Tool for Asians; QUI=ultrasound index; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; SE=standard error; SOF=Study of Osteoporotic Fractures; SOFSURF=Study of Osteoporotic Fractures Simple Useful Risk Factors; UK=United Kingdom; US=United States; USA=United States of America.

#### Accuracy of Clinical Risk Assessment Instruments in Identifying Osteoporosis: Findings

##### Overall Findings

As in the previous update, we found a wide range of AUCs (Table 3). When possible, we pooled AUCs for instruments reporting results from three or more populations (Appendix H Figures 1 7). With the exception of one meta-analysis, all demonstrated high I^2^ (>83%), suggesting that the variability between studies can be explained by heterogeneity rather than chance. Pooled estimates of AUCs ranged from 0.65 (Osteoporosis Risk Assessment Instrument [ORAI]; 10 studies; 16,780 participants) to 0.76 (Osteoporosis Self-Assessment Tool for Asians [OSTA]; four studies; 2,962 participants) in women. AUCs from individual studies have a wider range from 0.32^88^ to 0.873^107^. AUCs appear to be higher in studies recruiting men, ranging from 0.62^98^ to 0.89.^111^ The pooled estimate for OST is 0.76 (seven studies; 7,798 participants) and for MORES is 0.80 (three studies; 4,828 participants). Instruments with more risk factors do not report higher AUCs than instruments with fewer risk factors.

##### Findings in Younger Women

We also evaluated the accuracy of clinical risk assessment instruments in younger women, drawing on studies of populations under age 65 years, subgroup analysis of those under age 65 years, and studies with a mean age under 60 years.

FRAX. Three studies of younger women (<65 years) evaluated the accuracy of FRAX in identifying major osteoporotic fractures.^56,^ ^57,^ ^113^ Of these, two specified the USPSTF recommended threshold of 9.3 percent for a 10-year risk of major osteoporotic fractures^56,^ ^57^ and one did not.^113^ AUCs range from 0.58 to 0.67. As noted previously in Chapter 1, one of these studies also compared the accuracy of FRAX with those of other instruments (OST and SCORE) and found that that the FRAX threshold of ≥9.3 percent was modestly better than chance, and inferior to OST and SCORE in identifying women with osteoporosis (femoral neck T-score ≤−2.5).^57^

OST. Five studies evaluated the performance of OST in women (three in populations under age 65 years,^57,^ ^102,^ ^113^ one in a subgroup of women under age 65 years,^79^ and one in a population ranging from ages 40 to 69 years, with a mean age of 54.2 years^99^). AUCs ranged from 0.64^99^ to 0.77.^79,^ ^102^

SCORE. Four studies reported on the performance of SCORE in younger women (one in a population under age 65 years,^57^ two in subgroup analyses of women younger than 65 years of age,^79,^ ^100^ and one in a population with a mean age of 50.5.^109^ AUCs ranged from 0.68^109^ to 0.85.^100^

ORAI. Four studies reported on the performance of SCORE in younger women (two in subgroup analyses of women younger than 65 years of age,^79,^ ^100^ and two in population with mean ages of 50.5^109^ and 54.2 years,^99^ respectively. AUCs ranged from 0.6299 to 0.82.^100^

Other instruments. Two studies reported on the performance of the NOF guidelines and OSIRIS and reported AUCs of 0.69^100^ and 0.63^99^ respectively.

Appendix F Tables 1-7 provides additional details on sensitivity, specificity, positive predictive value (PPV), and negative predictive value (NPV). As noted above, fewer studies reported these statistics than AUCs. Reported thresholds varied considerably within instruments; we present ranges for the most commonly reported threshold. Even with a common threshold, results varied widely; as an example, for the ORAI instrument, sensitivity ranged from 50 percent to 100 percent, specificity from 10 percent to 75 percent, PPV from 20 percent to 98 percent, and NPV from 25 percent to 94 percent. These wide ranges reflect the underlying heterogeneity described above.

#### Accuracy of Bone Measurement Tests Used to Identify Low Bone Mass and Osteoporosis: Overview of the Evidence

Eleven studies provide information on the accuracy of bone measurement tests for screening for low bone mass or osteoporosis (summary in Table 4; details in Appendix F Table 6). Of these, five are new inclusions^94-96,^ ^101,^ ^116^ and six^87,^ ^93,^ ^97,^ ^111,^ ^117,^ ^118^ were previously described in the 2010 review.^3^ The previous review also relied on a systematic review that found a pooled AUC of 0.76 (95% CI, 0.72 to 0.79) overall, and specifically for postmenopausal women, 0.75 (95% CI, 0.66 to 0.82).^119,^ ^120^

Table 4 Characteristics and Accuracy of Machine-Based Tests in Identifying Osteoporosis

Imaging Test | Site of Test | Sex | Age Range (Years) | Gold Standard Test | Site of Gold Standard | Number of Studies | Number of Participants | Summary of Accuracy
QUS | Calcaneus | Women | Mean age ranges from 59-63 | DXA ≤-2.5 | Lumbar spine, femoral, or total hip | 7^87,^ ^93,^ ^95,^ ^101,^ ^116-118^ | 1,969 | AUCs range from 0.69 to 0.898, pooled estimate: 0.77 (95% CI, 0.72 to 0.81)
QUS | Calcaneus | Men | Mean age ranges from 61-63 | DXA ≤-2.5 | Lumbar spine, femoral, or total hip | 3^96,^ ^97,^ ^111^ | 5,142 | AUCs vary from 0.696 to 0.93, pooled estimate: 0.80 (95% CI, 0.67 to 0.94)
Peripheral DXA | Calcaneus | Women | 61 (SD ranges from 4 to 8) | DXA | Lumbar spine, femoral, or total hip | 2^93,^ ^94^ | 712 | AUC ranges from 0.67 to 0.803 (variance NR)
DXR | Nondominant metacarpals | Women | 61 (range 50-75) | DXA | Lumbar spine or total hip | 1^116^ | 221 | AUC: 0.84 (95% CI, 0.79 to 0.89)
RA | Nondominant phalanges | Women | 61 (range 50-75) | DXA | Lumbar spine or total hip | 1^116^ | 221 | AUC: 0.80 (95% CI, 0.74 to 0.85)

Abbreviations: AUC=area under the curve; CI=confidence interval; DXA=dual energy X-ray absorptiometry; DXR=digital X-ray radiogrammetry; NR=not reported; QUS=quantitative ultrasound; RA=radiographic absorptiometry; SD=standard deviation; SE=standard error.

Seven of 11 studies included fewer than 250 patients.^87,^ ^93,^ ^101,^ ^111,^ ^116-118^ Three studies, including the largest (N=6,572)^97^ focused on men in the United States,^111^ Hong Kong,^96^ or both countries.^97^ Studies of women were set in Belgium,^116,^ ^118^ Hong Kong,^95^ Spain,^94^ Canada,^101^ and the United Kingdom.^87,^ ^93,^ ^117^ Studies varied widely in the degree of restrictiveness of participant inclusion and exclusion. Two studies reported no exclusion criteria.^87,^ ^101^ In contrast, two studies set in Hong Kong reported an extensive list of inclusion and exclusion criteria.^95,^ ^96^ All we re of low or unclear risk of bias.

Studies evaluated quantitative ultrasound (QUS),^87,^ ^93,^ ^95-97,^ ^101,^ ^111,^ ^116,^ ^117^ peripheral DXA,^93,^ ^94^ digital X-ray absorptiometry (DXR),^116^ and radiographic absorptiometry.^116^ No studies on vertebral fracture assessment or dental tests met our inclusion criteria.

#### Accuracy of Bone Measurement Tests Used to Identify Low Bone Mass and Osteoporosis: Findings

Studies in women focusing on comparisons of calcaneal QUS against a centrally measured DXA BMD T-score cutoff of -2.5 or less reported AUCs varying from 0.69 (N=202, Belgium) to 0.90 (N=174, Canada). For women, seven studies of 1,969 women yielded a pooled estimate of 0.77 for the AUC (95% CI, 0.72 to 0.81, I^2^=82.1%) (Appendix H Figure 8). We were unable to replicate reported confidence intervals in three studies,^87,^ ^101,^ ^117^ and used our estimate, based on reported populations and AUCs. Sensitivity analysis without these three studies yielded similar results (AUC, 0.74; 95% CI, 0.70 to 0.78; I^2^:65%; 4 studies, N=1352). Studies in women also reported on the use of peripheral DXA, with AUC ranging from 0.67 to 0.80;^93,^ ^94^ DXR with an AUC of 0.84 (95% CI, 0.79 to 0.89);^116^ and radiographic absorptiometry with an AUC of 0.80 (95% CI, 0.74 to 0.85).^116^

All studies in men focused on comparisons of calcaneal QUS to a centrally-measured DXA BMD T-score cutoff of -2.5 or less.^96,^ ^97,^ ^111^ AUC estimates ranged from 0.70 (N=4,658 Caucasian men in the United States) to 0.93 (N=128 African American men). For all men in the three studies (N=5,142), the pooled AUC estimate was 0.80 (95% CI, 0.67 to 0.94; I^2^, 98%) (Appendix H Figure 9).

#### Accuracy of Fracture Risk Prediction Instruments: Overview

We identified five systematic reviews^75,^ ^76,^ ^119,^ ^121,^ ^122^ addressing the accuracy of tools to predict fracture in adults. Our synthesis is based on the good-quality Marques et al systematic review^76^ supplemented by 13 eligible observational studies with low risk of bias or unclear bias not included in the Marques et al review (summary in Table 6; details in Appendix F Table 8)^58,^ ^102,^ ^123-133^ The Marques et al review used a search through late 2014, and selected studies for inclusion based on similar criteria to our review and consistent with the previous evidence review in support of this USPSTF recommendation.^3^

Table 6 Summary Of Imaging Tests Predicting Fracture

Imaging Test | Type of Incident Fracture | Site of Test | Sex | Age Range at Baseline (Years) | Number of Studies | Number of Participants | Summary of Accuracy (AUC)
DXA/DXA aBMD | Any osteoporotic or nonspine | Lumbar spine | Women | 44-95 | 3^162,^ ^165,^ ^166,^ ^144^ | 33,839 | Unadjusted: 0.64-0.77 Adjusted: 0.66^a^
DXA/DXA aBMD | Any osteoporotic or nonspine | Lumbar spine | Men | 65-≥75 | 1^167^ | 1,921 | Adjusted: 0.71^b^
DXA/DXA aBMD | Any osteoporotic or nonspine | Total hip | Women | 46-95 | 2^165,^ ^166,^ ^173^ | 29,963 | Unadjusted: 0.66-0.68
DXA/DXA aBMD | Any osteoporotic or nonspine | Total hip | Men | 65-≥75 | 1^167^ | 1,921 | Adjusted: 0.72^b^
DXA/DXA aBMD | Any osteoporotic or nonspine | Femoral neck | Women | 40-95 | 10^144,^ ^154,^ ^162,^ ^165,^ ^166,^ ^168,^ ^171,^ ^172,^ ^175-177^ | 41,294 | Unadjusted: 0.59-0.76 Unadjusted by baseline T-score range: -1: 0.54, ≤ -1 > -2.5: 0.57, ≤ -2.5: 0.63 Adjusted 64^a^-0.71^c^
DXA/DXA aBMD | Any osteoporotic or nonspine | Femoral neck | Men | 60-≥75 | 3^163^ ^167,^ ^168^ | 7,972 | Unadjusted: 0.68 Adjusted: 0.71^c^-0.72^b^
DXA/DXA aBMD | Any osteoporotic or nonspine | Femoral neck | Combined | ≥50 | 2^147,^ ^148^ | 46,300 | Unadjusted: 0.66-0.68
DXA/DXA aBMD | Any osteoporotic or nonspine | Middle phalanges | Women | 40-90 | 2^133,^ ^174^ | 12,830 | Unadjusted: 0.71 Adjusted: 0.68^d^
DXA/DXA aBMD | Any osteoporotic or nonspine | Middle phalanges | Men | 40-90 | 1^174^ | 5,206 | Unadjusted: 0.64
DXA/DXA aBMD | Vertebral, spine | Thoracolumbar vertebra, spine | Women | 50-95 | 3^164-166,^ ^169^ | 30,837 | Unadjusted: 0.61-0.69
DXA/DXA aBMD | Vertebral, spine | Total hip | Women | 50-95 | 2^165,^ ^166,^ ^168^ | 29,861 | Unadjusted: 0.71 Adjusted: 0.77^c^
DXA/DXA aBMD | Vertebral, spine | Femoral neck | Women | 50-95 | 2^165,^ ^166,^ ^168^ | 29,861 | Unadjusted: 0.71 Adjusted: 0.70^c^
DXA/DXA aBMD | Vertebral, spine | Femoral neck | Men | ≥60 | 1^168^ | 445 | Adjusted: 0.75^c^
DXA/DXA aBMD | Hip | Thoracolumbar vertebra, spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.65
DXA/DXA aBMD | Hip | Total hip | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.81
DXA/DXA aBMD | Hip | Total hip | Men | ≥60 | 1^168^ | 445 | Adjusted: 0.77^c^
DXA/DXA aBMD | Hip | Femoral neck | Women | 40-95 | 7^165,^ ^166,^ ^168,^ ^170^ ^171,^ ^176,177^ | 38,322 | Unadjusted: 0.64-0.86 Adjusted: 0.75^d^
DXA/DXA aBMD | Hip | Femoral neck | Men | ≥65 | 1^163^ | 5,606 | Unadjusted: 0.85
DXA/DXA aBMD | Hip | Femoral neck | Combined | ≥50 | 2^147,^ ^148^ | 46,300 | Unadjusted: 0.76-0.80
DXA/DXA aBMD | Hip | Middle phalanges | Women | 40-90 | 2^174^ | 12,830 | Unadjusted: 0.83
DXA/DXA aBMD | Hip | Middle phalanges | Men | 40-90 | 1^174^ | 5,206 | Unadjusted: 0.64
DXA TBS | Any osteoporotic | Spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.63
DXA TBS | Vertebral, spine | Thoracolumbar vertebra, spine | Women | 53-61; 50-95 | 2^164-166^ | 30,072 | Unadjusted: 0.66-0.68
DXA TBS | Hip | Spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.68
| Any osteoporotic | Spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.66
| Any osteoporotic | DXA BMD total hip + TBS spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.69
DXA aBMD & TBS | | DXA BMD femoral neck + TBS spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.69
DXA aBMD & TBS | Vertebral, spine | Thoracolumbar vertebra, spine | Women | 53-61; 50-95 | 2^164-166^ | 30,072 | Unadjusted: 0.70-0.71 Adjusted: 0.72^d^-0.73^e^
DXA aBMD & TBS | Vertebral, spine | DXA BMD total hip + TBS spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.73
DXA aBMD & TBS | Vertebral, spine | DXA BMD femoral neck + TBS spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.73
DXA aBMD & TBS | Hip | Spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.69
DXA aBMD & TBS | Hip | DXA BMD total hip + TBS spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.82
DXA aBMD & TBS | Hip | DXA BMD femoral neck + TBS spine | Women | 50-95 | 1^165,^ ^166^ | 29,407 | Unadjusted: 0.81
QUS (BUA) | Any osteoporotic | Heel | Women | 44-56 | 1^162^ | 775 | Adjusted: 0.72^a^
QUS (BUA) | Any osteoporotic | Heel | Men | 65-≥75; ≥65 | 2^163,^ ^167^ | 1,921 + 5,606 | Unadjusted: 0.68 Adjusted: 0.65^b^
QUS (BUA) | Hip | Heel | Men | ≥65 | 1^163^ | 5,606 | Unadjusted: 0.84
QUS (SOS) | Any osteoporotic | Heel | Men | 65-≥75 | 1^167^ | 1,921 | Adjusted: 0.64^b^
QUS (QUI) | Any osteoporotic or nonspine | Heel | Men | 65-≥75 | 1^167^ | 1,921 | Adjusted: 0.66^b^
QUS (BUA) & DXA BMD | Any osteoporotic or nonspine | QUS: Heel DXA: Femoral neck | Women | ≥60 | 1^168^ | 454 | Adjusted: 0.73^c^
QUS (BUA) & DXA BMD | Any osteoporotic or nonspine | QUS: Heel DXA: Femoral neck | Men | ≥65; ≥60 | 2^163,^ ^168^ | 5,606 | Unadjusted: 0.69 Adjusted: 0.71^c^
QUS (BUA) & DXA BMD | Vertebral | QUS: Heel DXA: Femoral neck | Women | ≥60 | 1^168^ | 454 | Adjusted: 0.72^c^
QUS (BUA) & DXA BMD | Vertebral | QUS: Heel DXA: Femoral neck | Men | ≥60 | 1^168^ | 445 | Adjusted: 0.75^c^
QUS (BUA) & DXA BMD | Hip | QUS: Heel DXA: Femoral neck | Women | ≥60 | 1^168^ | 454 | Adjusted: 0.81^c^
QUS (BUA) & DXA BMD | Hip | QUS: Heel DXA: Femoral neck | Men | ≥65; ≥60 | 2^163,^ ^168^ | 5,606 + 445 | Unadjusted: 0.85 Adjusted: 0.78^c^

a Adjusted for age, height, weight, menopausal status, neck BMD (QUS only).

b Adjusted for age and fracture history.

c Adjusted for age, falls, and fracture history.

d Adjusted for age.

e Adjusted for age and prevalent vertebral deformity.

Abbreviations: aBMD=areal bone mineral density; AUC=area under the curve; BUA=broadband ultrasound attenuation; DXA=dual-energy X-ray absorptiometry; DXL=dual X-ray and laser; QUI=quantitative ultrasound index (combines BUA and SOS); QUS=quantitative ultrasound measured at the calcaneus in all studies; SOS=speed of sound; TBS=trabecular bone score.

Marques et al included 45 articles that assessed 13 different risk prediction instruments; of these, 10 had been evaluated by only one or two studies. The three risk prediction tools evaluated by three or more studies and for which a quantitative synthesis was performed included FRAX (k=26), the Garvan Fracture Risk Calculator (FRC) (k=6), and the QFracture prediction tool (k=4).

Marques et al identified other fracture risk prediction instruments, but studies on these instruments reported no measures of discrimination (e.g., AUC, sensitivity, specificity) for populations external to the development cohort. This includes the Cummings Risk Score,^134^ Fracture and Mortality Index,^135,^ ^136^ a simple clinical score,^137^ and simplified system for fracture risk assessment.^138^ Of the studies that we identified as eligible that had not been included in the Marques et al review, four studies were published after the Marques et al search dates,^58,^ ^124,^ ^129,^ ^133^ and nine were studies we identified as eligible but were either not identified or not included by Marques et al^102,^ ^123,^ ^125-128,^ ^130-132^ These additional studies reported on FRAX, Garvan FRC, and QFracture in addition to five risk instruments not reported in Marques et al The evidence tables for studies we identified are in Appendix F; these tables do not contain the studies that were included in the Marques et al review.

In updating the Marques et al meta-analysis, we identified one study^139^ included in the original pooled AUC estimate that was not from an external validation population, and one study^140^ that used a cross-sectional design, which has a high risk of bias for risk prediction. We have excluded these two studies from this update. The previous review^3^ included several studies not included in this update. Two studies evaluating risk prediction instruments used cross-sectional designs. This includes a study^141^ assessing age, body size, and estrogen use, ORAI, and body weight as risk prediction instruments, and a study^142^ assessing FRAX and Garvan FRC. Three studies^143-145^ of clinical risk scoring algorithms, the Dubbo Osteoporosis Epidemiology Score, the Established Populations for the Epidemiologic Study of the Elderly, and the Fracture Index did not report outcomes for an external validation population. One study^146^ evaluated a risk prediction model focused exclusively on risk prediction in nursing home residents using the Minimum Data Set.

#### Accuracy of Fracture Risk Prediction Instruments: Discrimination Findings

In Table 5 we characterize and report the accuracy of fracture risk prediction at 10 years for 11 instruments as measured by the AUC measure of discrimination. These findings are stratified by sex, site of fracture, and whether BMD was used in the risk prediction. Where possible, we pool AUCs. The rest of this section details findings by risk prediction instrument.

Table 5 Characteristics and Accuracy of Fracture Risk Prediction Models in Predicting Fracture^a^

Risk Prediction Tool | Risks Included | Bone Tests Included | Sex | Age Range (Years) | Prediction Time (Years) | AUC without BMD^b^ | AUC with BMD^b^ | Countries Covered by Included Studies
FRAX^®c^,^32^ | Age, sex, weight, height, previous fracture, parental hip fracture, current smoking, glucocorticoid steroid use, rheumatoid arthritis, secondary osteoporosis, alcohol use | Hip BMD^d^ optional | Men and women | 40 to 90 | 10^c^ | [underlined: Men] MOF: 0.62 (95% CI, 0.61 to 0.64, I^2^=40.5%, 3 studies, 13,970 men)^123,^ ^174,^ ^338^ Hip: 0.73 (95% CI, 0.68 to 0.77, I^2^=96.7%, 3 studies, 13,970 men)^123,^ ^174,^ ^338^ [underlined: Women] MOF: 0.67 (95% CI, 0.65 to 0.68, I^2^=99.2%, 17 studies, 158,897 women)^58,^ ^123-126,^ ^128,^ ^133,^ ^171-174,^ ^176-178,^ ^184,^ ^339,^ ^340^ Hip: 0.76 (95% CI, 0.72 to 0.81, I^2^=99.8%, 12 studies, 190,795 women)^123,^ ^125,^ ^133,^ ^170,^ ^171,^ ^174,^ ^176-178,^ ^184,^ ^187,^ ^340^ [underlined: Both Sexes] MOF: 0.67 (95% CI, 0.66 to 0.67, I^2^=47.1%, 3 studies, 66,777)^127,^ ^147,^ ^148^ Hip: 0.77 (95% CI, 0.73 to 0.79, 6,697 participants)^147^ 0.79 (95% CI, 0.78 to 0.82, 39,603 participants)^148^ | [underlined: Men] MOF: 0.67 (95% CI, 0.66 to 0.68, I^2^=0%, 4 studies, 15,842 men)^123,^ ^132,^ ^174,^ ^338^ Hip: 0.76 (95% CI, 0.72 to 0.80, I^2^=96.7%, 3 studies, 13,970 men)^123,^ ^174,^ ^338^ [underlined: Women] MOF: 0.70 (95% CI, 0.68 to 0.71, I^2^=92.1%, 12 studies, 62,054 women)^123-126,^ ^171,^ ^172,^ ^174-178,^ ^339^ Hip: 0.79 (95% CI, 0.76 to 0.81, I^2^=99.1%, 10 studies, 161,984 women)^123-125,^ ^170,^ ^171,^ ^174,^ ^176-178,^ ^187^ [underlined: Both Sexes] MOF: 0.69 (95% CI, 0.69 to 0.70, I^2^=70.3%, 3 studies, 66,777)^127,^ ^147,^ ^148^ Hip: 0.80 (95% CI, 0.77 to 0.83, 6,697 participants)^147^ 0.83 (95% CI, 0.82 to 0.85, 39,603 participants)^148^ | [underlined: Men] Canada, Denmark, U.S., Japan [underlined: Women] Australia, Canada, Denmark (2), Finland, France (2), Hong Kong, Japan, Multinational European and U.S. Cohort, Netherlands, New Zealand, Spain (3), U.S. (4) [underlined: Both Sexes] Canada (3)
Garvan nomogram/ FRC^139^ | Age, sex, weight, previous nontraumatic fracture since age 50, fall within past 12 months | Hip BMD^e^ optional^f^ | Men and Women | 60 to 96 | 10^g^ | [underlined: Men] Hip: 0.65 (95% CI, NR, 1,285 men)^129^ Nonvertebral: 0.61 (95% CI, NR, 1,355 men)^129^ [underlined: Women] MOF: 0.66 (95% CI, 0.61 to 0.72, 600 women)^126^ Any OF: 0.65 (95% CI, NR, 506 women)^124^ Hip: 0.68 (95% CI, NR, 1,369 women)^129^ Nonvertebral: 0.58 (95% CI, NR, 1,637 women)^129^ | [underlined: Men] MOF^h^: 0.70 (95% CI, NR, 1,606 men)^149^ Hip^h^: 0.79 (95% CI, NR, 1,346 men)^129^ 0.85 (95% CI, NR, 1,606 men)^149^ Nonvertebral: 0.67 (95% CI, NR, 1,346 men)^129^ [underlined: Women] MOF^h^: 0.68 (95% CI, 0.64 to 0.71, I^2^=84.8%, 3 studies,^126,^ ^149^ ^171^ 6,174 women) Any OF: 0.69 (95% CI, NR, 506 women)^124^ Hip^h^: 0.73 (95% CI, 0.66 to 0.79, I^2^=97.3%, 4 studies,^124,^ ^129^ ^149,^ ^171^ 7,449 women) Nonvertebral: 0.62 (95% CI, NR, 1,646 women)^129^ | [underlined: Men] Canada, Norway [underlined: Women] Australia, Canada, Netherlands, New Zealand, Norway
QFracture^150^ | Age, sex, weight, height, smoking, parental fracture or osteoporosis, previous fall, glucocorticoid steroid use, rheumatoid arthritis, alcohol use, hormone replacement therapy^i^, asthma, endrocrine disease, cardiovascular disease, menopausal symptoms^i^, malapsorptive gastrointestinal disease, liver disease, type II diabetes, tricyclic antidepressant use (or other antidepressant use^j^), ethnicity^j^, previous fracture^j^, dementia^j^, kidney disease^j^, epilepsy^j^, Parkinson’s disease^j^, living in a nursing home^j^, COPD^i^, cancer^j^, lupus^j^, anti-convulsant use^j^, type I diabetes^j^ | None | Men and women | 30 to 85^k^ | 1 to 10 | 2009 version of instrument: [underlined: Men] MOF^i^: 0.69 (95% CI, 0.68 to 0.69, 633.764 men)^150^ 0.74 (95% CI, NR, 1,108,219 men)^341^ Hip: 0.86 (95% CI, 0.85 to 0.86, 633.764 men)^76,^ ^150^ 0.86 (95% CI, NR, 1.108.219 men)^341^ [underlined: Women] MOF^l^: 0.79 (95% CI, 0.79 to 0.79, 642.153 women)^76^ ^150^ 0.82 (95% CI, NR, 1,136,417 women)^341^ Hip: 0.89 (95% CI, 0.89 to 0.89, 642.153 women)^150^ 0.89 (95% CI, NR, 1.136.417 women)^76,^ ^341^ 2012 version of instrument: [underlined: Men] MOF^l^: 0.71 (95% CI, 0.70 to 0.72, 778,810 men)^130^ Hip: 0.88 (95% CI, 0.87 to 0.88, 778.810 men)^130^ [underlined: Women] MOF^I^: 0.79 (95% CI, 0.79 to 0.79, 804.563 women)^130^ Hip: 0.89 (95% CI, 0.89 to 0.90, 804.563 women)^130^ | NA | [underlined: Men and Women] France, U.K. [underlined: Men and Women] U.K.
WH^151^ | Age, weight, height, self-reported health, previous fracture after age 55, race/ethnicity, physical activity, smoking, parental hip fracture after age 40, diabetes treated with medications, glucocorticoid steroid use | Hip BMD optional ^m^ | Women | 50 to 79 | 5 | Hip: 0.80 (95% CI, 0.77 to 0.82, 10,750 women)^151^ 0.82 (95% CI, NR, 13,353 women)^160^ | Hip: 0.80 (95% CI, 0.75 to 0.85, 10,750 women)^151^ | Denmark, U.S.
OST^152^ | Age, weight (score calculated as 0.2 X [weight in kg-age]) | None | Women | 45 to 88 | NA^n^ | MOF (3-year risk): 0.56 (95% CI, 0.52 to 0.60, 8,254 women)^102^ 0.71 (95% CI, 0.68 to 0.75, 3,614 women)^128^ MOF (10-year risk): 0.52 (95% CI, 0.52 to 0.53, 62,492 women)^58^ | NA | Canada, Denmark, U.S.
SCORE^153^ | Age, weight, race, rheumatoid arthritis, prior nontraumatic fracture, prior estrogen use | None | Women | 45 and older | NA^n^ | MOF (10-year risk):0.53 (95% CI, 0.53 to 0.54, 62,492 women)^58^ MOF (3-year risk): 0.70 (95% CI, 0.66 to 0.74, 3,614 women)^128^ | NA | Denmark, U.S.
FRISC^154^ | Age, weight, menopausal status, secondary osteoporosis, prior fracture, back pain, dementia | Lumbar BMD | Women | 40 to 79 | 1, 3, 5 or 10 | NA | MOF: 0.73 (95% CI, NR, 400 women)^154^ Long bone and vertebral fracture^o^: 0.69 (95% CI, 0.64 to 0.73, 765 women)^169^ | Japan (2)
FRISK^155^ | Age, weight, height, prior fracture, prior falls | Lumbar and Hip BMD, optional | Women | 60 and older | 5 or 10 | MOF: 0.62 (95% CI, 0.56 to 0.67, 600 women)^126,^ ^155^ | MOF: 0.66 (0.60 to 0.71, 600 women)^126^ | Australia
FRC^156^ | Age, sex, BMI, prior fracture, parental fracture, smoking, alcohol use, glucocortico-steroid use, rheumatoid arthritis, secondary osteoporosis, race/ethnicity | BMD^p^ optional | Men and women^q^ | 45 to 75 | 10^q^ | MOF: 0.66 (95% CI, NR, 893 men)^191^ Hip: 0.71 (95% CI, NR, 893 men)^191^ Hip: 0.83 (95% CI, 0.82 to 0.84, 94,489 women)^159^ | MOF: 0.70 (95% CI, NR, 893 men)^191^ Hip: 0.79 (95% CI, NR, 893 men)^191^ Hip: 0.85 (95% CI, 0.84 to 0.86, 94,489 women)^159^ | U.S. (2)
ORAI^157^ | Age, weight, current estrogen use | No | Women | 45 or older | NA^n^ | MOF (3-year risk): 0.71 (95% CI, 0.68 to 0.75, 3,614 women)^128^ Any OF (3-year risk): 0.69 (95% CI, 0.66 to 0.72, 3,614 women)^128^ | NA | Denmark
OSIRIS^158^ | Age, weight, current hormone therapy use, prior fracture | No | Women | 60 to 80 | NA^n^ | MOF (3-year risk): 0.70 (95% CI, 0.66 to 0.74, 3,614 women)^128^ Any OF (3-year risk): 0.68 (95% CI, 0.65 to 0.72, 3,614 women)^128^ | NA | Denmark

a Studies summarized in this table include instruments predicting fracture risk over a specified time horizon (e.g., 5 or 10 years). Additional studies predicting fracture by a certain age are summarized in the narrative.

b Updated pooled estimates are provided where possible; otherwise, range of AUC estimates from relevant studies is provided.

c FRAX has been updated several times since its initial release. Studies included in this review do not consistently report which version was used; thus, findings reflect various versions of FRAX released from the initial version through the current version. Further, although FRAX predicts 10 year fracture risk, the range of actual followup used by studies reporting accuracy of fracture risk prediction varied from 2 years to 10 years.

d Based on DXA at the femoral neck with T-scores based on NHANES reference values for women 20-29 years of age.

e Based on DXA, site unspecified, reference values for T-scores unspecified.

f Either BMD or body weight is used in the nomogram.

g This instrument can be used for either 5- or 10-year fracture risk prediction.

h One of the studies included^171^ uses a broader definition of major osteoporotic fractures and one study^149^ reports discrimination using Harrell’s C statistic.

i Risk factors only used in prediction of fracture for women.

j Risk factor not included in the original QFracture, but is present in the 2012 update to QFracture.

k Original instrument was validated for up to 85 years of age; 2012 updated version included up to 100 years of age.

l Two studies^130,^ ^150^ did not include fractures of the proximal humerus in their definition of major osteoporotic fracture.

m Based on DXA of the proximal femur, reference values for T-scores unspecified.

n These instruments were initially developed to predict osteoporosis, not incident fracture. Studies have evaluated their use for fracture prediction with length of followup over 3 years or over 10 years as indicated.

o Only five risk factors from the original FRISC model were used for this estimate: age, weight, prior fracture, lumbar BMD, back pain.

p Based on DXA of the total hip and hip subregions, T-scores based on NHANES reference values for men.

q Originally developed on a cohort of only women for 5-year risk prediction, with a smaller set of clinical risk factors. Subsequent validation studies included added risk factors, included 10-year risk predictions, and applied the model to a cohort of only men.

Abbreviations: AUC=area under the curve; BMD=bone mineral density; BMI=body mass index; CI=confidence interval; COPD=chronic obstructive pulmonary disease; DXA=dual-energy X-ray absorptiometry; FRAX=Fracture Risk Assessment Tool; FRC=Fracture Risk Calculator; FRISC=Fracture and Immobilization Score; FRISK=Fracture Risk Score; lb=pound(s); MOF=major osteoporotic fracture defined as fractures of the proximal femur, distal radius, proximal humerus, and clinical vertebral fractures; NA=not applicable; NHANES=National Health and Nutrition Examination Survey; NR=not reported; OF=osteoporotic fracture; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=Osteoporosis Index of Risk; OST=osteoporosis self-assessment tool; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; WHI=Women’s Health Initiative.

##### Frax

FRAX was developed and validated in 11 different cohorts (230,486 participants including men and women) and uses age, sex, weight, height, prior fracture, parental history of fracture, and five other clinical risk factors.^32^ It can be used with or without femoral neck BMD to predict the 10-year risk of hip and MOF. FRAX is calibrated for use in different countries based on country-specific data. Studies included were conducted in the following countries: Australia, Canada, Denmark, Finland, France, Hong Kong, Japan, Netherlands, New Zealand, Spain, the United States, and in a multinational European and U.S. cohort.

The discriminative ability of FRAX for predicting future fracture varied by sex, site of fracture prediction, and whether BMD was used in the risk prediction. In men, pooled estimates of AUC from 3 to 44 studies and 13,970 to 15,842 participants ranged from 0.62 to 0.76 (depending on the model) (Appendix H, Figures 10-13). Within that range, pooled estimates were higher for 13 prediction models that included BMD and for the models predicting hip fracture. Pooled estimates for women based on between 10 and 17 studies with between 62,054 and 190,795 participants ranged somewhat higher (0.67 to 0.79) but they shared a similar pattern (Appendix H Figures 14-17). Pooled estimates for the prediction of MOF based on three studies (66,777 participants), including men and women, but that did not report findings by sex, were similar (AUC without BMD, 0.67 [95% CI, 0.66 to 0.67; I^2^, 47.1%]; AUC with BMD, 0.69 [95% CI, 0.69 to 070, I^2^, 70.3%]) (Appendix H, Figures 18-19). Two studies reported AUC for hip fracture with and without BMD from combined cohorts of men and women; estimates from these two studies^147,^ ^148^ were similar to estimates from the women-only cohorts.

The original FRAX validation study^32^ also reported AUCs; however, the AUCs reflected the risk of fracture at age 70, not a 10-year fracture risk, and did not report on MOF. Thus, we did not include these AUCs in our pooled estimates. In this validation study, the range of AUCs in the validation cohorts for prediction of hip fracture at age 70 (both sexes combined) was 0.70 to 0.81 with BMD and 0.57 to 0.77 without BMD. For nonhip osteoporotic fractures, the range was 0.55 to 0.77 with BMD and 0.54 to 0.81 without BMD.

##### Garvan Fracture Risk Calculator

The Garvan FRC, originally developed in cohorts of Australian men and women,^139^ uses age, sex, weight, prior nontraumatic fracture after age 50, and a fall within the past year as risk to predict risk of hip or MOF at either 5 or 10 years. BMD at the hip is an optional input to the risk prediction. We focus on estimates for 10-year fracture risk prediction, for comparison with other instruments that predict 10-year risk. Studies included were conducted in Australia, Canada, Netherlands, New Zealand, and Norway.

The discriminative ability of the Garvan FRC varied by sex, site of fracture prediction, and whether BMD was used in the risk prediction. Two studies reported AUC estimates in men.^129,149^ The AUC for hip fracture without BMD was 0.65 (95% CI, not reported [NR]; 1,285 men).^129^ With BMD, the AUC for hip fracture was 0.74 (95% CI, NR; 1,285 men) in one study^129^ and 0.85 (95% CI, NR; 1,606 men) in the other study.^149^ Estimates of AUC for nonvertebral fractures were 0.61 and 0.57 with and without BMD, respectively (95% CI, NR for either).^129^ Only one of the two studies reported AUC for MOF; the estimate was 0.70 (95% CI, NR; 1,606 men).^149^

In women, we calculated pooled AUC estimates for models with BMD of 0.68 (95% CI, 0.64 to 0.71; I^2^=848%; three studies, 6,534 women) for MOF (Appendix H Figure 20) and 0.73 (95% CI, 0.66 to 0.79; I^2^=97.3%; four studies, 7,809 women) for hip fracture (Appendix H Figure 21). One study^124^ reported an AUC of 0.69 (95% CI, NR; 506 women); a different study^129^ reported an AUC of 0.62 (95% CI, NR; 1,637 women) for nonvertebral fracture, both for prediction without BMD. Estimates of AUC for models without BMD ranged from 0.58 to 0.68 depending on site of fracture based on estimates from three studies.^124,^ ^126,^ ^129^

##### QFracture

QFracture predicts fracture risk in men and women over a 1- to 10-year period using age, sex, weight, height, parental fracture, previous fall, and between 11 and 13 clinical risk factors depending on sex.^150^ A 2012 update to the instrument added previous fall, ethnicity, and 10 additional clinical risk factors.^130^ BMD is not used to predict risk with QFracture. Studies included were conducted in France and the U.K. The AUC for MOF ranged from 0.69 to 0.74 in men and from 0.79 to 0.82 in women.^76^ For hip fracture, AUC estimates were 0.86 to 0.89 in men and was 0.89 in women.^76^

##### Other Fracture Risk Assessment Instruments

The remaining eight fracture risk assessments include the Women’s Health Initiative algorithm,^151^ OST,^152^ SCORE,^153^ Fracture and Immobilization Score,^154^ Fracture Risk Score,^155^ FRC,^156^ ORAI,^157^ and Osteoporosis Index of Risk (OSIRIS).^158^ Of these, all but the Fracture Risk Calculator^156^ were developed using only cohorts of women, and the prediction time range from 3 to 10 years. The only assessments evaluated in U.S. populations are the Women’s Health Initiative algorithm, OST, SCORE, and the Fracture Risk Calculator. Several of these instruments (OST, SCORE, ORAI, OSIRIS) were initially developed for the prediction of low bone mass or osteoporosis and later applied to the prediction of incident fracture. The Fracture Risk Calculator, OST, and the Women’s Health Initiative algorithm were evaluated in two external validation populations; the rest of the instruments have been evaluated only in one external validation population. Across all these instruments, AUC estimates for MOF in women ranged from 0.53 to 0.73^58,^ ^102,^ ^126,^ ^128^ and from 0.80 to 0.85 for hip fracture.^151,^ ^159,^ ^160^

Last, the Canadian Association of Radiologist and Osteoporosis Canada uses age, sex, prior fragility fracture, use of glucocorticoid steroids, and BMD to predict the 10-year risk of MOF in men and women age 50 or older.^161^ This instrument computes a 10-year absolute fracture risk and then categorizes risk as high (>20%), moderate (between 10% and 20%), and low (<10%). An external validation study using 10,039 participants reported a sensitivity of 0.54 (95% CI, 0.52 to 0.56) for predicting fracture among women in the high-risk category and a sensitivity of 0.31 (95% CI, 0.24 to 0.38) for men.^131^ The reported specificities were 0.75 (95% CI, 0.74 to 0.75) and 0.86 (0.85 to 0.87) for women and men, respectively.

#### Accuracy of Bone Measurement Tests Used to Predict Fracture: Overview of the Evidence

The 2010 review,^3^ based on evidence from 11 studies, found that DXA and QUS had similar AUC estimates for the prediction of fracture outcomes among samples of both women and men. Among postmenopausal women, for all types of fractures combined, AUC estimates based on DXA ranged from 0.59 to 0.66, and estimates based on QUS were approximately 0.66. In our updated review, we included 23 studies of low or unclear risk of bias (reported in 24 articles), two of which were included in the 2010 review,^162,163^ evaluating the performance of various bone measurement tests for predicting fractures (summary in Table 6; details in Appendix F Table 7).^133,144,147,148,154,155,162-179^ We do not discuss two studies further because they did not have usable data for our analysis of fracture outcomes; Henry et al did not report AUC estimates,^155^ and Ensrud et al did not present risk estimates separately for BMD alone.^178^ We rated one other study as high risk of bias and did not include it in our update.^180^ We did not include eight other studies from the 2010 review because they did not meet our inclusion criteria for one or more reasons, such as measuring bone density after the occurrence or identification of fracture or not reporting an AUC estimate.

Of the 21 studies we report on, two were conducted in the United States,^133,^ ^163^ one in Scotland,^162^ four in Japan,^154,^ ^164,^ ^169,^ ^177^ three in Canada,^147,^ ^148,^ ^165,^ ^166^ two in Hong Kong,^167,^ ^176^ two in Australia,^144,^ ^168,^ ^171^ one in Finland,^170^ two in France,^172,^ ^173^ one in Denmark,^174^ one in Sweden,^179^ one in New Zealand,^87^ and one in Spain.^175^

The Canadian Manitoba study of men and women age 50 years or older was the largest study (N=39,603).^148^

One study only reported data on men and women combined.^147^ All others included separate reporting on women and men; 14 reported on postmenopausal women and four reported on men. These studies generally had few exclusion restrictions.

All studies reported on centrally measured DXA. Four studies also reported on calcaneal QUS tests, and one study also reported on dual X-ray and laser (DXL). No studies on vertebral fracture assessment or dental tests met our inclusion criteria. The various bone measurement tests evaluate bone density using different technologies; this results in different measures of bone “strength” that are not comparable across technologies. For example, QUS yields measures of broadband attenuation (BUA), speed of sound (SOS), or a quantitative ultrasound index (QUI). Studies also differ by the number and location of the incident fracture site being predicted (any osteoporotic fracture, vertebral, or hip), and the reference sites (spine, hip, or femoral neck) used to determine DXA-measured BMD. The length of followup for fracture surveillance following bone measurement testing ranged from approximately 4 years to up to 15 years.

#### Accuracy of Bone Measurement Tests Used to Predict Fracture: Findings

Because of differences across studies in the combination of the type of imaging test, sex of the participants, and location of an incident facture being predicted, few studies reported on the same combination of parameters (Table 6). In general, we did not find differences in AUC by type of bone test or sex.

Regarding type of bone test, AUC estimates for fracture prediction based on centrally measured DXA BMD, trabecular bone score, or a combination of both were as follows: any osteoporotic fracture (0.63 to 0.74), vertebral or spine fracture (0.61 to 0.75), and hip (0.64 to 0.85). The AUC estimate of hip fracture based on DXL was 0.61.^179^ The range of AUC estimates for fracture prediction based on QUS parameters (BUA, SOS, or QUI) were similar: any osteoporotic fracture (0.64 to 0.72) and, measured in men in one study, hip (0.84). Two studies^163,^ ^168^ measured a combination of DXA and QUS (BUA parameter) and found that this approach did not appreciably increase AUC: any osteoporotic fracture (0.69 to 0.73), vertebral (0.72 in women) and (0.75 in men) in one study,^168^ and hip (0.78 to 0.85).

Regarding sex of the study participants, AUC estimates for fracture predictions based on DXA BMD in postmenopausal women ranged from 0.64 to 0.82. For QUS, AUC estimates ranged from 0.66 to 0.72. AUC estimates based on combinations of DXA and QUS reported in one study ranged from 0.72 to 0.81, differing by the location of the fracture.^168^ Four studies evaluating the performance of bone measurement tests for predicting fractures in men examined the same bone measurement screening tests used for women.^163,^ ^167,^ ^168,^ ^174^ AUC estimates based on DXA BMD in men ranged from 0.64 to 0.85, and for QUS, ranged from 0.64 to 0.84.^163,^ ^167^ AUC estimates based on combinations of DXA and QUS, reported in two studies, ranged from 0.69 to 0.85.^163,^ ^168^

Regarding fracture site, for both men and women, AUC point estimates of 0.80 or better were associated only with predictions of future hip fracture. These results were found in eight of 12 studies that evaluated this outcome. These include studies of women based on results of DXA of the total hip (0.81 to 0.82),^165,^ ^166^ middle phalanges of the second, third, and fourth fingers on the nondominant hand (0.83),^174^ and the femoral neck (0.85 and 0.82).^176,^ ^177^ Similar results among women were based on a combination of DXA of the femoral neck and QUS (0.81).^168^ One study of men found similar results, based on DXA of the femoral neck (0.85), QUS (0.84), and a combination of the two (0.85),^163^ but these findings were not replicated in one study based on DXA of the middle phalanges (0.64).^174^ AUC point estimates in two studies combined hip fracture results for men and women, based on DXA of the femoral neck (0.80^148^ and 0.76^147^). AUC accuracy in predicting hip fracture were lower in one study of women (0.77) than in two other studies, possibly the authors adjusted the results for age, falls, and fracture history,^168^ whereas the other two studies reported unadjusted outcomes. The reasons that the prediction for women in yet another study was lower (0.64) are unknown.^171^

#### Calibration of Fracture Risk Prediction Instruments

We identified 14 studies of low or unclear risk of bias reporting eligible calibration outcomes in countries with an incidence of hip fracture similar to that found in the United States (i.e., in the moderate range).^102,^ ^125,^ ^147-149,^ ^154,^ ^170,^ ^171,^ ^175,^ ^177,^ ^181-185^ Eleven reported calibration outcomes for FRAX (various versions);^125,^ ^147,^ ^148,^ ^170,^ ^171,^ ^175,^ ^177,^ ^181-185^ four reported outcomes for other risk models.^102,^ ^149,^ ^154,171^ We identified no published studies that met our eligibility criteria that provided results of calibration for the U.S. version of FRAX or of other risk assessment instruments in U.S. populations. Ten calibration studies conducted outside of the United States in countries with hip fracture incidence dissimilar to the US were not included in the evidence synthesis.^102,^ ^123,^ ^125,^ ^127,^ ^129-131,^ ^181,^ ^183,^ ^184^

#### Other Measures of Test Performance: Reclassification of Risk Overview

Several studies compared overall proportions of individuals classified at risk for various fracture risk prediction instruments without presenting reclassification data.^131,^ ^138,^ ^178,^ ^186,^ ^187^ Others present reclassification rates^188-190^ or net reclassification improvement (NRI).^127,^ ^129,^ ^149,^ ^164,^ ^168,^ ^191,^ ^192^ We describe results for studies presenting only reclassification rates in greater detail in the text below. We present details regarding NRI in text below and in Table 7. In instances in which studies report NRI as a percentage, we follow guidance on net reclassification to present these results as unitless measures rather than as a percentage of the cohort reclassified. Guidance suggests that these results cannot be interpreted as percentages because of the implicit weighting by event rates when summing two fracture numbers with two different denominators to arrive at the NRI.^193^

Table 7 Reclassification Of Risk With Osteoporosis Tools Or Instruments

Tool or Instrument | Author, Year of Publication | Population | N | Followup Period | Fracture Rate | Clinical Threshold or Tool Used for Reclassification | Results
FRAX with BMD | Pressman et al, 2011^187^ | Participants >50 years of age with BMD in Kaiser Permanente Northern California, USA | 94,489 women | Mean: 6.6 years | Hip fracture: 1.7% (1,579/94,489) | Youdenʼs Index (81% sensitivity threshold [identified as the optimal level from the NRI curve for the model without BMD, corresponding to a 10-year probability of 1.2% risk of hip fracture]) | NRI: 0.055
FRAX with lumbar spine BMD inputs | Leslie et al, 2012^127^ | All individuals age 50 years of age and older with valid DXA measurements from the lumbar spine and femoral neck in Manitoba, Canada | 20,477 men and women | Mean: 8 years | Osteoporotic fracture: 9% (1,845/20,477) | FRAX with femoral neck BMD | NRI for FRAX with weighted mean (lumbar spine or femoral neck): 0.02 NRI for FRAX with offset spine-hip T-score difference): 0.02 FRAX with minimum site (lumbar spine or femoral neck): 0.028 NRI for FRAX with lumbar spine T-score: 0.01
FRC with BMD | Ettinger et al, 2012^191^ | Participants age ≥65 years in the Osteoporotic Fractures in Men Study database, United States | 5,893 men | Mean: 8.4 years | Incident hip fracture: 2.6% (156/5,873) Incident major osteoporotic fracture: 5.7% (335/5,873) | NOF 10-year 3% probability of a hip fracture | NRI: 0.085
FRC with BMD | Ettinger et al, 2012^191^ | Participants age ≥65 years in the Osteoporotic Fractures in Men Study database, United States | 5,893 men | Mean: 8.4 years | Incident hip fracture: 2.6% (156/5,873) Incident major osteoporotic fracture: 5.7% (335/5,873) | NOF 10-year 20% probability of a major osteoporotic fracture | NRI: 0.04
Dubbo nomogram with calcaneal QUS | Chan et al, 2012^168^ | Participants ages 62-89 years from the Dubbo Osteoporosis Epidemiology Study, Australia | 454 women | Median: 13 years | 33.9% (154/454) | Dubbo nomogram with femoral neck BMD | NRI for hip fractures: 0.111 for hip fracture NRI for vertebral fractures: 0.052 NRI for any fractures: 0.073
Dubbo nomogram with calcaneal QUS | Chan et al, 2012^168^ | Participants ages 62-89 years from the Dubbo Osteoporosis Epidemiology Study, Australia | 445 men | Median: 13 years | 16.9% (75/445) | Dubbo nomogram with femoral neck BMD | NRI for hip fractures: -0.055 for hip fracture NRI for vertebral fractures: 0.038 NRI for any fractures: no improvement
Dubbo nomogram with calcaneal QUS | Chan et al, 2013^192^ | Participants ages 62-90 years with BMD T-score >-2.5 at femoral neck from the Dubbo Osteoporosis Epidemiology Study, Australia | 312 women | Median: 12 years | 26% (80/312) | Dubbo nomogram with femoral neck BMD | NRI for hip fractures: 0.338 for hip fracture NRI for vertebral fractures: -0.09 NRI for any fractures: 0.164
Dubbo nomogram with calcaneal QUS | Chan et al, 2013^192^ | Participants ages 62-90 years with BMD T-score >-2.5 at femoral neck from the Dubbo Osteoporosis Epidemiology Study, Australia | 390 men | Median: 12 years | 14% (53/390) | Dubbo nomogram with femoral neck BMD | NRI for hip fractures: -0.003 for hip fracture NRI for vertebral fractures: 0 NRI for any fractures: 0.035
Dubbo nomogram | Langsetmo et al, 2011^149^ | Participants ages 55-95 years at baseline in the Canadian Multicentre Osteoporosis Study | 4,152 women | Mean: 8.6 years | 14.04% (583/4,152) | WHO criteria of a T-score of ≤-2.5 for high risk | NRI: 0.015 in women (95% CI, -0.026 to 0.056)
Dubbo nomogram | Langsetmo et al, 2011^149^ | Participants ages 55-95 years at baseline in the Canadian Multicentre Osteoporosis Study | 4,152 women | Mean: 8.6 years | 14.04% (583/4,152) | Canadian guidelines: low risk = 0%–10%, moderate = 10%–20%, and high = >20% | NRI: -0.055 (95% CI, -0.095 to -0.015)
Dubbo nomogram | Langsetmo et al, 2011^149^ | Participants ages 55-95 years at baseline in the Canadian Multicentre Osteoporosis Study | 1,606 men | Mean: 8.3 years | 7.2% (116/1,606) | WHO criteria of a T-score of ≤-2.5 for high risk | NRI: 0.067 (95% CI, -0.06 to 0.194)
Dubbo nomogram | Langsetmo et al, 2011^149^ | Participants ages 55-95 years at baseline in the Canadian Multicentre Osteoporosis Study | 1,606 men | Mean: 8.3 years | 7.2% (116/1,606) | Canadian guidelines: low risk = 0%–10%, moderate = 10%–20% and high = >20% | NRI: 0.192 (95% CI, 0.063 to 0.322)
Garvan nomogram with body weight | Ahmed et al, 2014^129^ | Participants age 60 years and older from Troms∅, Norway | 1,637 women 1,355 men | Mean: 6.9 years Mean: 7.1 years | Nonvertebral osteoporotic fractures: 21.7% (356/1,637) Hip fractures: 5.4% (88/1,637) | Garvan nomogram with BMD | NRI for nonvertebral osteoporotic fractures: -0.106 (SE: 0.04)
Garvan nomogram with body weight | Ahmed et al, 2014^129^ | Participants age 60 years and older from Troms∅, Norway | 1,637 women 1,355 men | Mean: 6.9 years Mean: 7.1 years | Nonvertebral osteoporotic fractures: 21.7% (356/1,637) Hip fractures: 5.4% (88/1,637) | Garvan nomogram with BMD | NRI for hip fractures: -0.172 (SE: 0.052)
Garvan nomogram with body weight | Ahmed et al, 2014^129^ | Participants age 60 years and older from Troms∅, Norway | 1,637 women 1,355 men | Mean: 6.9 years Mean: 7.1 years | Nonvertebral osteoporotic fractures: 8.6% (117/1,355) Hip fracture: 3.5% (47/1,355) | Garvan nomogram with BMD | NRI for nonvertebral osteoporotic fractures: -0.133 (SE 0.072)
Garvan nomogram with body weight | Ahmed et al, 2014^129^ | Participants age 60 years and older from Troms∅, Norway | 1,637 women 1,355 men | Mean: 6.9 years Mean: 7.1 years | Nonvertebral osteoporotic fractures: 8.6% (117/1,355) Hip fracture: 3.5% (47/1,355) | Garvan nomogram with BMD | NRI for hip fractures: -0.175 (SE 0.10)
Lumbar spine trabecular bone score | Iki et al, 2014^164^ | Japanese women age 50 years and older | 665 | Median: 10 years | 13.8% (92/665) | Appears to be continuous (no risk categories specified) | NRI: 0.235 (95% CI, 0.15 to 0.54)

Abbreviations: BMD=bone mineral density; CI=confidence interval; DXA=dual energy X-ray absorptiometry; FRAX=Fracture Risk Assessment tool; FRC=Fracture Risk Calculator; N=number; NOF=National Osteoporosis Foundation; NRI=net reclassification improvement; QUS=quantitative ultrasound; SE=standard error; USA=United States of America; WHO=World Health Organization.

#### Other Measures of Test Performance: Findings

##### Frax

Five studies evaluate reclassification for FRAX.^123,^ ^127,^ ^149,^ ^189,^ ^190^ One study examined reclassification in the context of FRAX with and without BMD in a sample of 36,730 women and 2,873 men age 50 years or older from the Manitoba Bone Density Program database (Canada).^123^ The study reported no differences in AUCs for men or women for any outcomes other than major osteoporotic fractures. It reported the addition of BMD to FRAX, against an intervention threshold of a 10-year risk ≥20 percent of a MOF, resulting in a reclassification of 8.5 percent of the cohort. Of these individuals, 2.8 percent moved to the higher risk category (≥20% risk of MOF) and 5.7 percent moved to the lower risk category (<20%). For those in the intermediate category of risk (10% to 19% risk of MOF), adding BMD to FRAX produced a reclassification of 7.5 percent to the low-risk category (<10% risk of MOF) and 2.7 percent to high risk (≥20% risk of MOF). Of those categorized as low risk, adding BMD to FRAX led to a reclassification of 6.2 percent to moderate risk and 0.1 percent to high risk.^123^ A large study of 94,489 women age 50 years or older with BMD measured during 1997–2003 in Kaiser Permanente Northern California also found no differences in AUC with or without BMD.^187^ An exploration of reclassification when adding BMD to fracture risk assessment used an 81 percent sensitivity threshold (identified as the optimal level from the receiver operating characteristic curve, corresponding to a 10-year risk for hip fracture of 1.2% in the model without BMD). This reclassification resulted in an NRI of 0.055.

Three studies reporting on the same cohort of participants in Manitoba, focused on issues specific to the measure of BMD in FRAX, specifically the inclusion of information on lumbar spine BMD in addition to femoral neck BMD. Two were developed and validated using a split-sample cohort.^189,^ ^190^ One study developed a hybrid system for FRAX that incorporated femoral neck BMD to assess nonvertebral fracture risk and lumbar spine BMD for clinical vertebral fracture risk.^190^ The study found that in 37,032 women, against an intervention threshold of >20 percent risk of a major MOF, the use of the hybrid model resulted in a reclassification of 7.6 percent of the cohort. Of these individuals, 0.1 percent moved to the higher risk category (>20% risk of MOF) and 7.5 percent moved to the lower risk category (≤20%). For those in the moderate category of risk (10% to 20% risk of MOF), the hybrid model resulted in a reclassification of 0.5 percent of the cohort to the low-risk category (<10% risk of MOF) and 7.5 percent to high risk. Of those categorized as low risk, the hybrid model produced a reclassification of 6.1 percent of the cohort to moderate risk.^190^

The difficulties in applying this hybrid model in clinical practice led to further testing of ways to incorporate lumbar spine measurement. A second study evaluated reclassification after adding information on an offset (the difference between lumbar spine and femoral neck T-scores) to FRAX.^189^ In a sample of 18,215 women in the validation cohort, adding the lumbar spine offset against an intervention threshold of ≥20 percent risk of a MOF, resulted in a reclassification of 13.1 percent of the cohort. Of these individuals, 3.8 percent moved to the higher risk category (≥20% risk of MOF) and 9.3 percent moved to the lower risk category (<20% risk of MOF). For those in the moderate category of risk (10% to 19% risk of MOF), adding the lumbar spine offset to FRAX resulted in a reclassification of 8.8 percent to the low-risk category (<10% risk of MOF) and 3.8 percent to high risk) (≥20% risk of MOF). Of those categorized as low risk, the addition of lumbar spine offset to FRAX led to a reclassification of 4.9 percent to moderate risk (10% to 19% risk of MOF).^189^

A third study compared FRAX with T-scores from the femoral neck, lumbar spine, minimum site (femoral neck or lumbar spine), weighted mean, and an offset (the difference between the lumbar spine and femoral neck T-scores) in 20,477 men and women.^127^ It found that the use of lumbar spine or minimum site resulted in both reclassification and miscalibration, while the use of weighted mean or offset did not. Specifically, the authors report that the change in accuracy was negative for lumbar spine (-4.4%) and minimum site (-11.8%), and unchanged for weighted mean (0.1%) and offset (0.3%) (details on calculation of change of accuracy not reported).

##### Fracture Risk Calculator

One study evaluated adding BMD to the FRC in men 65 years and older using the Osteoporotic Fractures in Men Study database of 5,893 men in the United States who participated in the baseline visit (March 2000–April 2002).^191^ Against the National Osteoporosis Foundation’s (NOF) intervention threshold (10-year 3% risk of a hip fracture), the addition of BMD resulted in an NRI of 0.085. Using the NOF intervention threshold of a 20 percent 10-year risk of MOF, the addition of BMD resulted in an NRI of 0.04. In 17 of 20 examined quintiles of expected fracture probabilities to observed fractures (with BMD, without BMD, hip fracture, MOF), the ratio (of expected to observed fractures) was within 20 percent of the ideal 1.0 ratio.

##### Garvan FRC (Dubbo Nomogram in Earlier Studies)

Two studies, both drawing from the Dubbo Osteoporosis Epidemiology Study (Australia), evaluated the performance of fracture risk prediction models that included calcaneal QUS (measured through BUA) with the Garvan FRC,^168,^ ^192^ which includes femoral neck BMD, age, history of falls, and prior fracture. One study included 899 participants between ages 62 and 89 years (445 men and 454 women) who had both QUS and DXA BMD measurements.^168^ Participants been followed for a median of 13 years. The second study restricted analysis to nonosteoporotic participants (BMD T-score >−2.5).^192^ The sample comprised 312 women and 390 men ages 62 to 90 years, followed for a median of 12 years. Both studies reported that the addition of BUA to the femoral neck BMD model improved AUC for women for hip fractures and any fractures,^168,^ ^192^ and for vertebral fractures in nonosteoporotic women only.^192^ Both studies found that adding BUA to the model did not improve AUCs. In the larger sample of all women, adding BUA to the model resulted in an NRI of 0.073 for any fracture, 0.111 for hip fracture, and 0.052 for vertebral fracture.^168^ In nonosteoporotic women, adding BUA to the model resulted in an NRI of 0.164 for any fractures and 0.338 for hip fracture.^192^ The importance of these differences is difficult to evaluate in the context of small sample sizes and lack of information on the potential for miscalibration.

One study of 4,152 women and 1,606 men, ages 55 to 95 years at baseline in the Canadian Multicentre Osteoporosis Study compared the performance of the instrument with (1) the World Health Organization (WHO) criteria of a T-score of ≤−2.5 indicating high risk and (2) Canadian guidelines (defining low risk = 0–10%, moderate = 10–20%, and high >20%, and derived from age, minimum T-score [lumbar spine, total hip, femoral neck, trochanter], glucocorticoid use and history of fracture after age 40).^149^ Comparisons with the WHO criteria suggested no differences with an NRI of 0.067 (95% CI, —0.06 to 0.194) among men and 0.015 in women (95% CI, −0.026 to 0.056). Comparisons with the Canadian guidelines suggested improvements in prediction for men (NRI, 0.192 [95% CI, 0.063 to 0.322) and worsening for women (NRI, −0.055 [95% CI, −0.095 to −0.015).^149^ The study did not present AUCs for these comparisons.

One study examined the performance of the Garvan tool with and without BMD in predicting nonvertebral osteoporotic and hip fractures. The study included 1,637 women and 1,355 men older than age 60 years from Tromsø (Norway).^129^ The study recorded all incident fragility fractures between 2001 and 2009. AUCs for the model with BMD were higher than the models without BMD but with body weight for men and women. Models that included body weight rather than BMD resulted in an NRI of −0.106 in women and − 0.172 in men for nonvertebral osteoporotic fractures. For hip fractures, models that included weight rather than BMD resulted in an NRI of −0.133 for women and −0.175 for men.

##### Trabecular Bone Score

One study evaluated reclassification arising from adding trabecular bone score to spine BMD in a sample of 665 Japanese women age 50 years or older who completed the baseline study and at least one followup survey over 10 years.^164^ The study reported no significant differences in AUC, but reported an NRI of 0.235 (95% CI, 0.15 to 0.54); no risk categories were specified for the NRI. This finding can potentially be explained by chance (given the small sample size) or miscalibration.

### Key Question 2b What Is the Evidence to Determine Screening Intervals for Osteoporosis and Low Bone Density?

#### Overview

Although the previous USPSTF recommendation suggested that a minimum of 2 years may be needed to measure a change in BMD reliably, it also noted continued clinical uncertainty about the optimal interval for rescreening to improve fracture prediction.^1^ Two good-quality studies address screening intervals for osteoporosis and low bone density; of these, one^194^ was reported in the 2010 review.^3^ These longitudinal cohort studies examined the effect of repeat BMD testing on prediction of fracture risk (Table 8).^194,^ ^195^

Table 8 Using Repeat BMD Testing To Predict Fracture Risk

Study | Study Cohort, Country | Inclusion / Exclusion Criteria | Mean Length of Followup, Years (Range) | N | Participant Characteristics | Bone Measurement Test | Fracture Site | AUC for Baseline BMD (95% CI) | AUC for BMD% Change (95% CI) | AUC for BMD Baseline and % Change (95% CI)
Berry, 2013^195^ | Framingham Osteoporosis Study, USA | Included participants with at least two BMD measurements. Excluded those with fracture prior to second test. | 3.7 (2.4 to 6.0) | 802 | Mean age: 74.8 (SD 4.5) Percent women: 61 | DXA, BMD | Hip fracture^1^ | 0.71 (0.65 to 0.78) | 0.68 (0.62 to 0.75) | 0.72 (0.66 to 0.79)
Berry, 2013^195^ | Framingham Osteoporosis Study, USA | Included participants with at least two BMD measurements. Excluded those with fracture prior to second test. | 3.7 (2.4 to 6.0) | 802 | Mean age: 74.8 (SD 4.5) Percent women: 61 | DXA, BMD | MOF fracture^1^ | 0.74 (0.69 to 0.79) | 0.71 (0.66 to 0.76) | 0.74 (0.69 to 0.79)
Hillier, 2007^194^ | Study of Osteoporotic Fractures, USA | Included participants with at least two BMD measurements. Excluded those with fracture prior to second test. | 8.0 (6.3 to 9.8) | 4,124 | Mean age: 74 (SD 4) Percent women: 100 | DXA, BMD | Hip fracture^2^ | 0.73 (CI, NR) | 0.68 (CI, NR) | 0.74 (CI, NR)
Hillier, 2007^194^ | Study of Osteoporotic Fractures, USA | Included participants with at least two BMD measurements. Excluded those with fracture prior to second test. | 8.0 (6.3 to 9.8) | 4,124 | Mean age: 74 (SD 4) Percent women: 100 | DXA, BMD | Nonspine fracture^2^ | 0.65 (CI,NR) | 0.61 (CI, NR) | 0.65 (CI, NR)
Hillier, 2007^194^ | Study of Osteoporotic Fractures, USA | Included participants with at least two BMD measurements. Excluded those with fracture prior to second test. | 8.0 (6.3 to 9.8) | 4,124 | Mean age: 74 (SD 4) Percent women: 100 | DXA, BMD | Spine fracture^2^ | 0.67 (CI, NR) | 0.62 (CI, NR) | 0.68 (CI, NR)

1 Adjusted for age, sex, BMI, weight loss, and history of fracture measured at the time of the second BMD.

2 Adjusted for age and weight change.

Abbreviations: AUC=area under the curve; BMD=bone mineral density; BMI=body mass index; CI=confidence interval; DXA=dual energy X-ray absorptiometry; MOF=major osteoporotic fracture defined as fractures of the proximal femur, distal radius, proximal humerus, and clinical vertebral fractures; N=number; NR=not reported; SD=standard deviation; USA=United States of America.

We also identified three studies for Contextual Question 2 that used data from large cohort studies to estimate the optimal screening interval to identify osteoporosis or fracture.^196-198^

#### Findings

The Study of Osteoporotic Fractures (N=4,124), in which women (mean age at baseline: 72; mean T-score: −1.37; 95% CI, −1.40 to −1.34) who had a repeat BMD an average of 8 years after baseline DXA measurement, found no significantly different AUCs for either hip, nonspine, or spine fractures for women with information on change in BMD or combined baseline BMD and change in BMD compared with women with information on baseline BMD alone.^194^ The study followed participants for a mean of 5 years after the second DXA measurement. The Framingham Osteoporosis study cohort included male participants (41%) with a similar mean age (74.8) and 74.7 percent of the sample having T-score >−2.5, but a shorter screening interval (3.7 years vs. 8 years), and followed patients for a median of 9.6 years after repeat BMD study (N=802).^194,^ ^195^ The authors of the Framingham Osteoporosis study reported similar results to the Study of Osteoporotic Fractures: AUCs for fractures among men with information on change in BMD or combined baseline and change in BMD did not differ from men with information on baseline BMD alone.^195^ The study reported a net gain in the percentage of participants with a hip fracture reclassified as high risk (defined by FRAX, NRI, 3.9% [95% CI, −2.2% to 9.9%]) with a second BMD, and a net loss for those without a hip fracture reclassified as low risk with repeat BMD (NRI, −2.2% [95% CI, −4.5% to 0.1%). The study reported a higher rate of reclassification for major osteoporotic fractures (NRI, 9.7% [95% CI, 3.4 to 15.7] vs. −4.6% [95% CI, −6.7 to −2.6]) than for hip fractures.

Additional contextual evidence comes from a small number of publications that have attempted to identify appropriate screening intervals based on the time in which 10 percent of patients transition to osteoporosis. A publication using healthy postmenopausal women age 65 years or older from the Study of Osteoporotic Fractures evaluated the time for 10 percent of women to develop osteoporosis across the various BMD categories; it found that baseline T-score is the most important determinant of BMD testing intervals, with results suggesting that the times for 10 percent of women to develop osteoporosis are as follows: 16.8 years (95% CI, 11.5 to 24.6) for women with normal BMD (T-score, −1.00 or higher), 17.3 years (95% CI, 13.9 to 21.5) for women with mild osteopenia (T-score, −1.01 to −1.49), 4.7 years (95% CI, 4.2 to 5.2) for women with moderate osteopenia (T-score, −1.50 to −1.99), and 1.1 years (95% CI, 1.0 to 1.3) for women with advanced osteopenia (T-score, −2.00 to −2.49).^196^ Within a given T-score range, the estimated time for 10 percent of women to transition from osteopenia to osteoporosis was longer for women with younger age and for those taking estrogen at baseline. For women with moderate osteopenia at baseline, the estimated BMD testing interval was 5.6 years (95% CI, 4.9 to 6.4) for women age 67 years compared with 3.2 years (95% CI, 2.6 to 3.9) for women age 85 years. Also for women with moderate osteopenia, the estimated BMD testing interval for past or never-users of estrogen was shorter, 4.3 years (95% CI, 3.9 to 4.8), than for women with current estrogen use, 6.9 years (95% CI, 5.7 to 8.4). Using an absolute risk-based prognostic model with a sample of nonosteoporotic women and men over the age of 60 from the Dubbo Osteoporosis Epidemiology study, the study found that current age and BMD T-score could be used to estimate the optimal time to repeat BMD testing for both men and women.^197^ For example, the time for women 60 years of age with a normal BMD to reach a 10 percent risk of sustaining a fracture or developing osteoporosis was 8.9 years (90% CI 6.7 to 10.6); it was 2.7 years (90% CI, 2.3 to 3.1) for women 80 years of age.

A third study provides contextual evidence for identifying the time to transition to fracture (rather than osteoporosis) in younger postmenopausal women ages 50 to 64 years. In a study of women from the Women’s Health Initiative with a baseline BMD, investigators estimated the time for 1 percent of women to sustain a hip or clinical vertebral fracture and for 3 percent of women to sustain a major osteoporotic fracture.^198^ Women were followed for up to 11 years after the initial BMD. Similar to findings of studies estimating time to transition to osteoporosis, the study found that age and baseline T-score were associated with the estimated time for 1 percent of women to transition to fracture. For women without osteoporosis at baseline (t > −2.50), the estimated times for 1 percent of women to transition to hip or clinical vertebral fracture were 12.8 years (95% CI, 8 to 20.4) for ages 50 to 54 years, 11.7 years (95% CI, 6.9 to 20) for ages 55 to 59 years, and 7.6 years (95% CI, 4.8 to 12.1) for ages 60 to 64 years. For all women with osteoporosis at baseline (t ≤ −2.50), the time interval for 1 percent of women ages 50 to 64 years to transition to hip or clinical vertebral fracture was 3.0 years (95% CI, 1.3 to 7.1). There were similar findings for major osteoporotic fracture.

### Key Question 3 What Are the Harms of Screening for Osteoporotic Fracture Risk?

One trial (SCOOP, previously described in KQ1)^72^ assessed the impact of screening on anxiety (based on State-Trait Anxiety Inventory) and quality of life (based on the EuroQol- 5 Dimension tool and the Short-Form Health Survey 12 [physical and mental health]) and found no differences between participants who were allocated to screening vs. usual care (variance not reported, P values >0.10 for all outcomes).

### Key Question 4a What Is the Effectiveness of Pharmacotherapy for the Reduction of Fractures and Related Morbidity and Mortality?

We present summary results in text below. Appendix F includes detailed evidence for alendronate (Appendix F Table 9), zoledronic acid (Appendix F Table 10), risedronate (Appendix F Table 11), etidronate (Appendix F Table 12), raloxifene (Appendix F Table 13), denosumab (Appendix F Table 14), and parathyroid hormone (Appendix F Table 15). Appendix H includes forest plots for meta-analyses.

#### Bisphosphonates: Overview of the Evidence

##### Alendronate

Seven fair- to good-quality studies examined fracture outcomes in patients receiving alendronate versus placebo. All studies were conducted in postmenopausal women receiving daily or weekly alendronate. The duration of the studies ranged from 1 to 3 years.^199-205^ Three studies reported fractures at baseline,^199,^ ^202,^ ^205^ three studies reported no fractures at baseline,^199,^ ^200,^ ^203^ and one study did not specify.^201^ Two studies reported on the Fracture Intervention Trial (FIT).^200,^ ^205^ The FIT had two arms, one with vertebral fractures at baseline, which was excluded for wrong population,^206^ and no fractures at baseline.^200^ One study looked at a subset of women with low bone mass from both arms of the FIT.^205^

We excluded several studies that were included in previous reviews, most commonly for wrong study population (i.e., specialty versus primary care population) or wrong outcome (change in BMD rather than fractures),^207-215^ and one study for high risk of bias.^216^

##### Zoledronic Acid

Two trials of zoledronic acid (N=1,550) met our eligibility criteria.^217,^ ^218^ Two studies in the previous review, both from the Horizon Pivotal Fracture Trial, were not included because more than 50 percent of the study population had a fracture at baseline.^219,^ ^220^ In addition, we excluded one study from a recent comparative effectiveness review^221^ because it drew from a nonprimary care population.^222^

One study of fair quality was a phase 2 study in postmenopausal women ages 45 to 80 years with low bone density (T-score <-2) and no prior vertebral fractures. It was conducted in 24 centers across 10 countries with 1 year of followup.^217^ A second and more recent study (good-quality) was also a multicenter trial conducted in Europe, South America, Africa, and Australia. This study examined men ages 50 to 85 years with T-score <1.5 or prevalent fractures with 2 years of followup.^218^ Both studies evaluated zoledronic acid against placebo infusion.^217,^ ^218^ In the phase 2 trial, cumulative doses of 4 mg yearly were included in the analysis of benefits;^217^ in the more recent study, zoledronic acid 5 mg was administered intravenously at baseline and 1 year.^218^

##### Risedronate

Four trials evaluating risedronate met eligibility criteria.^223-226^ All were conducted in postmenopausal women with low bone mass or osteoporosis, and we rated them as fair quality. Three of these studies were included in the main analysis^223-225^ of the previous review; one study was included in its sensitivity analysis because the proportion of prevalent vertebral fracture exceeded 20 percent.^226^ We did not include one study from the previous review^227^ in this update because the study population had mean T-score of -0.7 and was otherwise not at an increased risk for fracture. Approximately one-third of study subjects in two studies^223,^ ^226^ had prevalent or prior vertebral fracture at baseline. One study^224^ excluded subjects with prior fractures and one study^225^ did not report the proportion of study subjects with prior or prevalent fracture. All studies evaluated a dose of 5 mg per day for 2 years compared with placebo; followup for fracture outcome ascertainment was 2 to 3 years after baseline. Two trials were conducted in multiple centers in several European countries,^225,^ ^226^ one trial^223^ was conducted at multiple centers in North America, Europe, Australia and New Zealand, and one trial^224^ was conducted at two centers (one in the United States and one in Denmark).

One trial^223^ was powered to detect an effect on hip fracture outcomes. The other three trials were powered to detect an effect on BMD. For these trials, therefore, fracture outcomes reported in these trials were reported as safety events as opposed to efficacy end points.^224-226^

##### Etidronate

Two fair-quality trials of etidronate (n=206) met eligibility criteria.^228,^ ^229^ We excluded one trial of etidronate for wrong population that had been included in the 2010 review.^230^ Both included trials were conducted in postmenopausal women with no prior fractures^228^ or with unknown prior fracture history.^229^ One study enrolled women who were 6 to 60 months postmenopausal^229^ and one enrolled women 1 to 10 years postmenopausal.^228^ The mean baseline T-scores for the studies ranged between -1.3 and -1.1. The mean age of participants was <55 years in both trials. Both trials evaluated cyclical etidronate 400 mg for 2 years with change in BMD as the primary outcome. Both included studies were set in Europe.^228,^ ^229^

##### Ibandronate

We identified no studies or trials that assessed the benefits of ibandronate for preventing fractures.

#### Bisphosphonates: Findings

##### Vertebral Fracture

This analysis includes 11 trials (10 from the previous report and one from the new evidence).^199,^ ^200,^ ^203,^ ^204,^ ^217,^ ^218,^ ^224-226,^ ^228,^ ^229^ All studies reported on the reduction in radiographic vertebral fractures, except for one study reporting clinical vertebral fractures^225^ and one study that did not specific fracture type.^204^ Among women, bisphosphonates reduced vertebral fractures compared with placebo (2.1% vs. 3.8%; RR, 0.57 [95% CI, 0.41 to 0.78]; I^2^, 0%; 5 trials, N=5,433) (Appendix H Figure 22).^199,^ ^200,^ ^224,^ ^226,^ ^229^ Five trials recorded zero vertebral fractures and did not contribute to the pooled estimate in the primary analysis.^203,^ ^204,^ ^217,^ ^225,^ ^228^

Results based on alternative methods for pooling were nearly identical with and without zero event trials.

As noted in the 2010 review, the largest trial, FIT, a 4-year trial of alendronate, contributed 82 percent of the total number of patients (N=4,432 of 5,433) and vertebral fractures (171) in the analysis (1.9% vs. 3.5%; RR, 0.55 [95% CI, 0.38 to 0.80]).^200^ Drugs other than alendronate had small samples and few fractures.

One new trial reported on the effectiveness of zoledronic acid in 1,199 men with mean femoral neck T-scores of -2.23 (intervention) and -2.24 (control). Men were eligible to participate if they had a bone mineral density T score of —1.5 or less (based on the device-specific reference values for men). The authors found a reduced risk of morphometric vertebral fractures in the treatment arm (1.5% vs. 4.6%; RR, 0.33 [95% CI, 0.16 to 0.70]).^218^

##### Nonvertebral Fracture

Ten trials reported on nonvertebral fractures.^200,^ ^201,^ ^204,^ ^217,^ ^218,^ ^223-226,^ ^229^ Of these, one reported no fracture outcomes with either alendronate or placebo.^204^ Studies were generally not powered to examine this outcome and did not always clarify the definition or source of the fracture. Also, they often reported these fracture results along with other adverse events.

Among women, a pooled analysis of trials reporting total nonvertebral fractures a reduced risk of fractures in the treatment arm (8.9% vs. 10.6%; RR, 0.84 [95% CI, 0.76 to 0.92]; I^2^, 0; eight trials, N=16,438) (Appendix H Figure 23).^200,201,217,224-226,229^ One trail record zero nonvertebral fractures and did not contribute to the primary analysis.^204^

One new trial reported on the effectiveness of zoledronic acid in 1,199 men, with mean femoral neck T-score values of -2.23 (intervention) and -2.24 (control). The authors found a reduced risk of nonvertebral fractures in the treatment arm but the effect was not statistically significant (0.9% vs. 1.3%; RR, 0.65 [95% CI, 0.21 to 1.97]).^218^

##### Hip Fractures

Four studies reported on hip fractures.^200,^ ^201,^ ^223,^ ^224^ All had been identified in the 2010 review. We excluded one study because we were unable to find the reported data.^225^ One trial recorded no hip fractures and did not contribute to the primary analysis.^224^

Among women, the pooled analysis suggested a lower risk but wide confidence intervals (0.7% vs. 0.96%; RR, 0.70 [95% CI, 0.44 to 1.11]; I^2^, 0%; 3 trials, N=8,988) (Appendix H Figure 24). The two large trials dominating this meta-analysis, FIT^200^ and the study by McClung et al^223^ also found no statistically significant effects. Only one trial was powered for detecting differences in hip fractures;^223^ other studies may have been underpowered for this outcome. Results based on alternative methods for pooling were nearly identical with and without zero event trials; the confidence interval for the Peto odds ratio approaches but does not cross the line of no difference.

Results based on alternative methods for pooling were nearly identical with and without zero event trials.

No studies reported on hip fractures in men.

#### Raloxifene: Overview of the Evidence

One large good-quality RCT, included in the 2010 review,^3^ the Multiple Outcomes of Raloxifene (MORE) trial, reported in two articles, measured fracture outcomes among postmenopausal women at increased risk for fracture who were receiving raloxifene, a selective estrogen receptor modulator.^231,^ ^232^ A second large good-quality RCT, the Raloxifene Use for the Heart (RUTH) study, also reported in the 2010 review,^3^ does not meet our inclusion criterion of participants being at increased risk for fracture.^3,^ ^233,^ ^234^ We identified no new studies measuring fracture outcomes.

#### Raloxifene: Findings

The MORE trial (N=7,705) measured outcomes in women with BMD T-scores ≤−2.5, with or without previous vertebral fractures (37% with previous fractures).^231,^ ^232^ Although the approved Food and Drug Administration (FDA) raloxifene dosage is 60 mg/day, some study results report a combined treatment group (60 mg/day or 120 mg/day). After 4 years, raloxifene (60 mg/day) reduced radiographic vertebral fracture (7.5% vs. 12.5%; RR, 0.64 [95% CI, 0.53 to 0.76]) compared with placebo. Treatment with raloxifene (combined dosage amount group) did not yield differences in nonvertebral or hip fracture.

The RUTH trial (N=10,101) was designed primarily to evaluate coronary heart disease (CHD) and breast cancer outcomes among postmenopausal women with CHD or multiple risk factors for CHD and is therefore excluded from this review.^233,^ ^234^ Baseline BMD T-scores were not an inclusion criteria and are not reported. We note, however, that as was found in the MORE trial, raloxifene (60 mg/day) reduced clinical vertebral fractures (HR, 0.65 [95% CI, 0.47 to 0.89]) compared with placebo, but did not reduce nonvertebral or hip fractures.

#### Estrogen

The 2010 review discussed the results of the Women’s Health Initiative (WHI). Because the women enrolled in this trial had not been identified to be at high risk for osteoporosis (other than that all were postmenopausal), the trial did not meet inclusion criteria for this update. A recently completed review on the benefits and harms of estrogen therapy, with and without progestin, in primary care populations provides important contextual information.^235^ It incorporated information from WHI and other similar trials. Women using only estrogen had lower risks for total osteoporotic fractures (HR, 0.72; 95% CI, 0.64 to 0.80) when compared with women taking placebo. Women on estrogen plus progestin therapy also had lower risks for fractures (RR, 0.80; 95% CI, 0.68 to 0.94) with women on placebo. Additionally, we found one high risk-of-bias safety trial that included an estrogen only arm in comparison with a placebo arm (N=193). It reported a lower incidence but not statistically significant difference in clinical fractures over 2 years (7% vs. 8%; RR, 0.87 [95% CI, 0.29 to 2.66]).^216^

#### Denosumab: Overview of the Evidence

Three fair-quality phase 2 or phase 3 Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months (FREEDOM) trials of denosumab (N=8,565) met eligibility criteria.^236-238^ All were conducted in postmenopausal women with low bone mass or osteoporosis. One of these trials excluded women with any fractures since age 25.^237^ A second reported a 24 percent rate of prevalent fractures^238^ and the third excluded women with more than one vertebral fracture or any osteoporotic fracture in the past 2 years but did not report the rate of prevalent fractures.^236^ All evaluated subcutaneous denosumab against placebo for a minimum of 24 months; doses in the later studies were established as 60 mg every 6 months.^184,^ ^237,^ ^238^ One study was set in the United States,^236^ the second in the United States and Canada,^237^ and the third was a multicenter study that included sites in Europe, North America, Latin America, Australia, and New Zealand.^238^ A fourth dose-response study (N=226), also of postmenopausal osteoporotic women, was set in Japan.

#### Denosumab: Findings

Three studies were not powered to look at fractures as benefits and found no statistically significant differences in fractures (clinical, osteoporotic, or vertebral fracture).^236,^ ^237,^ ^239^ The fourth study was powered to evaluate vertebral, nonvertebral, and hip fractures (N=7,868).^238^ This large study demonstrated a statistically significant difference in incident vertebral fractures (2.3% vs. 7.2%; RR, 0.32 [95% CI, 0.26 to 0.41]), nonvertebral fractures (6.1% vs. 7.5%; RR, 0.80 [95% CI, 0.67 to 0.95]), hip fractures (0.7% vs. 1.1%; RR, 0.60 [95% CI, 0.37 to 0.97]). The study also reported a reduction in new clinical vertebral fractures and multiple new vertebral fractures.

#### Parathyroid Hormone: Overview of the Evidence

Two fair-quality studies^36,^ ^240^ which were also included in the prior systematic review by Nelson et al examined vertebral and nonvertebral fracture outcomes in patients receiving parathyroid hormone (an anabolic agent) versus placebo. One of these trials, the Treatment of Osteoporosis with Parathyroid Hormone (TOP) Study^36^ was conducted in postmenopausal women receiving daily PTH injections for 18 months versus placebo. Nineteen percent had a prior vertebral fracture. A second study^240^ was conducted among 437 men with a mean age of 59 years who were randomized to either placebo or one of two treatments arms of teriparatide (20 μg [the FDA-approved dose] or 40 μg daily) for an average of 11 months (treatment ranged from less than two months to 15 months). Prevalent fracture rates were not reported, nor was the reference range for the T-score (mean femoral neck T-score:-2.7). One new RCT^241^ among 40 postmenopausal women treated with teriparatide or placebo has been published since the systematic review by the 2010 review,^3^ but did not meet our inclusion criteria because of a high risk of bias.

#### Parathyroid Hormone Findings

##### Vertebral Fractures in Women

The TOP Study^36^ (N=2,532) evaluated effects of parathyroid hormone compared with placebo on risk of fractures in postmenopausal women with BMD T-score ≤−3.0 and no prevalent vertebral fractures or a T-score <-2.5 and one to four prevalent fractures (19% had prior vertebral fracture). Among women without a baseline fracture, parathyroid hormone produced a significant (0.7% vs. 2.1%; RR, 0.32 [95% CI, 0.14 to 0.75]) reduction in new radiographic vertebral fractures with parathyroid hormone.

##### Nonvertebral Fractures in Women

In an analysis of all participants with and without baseline fractures (N=2,532), there was no difference in risk of new nonvertebral fracture between the treatment and placebo arms (5.6% vs. 5.8%; RR, 0.97 [95% CI, 0.71 to 1.33]).

##### Vertebral Fractures in Men

No studies met our inclusion criteria to assess the effects of parathyroid hormone on vertebral fractures in men.

##### Nonvertebral Fractures in Men

In a fair-quality randomized, placebo-controlled trial (N=437), Orwoll and colleagues^240^ evaluated the effects of teriparatide at a dose of 20 μg (the FDA-approved dose, N=151 men) or 40 μg (N=139 men) and placebo (N=147) on risk of fractures in men with osteoporosis (mean baseline BMD femoral neck T-scores, -2.7). Reported findings show a reduction in nonvertebral fractures in both treatment groups compared with placebo, but the number of fractures was small and results did not reach statistical significance. Additionally, outcome assessments were limited by early termination of the study (mean duration of treatment was 11 months) because of a finding of osteosarcomas in routine animal toxicology studies.

### Key Question 4b How Does the Effectiveness of Pharmacotherapy for the Reduction of Fractures and Related Morbidity and Mortality Vary by Subgroup?

#### Bisphosphonates

We found no relevant results in included studies for subgroup analysis for zoledronic acid, etidronate, and ibandronate.

##### Alendronate

One study reported on a subset of osteopenic women (femoral neck T-score between -1.6 and -2.5) from both arms of the FIT.^205^ This subset of women had a relative risk of vertebral fracture of 0.59 (95% CI, 0.41 to 0.83, calculated; 2.7% vs. 4.6% rate of vertebral fractures for treatment vs. placebo); this figure is similar to findings from the parent FIT studies included in this update.^200^

##### Risedronate

One trial^223^ conducted among women age 70 or older, after a mean of 2.3 years follow up, reported an incidence of hip fracture of 3.9 percent in the placebo group and 2.8 percent in the treatment group (RR, 0.7; 95% CI, 0.6 to 0.9). In a post-hoc subgroup analysis of women ages 70 to 79 years without vertebral fracture at baseline, the incidence of hip fracture was 1.6 percent and 1.0 percent in the placebo and treatment groups, respectively (RR, 0.6; 95% CI, 0.3 to 1.2). Low numbers of fracture events could potentially explain the poor precision of estimates in women age 70 to 79 years.

#### Raloxifene

Subgroups of women, with and without a baseline vertebral fracture, did not different significantly in vertebral fracture outcomes, as reported in one article from the MORE study.^242^

#### Estrogen

Although we found no eligible evidence on estrogen, a recently updated review on hormone replacement therapy in primary care populations, unselected for osteoporosis or fracture risk, offers contextual information.^235^ The systematic review reported that some subgroup analyses indicated that time since menopause and age might modify the cardiovascular effects of hormone therapy. Younger women taking only estrogen had lower risks for myocardial infarction than older women relative to women using placebo. Younger women on estrogen only also had a reduced risk for all-cause mortality, whereas older women had an increased risk. Women who initiated estrogen plus progestin therapy closer to menopause did not have the elevated risk for myocardial infarction that women experienced who had started this therapy more than 20 years after menopause.

#### Denosumab

One trial of 7,808 osteoporotic women between the ages of 60 and 90 years reported variations in benefits by age, baseline BMD, and the combination of age and baseline BMD.^243-245^ The overall findings for the trial demonstrated effectiveness in reducing vertebral, nonvertebral, and hip fractures.^238^ Subgroup analysis for age demonstrated no statistically significant differences by age, when comparing women less than age 75 with women age 75 years or older (2.0% vs. 6.5%; RR, 0.30 [95% CI, 0.22 to 0.41] vs. 0.36 [3.1% vs. 8.6%; 95% CI, 0.25 to 0.53]; p for test of interaction = 0.48).^243^ Similarly, the trial demonstrated no statistically significant differences by baseline femoral neck T-score, when comparing those with T-scores at or lower than -2.5 with those with T-scores higher than -2.5 (3.1% vs. 9.9%; RR, 0.31 [95% CI, 0.22 to 0.44] vs. 1.9% vs. 5.6%; 0.34 [95% CI, 0.24 to 0.47]; p for test of interaction = 0.64).^243^ The trial reported no statistically significant differences when comparing combined risk.^244^

#### Parathyroid Hormone

The two eligible trials did not compare subgroups. However, one trial reported results in women without a baseline fracture and in women with a prior fracture.^36^ Women on parathyroid hormone who had a prior fracture had a lower risk of new fractures (4.2% vs. 8.9%; RR, 0.47; [95% CI, 0.22 to 0.98]) than women on placebo, as did women without a prior fracture (0.7% vs. 2.1%; RR, 0.32 [95% CI, 0.14 to 0.75]).

### Key Question 5 What Are the Harms Associated With Pharmacotherapy?

We present summary results in text below. Appendix F includes detailed evidence for alendronate (Appendix F Table 16), zoledronic acid (Appendix F Table 17), risedronate (Appendix F Table 18), etidronate (Appendix F Table 19), ibandronate (Appendix F Table 20), raloxifene (Appendix F Table 21), denosumab (Appendix F Table 22), and parathyroid hormone (Appendix F Table 23). Appendix H includes forest plots for meta-analyses.

#### Bisphosphonates: Overview of the Evidence

The 2010 review relied largely on systematic reviews to present evidence on harms.^3^ To ensure that we captured all relevant evidence, we relied on our searches, handsearches from included systematic reviews, particularly from a recent systematic review on the efficacy and effectiveness of drugs for osteoporosis.^221^

##### Alendronate

Sixteen fair- and good-quality studies reported on harms: 14 studies in postmenopausal women^199-204,^ ^246-253^ and 2 studies in combined populations of women and men.^254,^ ^255^ We excluded several studies that were included in previous reviews for wrong study population,^215,^ ^256-261^ wrong intervention,^262^ wrong comparator,^263-265^ wrong outcome,^266^ wrong setting,^267,^ ^268^ and wrong study design,^269^ an older review that has been subsequently updated,^270^ and high risk of bias.^216,^ ^265,^ ^271-273^ Nine studies reported on discontinuations because of adverse effects.^199-202,^ ^204,^ ^246,^ ^252-254^ Five studies reported serious adverse effects.^202,^ ^250,^ ^252-254^ Death was reported as a harm in two studies.^200,^ ^250^ Several gastrointestinal (GI) events were reported, including abdominal pain, reflux, ulcers, and esophagitis. The most commonly reported across studies was any upper GI adverse events.^200,^ ^202,^ ^204,^ ^250-255^ Three studies reported cardiovascular outcomes, including chest pain,^246^ myocardial infarction,^249^ and atrial fibrillation.^248^

##### Zoledronic Acid

Four fair- or good-quality studies reported on harms: three studies in postmenopausal women^217,^ ^274,^ ^275^ and one in men.^218^ We excluded several studies that were included in previous reviews for wrong study population,^219,^ ^220,^ ^222,^ ^276-280^ wrong study design,^281^ wrong comparator,^282^ and an older review that has been subsequently updated.^270^

Only one study reported on discontinuation of zoledronic acid due to adverse events,^217^ while three studies reported serious adverse events.^217,^ ^218,^ ^275^ Three studies reported on osteonecrosis of the jaw^218,^ ^274,^ ^275^ and two on atrial fibrillation.^274,^ ^275^ Three studies examined myalgia and arthralgia.^218,^ ^274,^ ^275^

##### Risedronate

Six trials met eligibility criteria for harms. These include four trials previously described.^223-226^ Two additional trials were also conducted among postmenopausal women, and we rated them as fair quality.^202,^ ^283^ One trial, conducted at multiple sites in Europe and Brazil, assessed 5 mg of risedronate for 3 months compared with placebo.^202^ Nearly half of the study population had prior fractures. The other trial assessed 5 mg of risedronate for 36 weeks, and was conducted in Japan.^283^ Women with prevalent fracture were not excluded from this study and the mean number of prevalent fractures at baseline was 0.3 (standard deviation [SD], 0.8) in the placebo group and 0.2 (SD, 0.5) in the risedronate group.

##### Etidronate

Two fair-quality studies reported on harms (N=206).^228,^ ^229^ Both reported on the rates of discontinuation and GI adverse events.^228,^ ^229^ One trial reported on serious adverse events and infection as an adverse event.^228^

##### Ibandronate

Seven fair-quality studies of ibandronate reported on harms (N=2,115).^284-290^ All were conducted in postmenopausal women with no prior fractures^285,^ ^286,^ ^289,^ ^290^ or with unknown prior fracture history.^285,^ ^287,^ ^288^ These studies differed in the menopausal categories of women enrolled: at least 1 year postmenopausal (two studies),^284,^ ^285^ at least 3 years postmenopausal (one study),^287^ at least 5 years postmenopausal (two studies),^288,^ ^290^ at least 10 years postmenopausal (one study),^286^ and 1 to 10 years postmenopausal (one study).^289^ The mean baseline T-scores for the seven studies ranged from -3.2 to 1.03. The mean age of participants ranged between ages 54 and 67 years. Included trials evaluated varying dosages and time periods. One trial evaluated 50 to 150 mg monthly for 3 months,^287^ one evaluated 0.25 mg to 2.0 mg every 3 months over a 1-year period,^290^ and one evaluated daily dosages of 0.25 to 50 mg over a 1-year period. Four publications reported on studies that evaluated ibandronate over a 2-year period, including two trials that evaluated daily dosages of 0.5 to 2.5 mg,^285,^ ^288^ one that evaluated intermittent dosages of 20 mg,^288^ one that evaluated weekly dosages of 5 to 20 mg,^289^ and one that evaluated monthly dosages of 150 mg.^284^ Six of the included trials were set in Europe^284,^ ^286-290^ and one in the United States and Canada.^285^ Four trials 284-287 reported on the discontinuation of participants by treatment group and two studies reported only the number of discontinuations overall.^289,^ ^290^ Four trials ^284-287^ reported on serious adverse events by treatment group and two studies reported only serious adverse events overall.^289,^ ^290^ Six studies evaluated the risk of GI adverse events.^285-290^ Only one trial reported on infection;^286^ two reported on deaths.^287,^ ^288^

#### Bisphosphonates: Findings

##### Discontinuations Due to Adverse Events

The 2010 review reported no differences in risk of discontinuation between study arms for any bisphosphonate drug. Our updated analysis of 20 trials and 17,369 participants found that the pooled risk was not significantly different for any individual drug or overall (RR, 0.99; 95% CI, 0.91 to 1.07; I^2^, 0%) (Appendix H Figure 25). Alternate methods of pooling that account for the contribution of a single trial^202^ to two arms yielded very similar results (11.5% vs. 11.8%; RR, 0.98; 95% CI, 0.89 to 1.08; I^2^, 0%).

##### Serious Adverse Events

The 2010 review did not summarize the evidence on overall serious adverse events. Our pooled estimate of effect of 17 trials and 11,745 participants showed no statistically significant differences for any individual drug or overall (RR, 0.98; 95% CI, 0.92 to 1.04; I^2^, 0%) (Appendix H Figure 26). Alternate methods of pooling that account for the contribution of a single trial^202^ to two arms yielded identical results (21.0% vs. 23.4%; RR, 0.97; 95% CI, 0.89 to 1.07; I^2^, 0%).

##### Gastrointestinal Adverse Events

The 2010 review reported a higher risk of mild upper GI events for etidronate and pamidronate than placebo but not for other drugs. The review noted a higher risk of esophageal ulceration for etidronate when including individuals without osteoporosis in the control group, but not otherwise; it also reported no differences in esophageal ulcerations for any other drug. Finally, it noted that the FDA has called for further research on the risk of esophageal adenocarcinoma.

Our updated analysis found that studies vary widely in the definition and reporting of GI adverse events. Some studies specify upper GI events overall, with no additional detail, whereas other studies provide details on individual complaints such as dyspepsia and abdominal pain. We pooled 13 trials with 20,485 participants that reported upper GI events and found no differences for any individual drug or overall (RR, 1.01; 95% CI, 0.98 to 1.05; I^2^, 0%) (Appendix H Figure 27). Alternate methods of pooling that account for the contribution of a single trial^202^ to two arms yielded very similar results (35.3% vs. 35.6%; RR, 1.01; 95% CI, 0.98 to 1.05; I^2^, 0%), as did an analysis that included a wider variety of outcomes in addition to upper GI events (all GI adverse events, abdominal pain, severe GI events, and esophagitis (RR, 1.02; 95% CI, 0.98 to 1.05; I^2^, 0%). We found no differences by study arms in individual study reports of ulcers^200,^ ^202,^ ^251,^ ^254,^ ^255^ and no reports of esophageal adenocarcinoma.

##### Cardiovascular Events

The 2010 review noted no clear evidence of an association between bisphosphonate use and atrial fibrillation. Our review found one study of alendronate reporting a higher incidence of atrial fibrillation in women in the intervention arm, but the association was not statistically significant (2.5% vs. 2.2%; RR, 1.14 [95% CI, 0.83 to 1.56]),^248^ and one study of zoledronic acid in men with a similarly nonsignificant association but higher incidence of atrial fibrillation (1.2% vs. 0.8%; RR, 1.45; 95% CI, 0.46 to 4.56).^218^ Two studies of women reported no cases of atrial fibrillation.^274,^ ^275^ A case control study using a Danish registry studied the association of bisphosphonates and atrial fibrillation and reported a relative risk of 0.75 (95% CI, 0.49 to 1.16; 3.2% vs. 2.9%) for new users.^247^ Two ineligible systematic reviews^291,^ ^292^ sought additional data from two sets of investigators not included in their published results.^236,^ ^293^ Estimates of effect for both studies spanned the null (RR, 1.11, 95% CI, 0.69 to 1.90 for data from Karam et al and RR, 0.99, 95% CI, 0.45 to 2.16 for unpublished data from Leiwecki et al).

##### Osteonecrosis of the Jaw

The 2010 review noted that the FDA published a case series listing osteonecrosis of the jaw, but that most cases occurred in cancer patients. The 2010 review noted that the FIT found one case each in the active and placebo arms. In our update, three studies (one in men and two in women) reported that they found no cases of osteonecrosis of the jaw.^218,^ ^274,^ ^275^ We also identified several additional studies of osteonecrosis of the jaw that did not meet our inclusion criteria; the study populations had a high proportion of subjects with prevalent vertebral fractures or secondary causes of osteoporosis.^278,^ ^281,^ ^282,^ ^294-298^

A systematic review, which also did not meet our inclusion criteria because it included populations outside the purview of this report, reported a higher incidence of osteonecrosis of the jaw with intravenous bisphosphonates and with greater duration (these findings are not restricted to primary prevention populations only).^299^ The review noted, however, that the incidence of osteonecrosis of the jaw ranged between 1.04 and 69 per 100,000 patient-years for oral bisphosphonate and between 0 and 90 per 100,000 patient-years for intravenous bisphosphonates. The authors note that the incidence is marginally higher than the estimated incidence in the general population of <0.001 percent. In comparison, the authors note that the incidence in the oncology patient population ranges from 0 to 12,222 per 100,000 patient-years.

##### Atypical Fractures of the Femur

The FDA added a warning label to bisphosphonates regarding the potential risk of atypical femur fractures; the communication also noted the rarity of the condition (fewer than 1% of all hip and femur fractures), the lack of evidence establishing causality, and the fact that atypical femur fractures have been reported primarily in patients taking bisphosphonates. No included studies in our review reported atypical femur fracture outcomes. Although we identified several additional studies reporting on atypical femur fractures, they did not meet inclusion criteria (wrong population,^300,^ ^301^ wrong comparator,^302,^ ^303^ wrong intervention,^304^ wrong design).^263^

Two excluded systematic reviews, published in 2013^302^ and 2015^303^ respectively, included a partially overlapping set of studies. Both reported an increased risk of atypical femur fractures, with odds ranging from 1.70 (95% CI, 1.22 to 2.37)^302^ to 1.99 (95% CIs, 1.28 to 3.10).^303^ Both reviews reported very high heterogeneity (I^2^ exceeding 80 percent), but only one review explored heterogeneity in greater detail.^302^ Specifically, Gedmintas et al explored subgroup analyses by outcome definition and found a continued high risk with more restrictive and validated measurement of outcomes, but with varying precision and heterogeneity. These results suggest an increased risk for atypical femur fractures, but the extent and applicability of this risk to a primary prevention population is unclear.

##### Kidney Failure

The FDA added a warning label to Reclast (zoledronic acid) in 2011 to note contraindication in patients with creatinine clearance less than 35 mL/min or in patients with evidence of acute renal impairment.^305^ No included studies in our review reported kidney failure outcomes.

#### Raloxifene: Overview of the Evidence

As was true for benefits of raloxifene, harms reported in the 2010 review were based on results from two studies, the MORE and RUTH trials.^3^ We include findings from six studies, with only the MORE study reported in multiple articles.^231,^ ^232,^ ^242,^ ^246,^ ^306-313^ As noted previously, we do not include the RUTH trial as evidence because it did not meet our inclusion criterion that participants be at increased risk for fracture.

#### Raloxifene: Findings

Pooled estimates of women followed from 1 to 4 years found no increased risk of discontinuation of treatment because of adverse events (12.6% vs. 11.2%; RR, 1.12; 95% CI, 0.98 to 1.28; I^2^, 0%, 6 trials, N=6,438) (Appendix H Figure 28). The pooled analysis suggests a higher rate of deep vein thromboses in the intervention arm (0.7% vs. 0.3%; RR, 2.14; 95% CI, 0.99 to 4.66; I^2^, 0%, 3 trials, N=5,839) (Appendix H Figure 29). However, among these studies, the large MORE trial found an increased risk after 4 years (0.8% vs. 0.3%; RR, 2.52; 95% CI, 1.11 to 5.71), whereas the other two included studies were much smaller and followed women for only 2 years.^307,^ ^308^ In contrast, the 2010 review found a statistically significant increase in thromboembolic events (RR, 1.60; 95% CI, 1.15 to 2.23). Similar to the 2010 review, we found no association between raloxifene and CHD, stroke, or endometrial cancer, an increased risk for hot flashes, (11.2% vs. 7.6%; RR, 1.42; 95% CI, 1.22 to 1.66; I^2^, 0%, 5 trials; N=6,249; Appendix H Figure 30) and no statistically significant increased risk of leg cramps (8.0% vs. 4.8%; RR, 1.41; 95% CI, 1.41; 0.92 to 2.14; I^2^, 67%, 3 trials; N=6,000) (Appendix H Figure 31).

#### Estrogen

The 2010 review discussed the results of the WHI. As noted, the WHI did not meet inclusion criteria for our update. A recently completed review on the benefits and harms of estrogen therapy, with and without progestin, in primary care populations provides important contextual information.^235^ Compared with women on placebo, women on estrogen, over a 5-year followup, experienced a higher rate of gallbladder events, stroke, and venous thromboembolism. The risk for urinary incontinence was increased during a followup of 1 year. Compared with women on placebo, women on estrogen plus progestin were found to have a higher risk of invasive breast cancer, CHD, probable dementia, gallbladder events, stroke, and venous thromboembolism. The risk for urinary incontinence was increased during a followup of 1 year. Additionally, one high risk-of-bias safety trial compared an estrogen only arm with a placebo arm (N=193) and found no statistically significant differences in discontinuations attributable to adverse events (10% vs. 10%; RR, 0.98 [95% CI, 0.37 to 2.58]), serious adverse events (12% vs. 10%; RR, 1.19 [95% CI, 0.46 to 305]), or upper gastrointestinal events over 2 years (30% vs. 22%; RR, 1.37 [95% CI, 0.77 to 2.44]).^216^

#### Denosumab: Overview of the Evidence

Four studies reported on harms.^209,^ ^236-239,^ ^314^ All were conducted in postmenopausal women with low bone mass or osteoporosis and were phase 2 or phase 3 studies for the FREEDOM trial.

#### Denosumab: Findings

Pooled estimates of effect from three trials with 8,451 participants suggest no differences in the rates of discontinuation due to adverse events (2.4% vs. 2.1%; RR, 1.14 [95% CI, 0.85 to 1.52]; I^2^, 0%) (Appendix H Figure 32) or serious adverse events (23.8% vs. 23.9%; RR, 1.12; 95% CI, 0.88 to 1.44; I^2^, 14.1%) (Appendix H Figure 33). Although treatment arms had higher rates of serious infections than control arms, confidence intervals for the pooled estimate were wide (4.0% vs. 3.3%; RR, 1.89; [95% CI, 0.61 to 5.91]; I^2^, 40.09%) (Appendix H Figure 34). A Peto odds ratio estimate, to account for zero events in one trial, also resulted in an estimate of effect with wide confidence intervals (Peto odds: 2.12; 95% CI, 0.72 to 6.14). A detailed analysis of serious infections identified these differences as arising from a higher rate of cellulitis and erysipelas in the denosumab arm (RR, 14.96 [95% CI, 1.98 to 113.21]).^314^ Two trials evaluated the risk of rash or eczema. Both reported a higher incidence in the treatment arm (RR for eczema, 1.81 [95% CI, 1.34 to 2.44; 3.0% vs. 1.7%]^238^ and rash, 2.82 [95% CI, 1.04 to 7.64; 8.5% vs. 3.0%]^237^). The studies reported wide confidence intervals spanning the null for GI events^236,^ ^237^ and cardiac or cardiovascular events.^236,^ ^238^ Although the large FREEDOM trial reported fewer deaths in the treatment arm, the difference in rates did not reach statistical significance (1.8% vs. 2.3%; RR, 0.78 [95% CI, 0.57 to 1.06]).^238^ One study reported no occurrences of osteonecrosis of the jaw events.^239^

#### Parathyroid Hormone: Overview of the Evidence

Two fair-quality studies^36,^ ^240^ reported adverse events in women and men receiving parathyroid hormone compared to placebo. The TOP Study^36^ was conducted in postmenopausal women receiving daily PTH injections for 18 months versus placebo. Another RCT^240^ was conducted among 437 men who were randomized to either placebo or one of two dosages of teriparatide (20 or 40 μg daily) for an average of 11 months (treatment ranged from <2 months to 15 months).

#### Parathyroid Hormone: Findings

##### Harms in Women

The TOP Study^36^ reported adverse events and discontinuation of study participants in the treatment and placebo groups. Among 2,532 postmenopausal women, the treatment group had higher rates of discontinuation due to adverse events when compared with the placebo group (30.2% vs. 24.6%; RR, 1.22 [95% CI, 1.08 to 1.40]). Other reported adverse events, which were related largely to nausea and headache, were higher in the treatment group (22.6% vs. 9.1%; RR, 2.47 [95% CI, 2.02 to 3.03]).

##### Harms in Men

In an RCT among 437 men,^240^ both the 20-microgram and 40-microgram treatment groups had a higher proportion of withdrawals than the placebo group (9.2% vs. 12.9% vs. 4.8%). The risk of withdrawals was statistically significant higher in the 40-microgram treatment group than the placebo group (RR, 2.72 [95% CI, 1.17 to 6.3]), although the number of withdrawals was small among all three groups. Cancers were reported in two groups (3/147 in the placebo group and 3/151 in the 20- μg treatment group), but none was reported as osteosarcomas. Evidence on harms associated with PTH is limited due to sparse data from two RCTs and incomplete descriptions of the criteria for an adverse event and therefore, inconsistent reporting of adverse events.