# Appendix H Forest Plots of Meta-Analyses

Appendix H Figure 1 Osteoporosis Risk Assessment Instrument (ORAI) in Women

Appendix H Figure 1 is a forest plot presenting the results of a meta-analysis combining the results from 10 trials of the Osteoporosis Risk Assessment Instrument (ORAI) in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.651; 95% confidence interval of 0.596 to 0.705; p<0.001; I2=97.83%.The number of events/treated is 111,302/16,780.

Appendix H Figure 2 Osteoporosis Index of Risk (OSIRIS) in Women

Appendix H Figure 2 is a forest plot presenting the results of a meta-analysis combining the results from 5 trials of the Osteoporosis Index of Risk (OSIRIS) in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.680; 95% confidence interval of 0.639 to 0.721; p<0.001; I2=83.6%. The number of events/treated is 3,678/5,649.

Appendix H Figure 3 Osteoporosis Self-Assessment Tool in Asians (OSTA) in Women

Appendix H Figure 3 is a forest plot presenting the results of a meta-analysis combining the results from 4 trials of the Osteoporosis Self-Assessment Tool in Asians (OSTA) in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.765; 95% confidence interval of 0.628 to 0.901; p<0.001; I2=98.5%. The number of events/treated is 2,022/2,692.

Appendix H Figure 4 Osteoporosis Self-Assessment Tool (OST) in Women

Appendix H Figure 4 is a forest plot presenting the results of a meta-analysis combining the results from 13 trials of the Osteoporosis Self-Assessment Tool (OST) in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.646; 95% confidence interval of 0.601 to 0.691; p<0.001; I2=98.88%. The number of events/treated is 31,112/44,323.

Appendix H Figure 5 Simple Calculated Osteoporosis Risk Estimation (SCORE) in Women

Appendix H Figure 5 is a forest plot presenting the results of a meta-analysis combining the results from 8 trials of Simple Calculated Osteoporosis Risk Estimation (SCORE) in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.698; 95% confidence interval of 0.685 to 0.711; p=0.070; I2=46.45%. The number of events/treated is 10,782/15,362.

Appendix H Figure 6 OST in Men

Appendix H Figure 6 is a forest plot presenting the results of a meta-analysis combining the results from 7 trials of the Osteoporosis Self-Assessment Tool (OST) in men. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.758; 95% confidence interval of 0.711 to 0.804; p<0.001; I2=93.2%. The number of events/treated is 5,678/7,798.

Appendix H Figure 7 Male Osteoporosis Risk Estimation Score (MORES) in Men

Appendix H Figure 7 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of the Male Osteoporosis Risk Estimation Score (MORES) in men. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.797; 95% confidence interval of 0.714 to 0.879; p<0.001; I2=97.64%. The number of events/treated is 3,723/4,828.

Appendix H Figure 8 Quantitative Ultrasound for Screening Osteoporosis for Women

Appendix H Figure 8 is a forest plot presenting the results of a meta-analysis combining the results from 7 trials of the quantitative ultrasound for screening osteoporosis for women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.768; 95% confidence interval of 0.719 to 0.813; p<0.001; I2=82.25%. The number of events/treated is 1,509/1,969.

Appendix H Figure 9 Quantitative Ultrasound for Screening Osteoporosis for Men

Appendix H Figure 9 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of the quantitative ultrasound for screening osteoporosis for men. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.804; 95% confidence interval of 0.665 to 0.943; p<0.001; I2=98.17%. The number of events/treated is 3,642/5,142.

Appendix H Figure 10 FRAX Without Bone Mineral Density Testing for Predicting Major Osteoporotic Fractures in Men

Appendix H Figure 10 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of FRAX without bone mineral density testing for predicting major osteoporotic fractures in men. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.624; 95% confidence interval of 0.613 to 0.635; p<0.001; I2=40.49%. The number of events/treated is 8,728/13,970.

Appendix H Figure 11 FRAX Without Bone Mineral Density Testing for Predicting Hip Fractures in Men

Appendix H Figure 11 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of FRAX without bone mineral density testing for predicting hip fractures in men. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.725; 95% confidence interval of 0.684 to 0.767; p<0.001; I2=96.73%. The number of events/treated is 10,098/13,970.

Appendix H Figure 12 FRAX With Bone Mineral Density Testing for Predicting Major Osteoporotic Fractures in Men

Appendix H Figure 12 is a forest plot presenting the results of a meta-analysis combining the results from 4 trials of FRAX with bone mineral density testing for predicting major osteoporotic fractures in men. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.670; 95% confidence interval of 0.662 to 0.677; p=0.505; I2=0%. The number of events/treated is 10,606/15,842.

Appendix H Figure 13 FRAX With Bone Mineral Density for Predicting Hip Fractures in Men

Appendix H Figure 13 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of FRAX with bone mineral density testing for predicting hip fractures in men. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.760; 95% confidence interval of 0.720 to 0.799; p<0.001; I2=96.67%. The number of events/treated is 10,554/13,970.

Appendix H Figure 14 FRAX Without Bone Mineral Density Testing for Predicting Major Osteoporotic Fractures in Women

Appendix H Figure 14 is a forest plot presenting the results of a meta-analysis combining the results from 17 trials of FRAX without bone mineral density testing for predicting major osteoporotic fractures in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.659; 95% confidence interval of 0.630 to 0.687; p<0.001; I2=99.16%. The number of events/treated is 98,277/158,897.

Appendix H Figure 15 FRAX Without Bone Mineral Density Testing for Predicting Hip Fractures in Women

Appendix H Figure 15 is a forest plot presenting the results of a meta-analysis combining the results from 12 trials of FRAX without bone mineral density testing for predicting hip fractures in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.763; 95% confidence interval of 0.717 to 0.810; p<0.001; I2=99.79%. The number of events/treated is 149,318/190,795.

Appendix H Figure 16 FRAX With Bone Mineral Density Testing for Predicting Major Osteoporotic Fractures in Women

Appendix H Figure 16 is a forest plot presenting the results of a meta-analysis combining the results from 12 trials of FRAX with bone mineral density testing for predicting major osteoporotic fractures in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.696; 95% confidence interval of 0.680 to 0.713; p<0.001; I2=92.07%. The number of events/treated is 43,420/62,054.

Appendix H Figure 17 FRAX With Bone Mineral Density Testing for Predicting Hip Fractures in Women

Appendix H Figure 17 is a forest plot presenting the results of a meta-analysis combining the results from 10 trials of FRAX with bone mineral density testing for predicting hip fractures in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.788; 95% confidence interval of 0.764 to 0.813; p<0.001; I2=99.06%. The number of events/treated is 133,731/161,984.

Appendix H Figure 18 FRAX Without Bone Mineral Density Testing for Predicting Major Osteoporotic Fractures in Both Sexes

Appendix H Figure 18 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of FRAX without bone mineral density testing for predicting major osteoporotic fractures in both sexes. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.665; 95% confidence interval of 0.660 to 0.670; p=0.151; I2=47.11%. The number of events/treated is 44,397/66,777.

Appendix H Figure 19 FRAX With Bone Mineral Density Testing for Predicting Major Osteoporotic Fractures in Both Sexes

Appendix H Figure 19 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of FRAX with bone mineral density testing for predicting major osteoporotic fractures in both sexes. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.694; 95% confidence interval of 0.686 to 0.701; p=0.035; I2=70.28%. The number of events/treated is 46,281/66,777.

Appendix H Figure 20 Garvan Fracture Risk Calculator With Bone Mineral Density Testing for Predicting Major Osteoporotic Fractures in Women

Appendix H Figure 20 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of Garvan Fracture Risk Calculator with bone mineral density testing for predicting major osteoporotic fractures in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.676; 95% confidence interval of 0.640 to 0.711; p=0.002; I2=84.61%. The number of events/treated is 4,195/6,174.

Appendix H Figure 21 Garvan Fracture Risk Calculator With Bone Mineral Density Testing for Predicting Hip Fractures in Women

Appendix H Figure 21 is a forest plot presenting the results of a meta-analysis combining the results from 4 trials of Garvan Fracture Risk Calculator with bone mineral density testing for predicting hip fractures in women. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.725; 95% confidence interval of 0.657 to 0.792; p<0.001; I2=97.26%. The number of events/treated is 5,626/7,449.

Appendix H Figure 22 Vertebral Fracture Outcomes for Bisphosphonates

Appendix H Figure 22 is a forest plot presenting the results of a meta-analysis combining the results from 5 trials of vertebral fracture outcomes for bisphosphonates. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.565; 95% confidence interval of 0.410 to 0.779; p=0.706; I2=0%. The overall number of events/treated is 57/2,774.The overall events/control is 100/2,659.

Appendix H Figure 23 Nonvertebral Fracture Outcomes for Bisphosphonates

Appendix H Figure 23 is a forest plot presenting the results of a meta-analysis combining the results from 8 trials of nonvertebral fracture outcomes for bisphosphonates. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.839; 95% confidence interval of 0.763 to 0.923; p=0.530; I2=0%. The overall number of events/treatment is 877/9,825. The overall number of events/control is 704/6,613.

Appendix H Figure 24 Hip Fracture Outcomes for Bisphosphonates

Appendix H Figure 24 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of hip fracture outcomes for bisphosphonates. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.700; 95% confidence interval of 0.444 to 1.106; p=0.811; I2=0%. The overall number of events/treated is 35/4,937. The overall number of events/control 39/4,051.

Appendix H Figure 25 Discontinuation Due to Adverse Events for Bisphosphonates vs. Placebo

Appendix H Figure 25 is a forest plot presenting the results of a meta-analysis combining the results from 21 trials of discontinuation due to adverse events for bisphosphonates vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.988; 95% confidence interval of 0.911 to 1.072; p=0.534; I2=0%. The overall number of events/treated is 1,040/9,047. The overall number of events/control 966/8,430.

Appendix H Figure 26 Serious Adverse Events for Bisphosphonates vs. Placebo

Note: Greenspan et al. present data on drug-related adverse events (serious adverse events were not drug related)

Appendix H Figure 26 is a forest plot presenting the results of a meta-analysis combining the results from 18 trials of serious adverse events for bisphosphonates vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 0.978; 95% confidence interval of 0.916 to 1.044; p=0.952; I2=0%. The overall number of events/treated is 1,296/6,171. The overall number of events/control 1,316/5,682.

Appendix H Figure 27 Upper Gastrointestinal Events for Bisphosphonates vs. Placebo

Appendix H Figure 27 is a forest plot presenting the results of a meta-analysis combining the results from 14 trials of upper gastrointestinal events for bisphosphonates vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 1.014; 95% confidence interval of 0.979 to 1.050; p=0.835; I2=0%. The overall number of events/treated is 3,694/10,463. The overall number of events/control 3,598/10,130.

Appendix H Figure 28 Discontinuations Due to Adverse Events for Raloxifene vs. Placebo

Appendix H Figure 28 is a forest plot presenting the results of a meta-analysis combining the results from 6 trials of discontinuations due to adverse events for raloxifene vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 1.121; 95% confidence interval of 0.981 to 1.281; p=0.533; I2=0%. The overall number of events/treated is 410/3,250. The overall number of events/control 356/3,188.

Appendix H Figure 29 Deep Vein Thrombosis for Raloxifene vs. Placebo

Appendix H Figure 29 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of deep vein thrombosis for raloxifene vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 2.144; 95% confidence interval of 0.986 to 4.662; p=0.438; I2=0%. The overall number of events/treated is 20/2,913. The overall number of events/control 9/2,926.

Appendix H Figure 30 Hot Flashes for Raloxifene vs. Placebo

Appendix H Figure 30 is a forest plot presenting the results of a meta-analysis combining the results from 5 trials of hot flashes for raloxifene vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 1.423; 95% confidence interval of 1.217 to 1.664; p=0.736; I2=0%. The overall number of events/treated is 354/3,158. The overall number of events/control 234/3,091.

Appendix H Figure 31 Leg Cramps for Raloxifene vs. Placebo

Appendix H Figure 31 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of leg cramps for raloxifene vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 1.406; 95% confidence interval of 0.923 to 2.142; p=0.048; I2=67.1%. The overall number of events/treated is 243/3,031. The overall number of events/control 143/2,969.

Appendix H Figure 32 Discontinuations Due to Adverse Events for Denosumab vs. Placebo

Appendix H Figure 32 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of discontinuations due to adverse events for denosumab vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 1.139; 95% confidence interval of 0.853 to 1.522; p=0.755; I2=0%. The overall number of events/treated is 105/4,364. The overall number of events/control 84/4,087.

Appendix H Figure 33 Serious Adverse Events for Denosumab vs. Placebo

Appendix H Figure 33 is a forest plot presenting the results of a meta-analysis combining the results from 4 trials of serious adverse events for denosumab vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 1.121; 95% confidence interval of 0.876 to 1.435; p=0.322; I2=14.13%. The overall number of events/treated is 1,076/4,522. The overall number of events/control 989/4,141.

Appendix H Figure 34 Serious Infections for Denosumab vs. Placebo

Appendix H Figure 34 is a forest plot presenting the results of a meta-analysis combining the results from 3 trials of serious infections for denosumab vs. placebo. The figure shows that the results of the quantitative synthesis is a pooled estimate of 1.894; 95% confidence interval of 0.607 to 5.910; p=0.188; I2=40.09%. The overall number of events/treated is 173/4,364. The overall number of events/control 134/4,087.