# Appendix G Ongoing Trials and Completed Not Published Trials

Appendix G Table 1 Completed Trials

Principal Investigators | Location | Population | Approximate Size | Investigations | Outcomes | Status as of 2017
Hyoung-Moo Park | Seoul, Republic of Korea | Women, Postmenopausal | 150 | Risedronate Cominbe, Risedronate., Pacebo, Pacebo | Proportion of patients with 25(OH)D level < 20 ng/mL at 16 weeks. [Time Frame: 16 weeks form first drug administration.] [Designated as safety issue: No] | Completed, Not Published
Eli Lilly | United States, Argentina, Australia, Austria, Belgium, Canada, Czech Republic, Denmark, Finland, France, Germany, Hungary, Israel, Italy, Mexico, Netherlands, New Zealand, Norway, Poland, Singapore, Slovakia, Slovenia, Spain, Sweden, United Kingdom | Women, < 80 years old, Postmenopausal with Osteoporosis | | Raloxifene HCL 60 mg, Raloxifene 120mg, Pacebo | To establish the effect of long-term treatment with raloxifene, compared with placebo, on the rate of new vertebral fractures in osteoporotic postmenopausal women with and without prevalent vertebral fractures by spinal x-ray | Completed, Not Published
Eli Lilly and Company | United States | Female,^45^ Years to 85 Years (Adult, Senior) With Osteoporosis | | Teriparatide and Roloxifene, Roloxifene, Pacebo | The study will evaluate any side effects that may be associated with the two drugs and may help to determine whether teriparatide and raloxifene together can help patients with osteoporosis more than teriparatide alone | Completed, Not Published
Clifford Rosen, MD St. Joseph Hospital Health Center | United States | Female 45 – 70 years, with osteoporosis | 50 | Teriparatide, Pacebo | Bone mineral density will be measured at 6 and 12 months | Completed, Not Published

Appendix G Table 2 Ongoing Trials

Principal Investigators | Location | Population | Approximate Size | Investigations | Outcomes | Status as of 2017
Sudhaker D Rao, MD, Henry Ford Health System | United States | Women, 50 years and older | 1000 | (Risedronate) Pathogenesis of Atypical Femur Fractures on Long Term Bisphosphonate Therapy | Determine the prevalence of PBD and/or Atypical Femoral Fractures (AFF) in patients | Recruiting
Susan L. Greenspan, University of Pttsburgh | United States | Women, 65 Years and older | 1000 | (Zoledronic Acid) Zoledronic Acid for Osteoporotic Fracture Prevention (ZEST II) | Total non-traumatic incident clinical fractures (vertebral and nonvertebral) | Recruiting
Eizabeth Shane, Columbia University | United States | Premenopausal Women | 40 | (Teriparatide) Forteo Trial on Idiopathic Osteoporosis in Premenopausal Women | Change in lumbar spine bone mineral density (LS-BMD) [Time Frame: Baseline and 12 months] [Designated as safety issue: Yes] | Recruiting
Susan L. Greenspan, University of Pttsburgh | United States | Men and Women 65 years and older | 212 | Preventing Osteoporosis Using Denosumab (PROUD) | Increased bone density of the total hip/spine | Recruiting