# Appendix F Evidence Tables

Appendix F Table 1 Characteristics and Results of Studies of Risk Prediction Instruments for Identifying Osteoporosis: Part 1

Appendix F Table 2 Characteristics and Results of Studies of Risk Prediction Instruments for Identifying Osteoporosis: Part 2

Appendix F Table 3 Characteristics and Results of Studies of Risk Prediction Instruments for Identifying Osteoporosis: Part 3

Appendix F Table 4 Characteristics and Results of Studies of Risk Prediction Instruments for Identifying Osteoporosis: Part 4

Appendix F Table 5 Characteristics and Results of Studies of Risk Prediction Instruments for Identifying Osteoporosis: Part 5

Appendix F Table 6 Characteristics And Results Of Imaging Studies Identifying Bone Density Status: Part 1

Appendix F Table 7 Characteristics And Results Of Imaging Studies Predicting Fractures: Part 2

Appendix F Table 8 Characteristics And Results Of Risk Prediction Instruments Predicting Fractures

Appendix F Table 9 Fracture Outcomes Of Placebo-Controlled Primary Prevention Trials Of Alendronate

Appendix F Table 10 Fracture Outcomes Of Placebo-Controlled Primary Prevention Trials Of Zoledronic Acid

Appendix F Table 11 Fracture Outcomes Of Placebo-Controlled Primary Prevention Trials Of Risedronate

Appendix F Table 12 Fracture Outcomes Of Placebo-Controlled Primary Prevention Trials Of Etidronate

Appendix F Table 13 Fracture Outcomes Of Placebo-Controlled Primary Prevention Trials Of Raloxifene

Appendix F Table 14 Fracture Outcomes Of Placebo-Controlled Primary Prevention Trials Of Denosumab

Appendix F Table 15 Fracture Outcomes Of Placebo-Controlled Primary Prevention Trials Of Parathyroid Hormone In Women And Men

Appendix F Table 16 Harm Outcomes Of Placebo-Controlled Primary Prevention Trials Of Alendronate

Appendix F Table 17 Harm Outcomes Of Placebo-Controlled Primary Prevention Trials Of Zoledronic Acid

Appendix F Table 18 Harm Outcomes Of Placebo-Controlled Primary Prevention Trials Of Risedronate

Appendix F Table 19 Harm Outcomes Of Placebo-Controlled Primary Prevention Trials Of Etidronate

Appendix F Table 20 Harm Outcomes Of Placebo-Controlled Primary Prevention Trials Of Ibandronate

Appendix F Table 21 Harm Outcomes Of Placebo-Controlled Primary Prevention Trials Of Raloxifene

Appendix F Table 22 Harm Outcomes Of Placebo-Controlled Primary Prevention Trials Of Denosumab

Appendix F Table 23 Harm Outcomes Of Placebo-Controlled Primary Prevention Trials Of Parathyroid Hormone