# Appendix E Inclusion/Exclusion Status of Studies Included in 2010 Report

Appendix E Table 1 Overview of 2010 Included Studies and Inclusion/Exclusion Status in Current Report

First Author, Year | Status in Current Report | Reasons for Exclusion
Adler, 2003^77^ | Include | NA
Alexandersen, 2005^353^ | Exclude | BMD screening after identification of fractures
Anderson, 2003 ^354^ | Exclude | Not osteoporotic women, WHI
Anderson, 2004^355^ | Exclude | Wrong population
Ascott-Evans, 2003^204^ | Include | NA
Barrett-Connor, 2006^233^ | Exclude | Wrong population
Bauer, 1997 ^356^ | Exclude | No AUCs
Bauer, 2007^163^ | Include | NA
Ben Sedrine, 2001^78^ | Include | NA
Black, 2001^145^ | Exclude | Wrong or no outcome
Black, 2007^219^ | Exclude | Wrong population
Brenneman, 2003^81^ | Include | NA
Cadarette, 2001^82^ | Include | NA
Cadarette, 2004^83^ | Include | NA
Cadarette, 2008^357^ | Exclude | Not a relevant comparison
Cass, 2006^84^ | Include | NA
Cauley, 2003^313^ | Exclude | Not osteoporotic women, WHI
Chesnut, 1995^203^ | Include | NA
Chesnut, 2000^359^ | Exclude | Wrong intervention
Chesnut, 2004^360^ | Exclude | Wrong population
Chlebowski, 2003^361^ | Exclude | Not osteoporotic women, WHI
Colon-Emeric, 2002^143^ | Exclude | Wrong or no outcome
Cook, 2005^87^ | Include | NA
Crabtree, 2002^362^ | Exclude | Wrong or no intervention
Cranney, 2002^363^ | Exclude | Calcitonin was not an Included intervention
Cryer, 2002^364^ | Exclude | Wrong study design
Cummings, 1998^200^ | Include | NA
Cummings, 2006^365^ | Exclude | Wrong or no outcome
Curb, 2006^366^ | Exclude | not osteoporotic women, WHI
Cushman, 2004 ^367^ | Exclude | not osteoporotic women, WHI
D’Amelio, 2005^88^ | Include | NA
Dargent-Molina, 2003^368^ | Exclude | not in externally validated cohort
Delmas, 2002^232^ | Include | NA
Diez-Perez, 2007^369^ | Exclude | not in externally validated cohort
Donaldson, 2009^339^ | Include | NA
Dursun, 2001^207^U | Exclude | Wrong or no comparator
Ensrud, 2009^178^ | Include | NA
Ettinger, 1999^231^ | Include | NA
Frediani, 2006^370^ | Exclude | BMD screening after identification of fractures
Gennari, 1985^371^ | Exclude | calcitonin was not an Included intervention
Girman, 2002^146^ | Exclude | Wrong clinical setting
Gluer, 2003^372^ | Exclude | Not original research
Gnudi, 2005^91^ | Include | NA
Goh, 2007^269^ | Exclude | Wrong study design
Gonnelli, 2005^373^ | Exclude | Not a key question reviewed in the current report (DXA in men)
Gourlay, 2005^79^ | Include | NA
Grbic, 2008^281^ | Exclude | Wrong population
Greenfield, 2007^374^ | Exclude | Greenfield, 2007 is an Exclude for wrong population Note, the authors of Nelson, 2010 have a discrepancy in the author names in References versus their tables.
Greenspan, 2005^373^ | Exclude | Superseded by the current meta-analysis in this update.
Greenspan, 2007^36^ | Include | NA
Hans, 1996^376^ | Exclude | No AUCs
Hans, 2008^377^ | Exclude | Not in externally validated cohort
Harris, 2008^378^ | Exclude | Superseded by the current meta-analysis in this update.
Harrison, 2006^93^ | Include | NA
Heckbert, 2008^256^ | Exclude | Wrong population
Herd, 1997^228^ | Include | NA
Hillier, 2007^194^ | Include | NA
Hippisley-Cox, 2009^150^ | Include | NA
Hizmetli, 1998^379^ | Exclude | Calcitonin was not an Included intervention
Hooper, 2005^227^ | Exclude | Wrong population
Hosking, 1998^215^ | Exclude | Wrong population
Hsia, 2006 ^380^ | Exclude | Not osteoporotic women, WHI
Kanis, 2007^32^ | Include | NA
Karam, 2007^293^ | Exclude | Superseded by the current meta-analysis in this update.
Kaufman, 2005^381^ | Exclude | Wrong or no intervention
Khaw, 2004 ^382^ | Exclude | No AUCs
Kurland, 2000^383^ | Exclude | Wrong population
LaCroix, 2005^384^ | Exclude | Wrong or no comparator
Lenart, 2008^263^ | Exclude | Wrong or no comparator
Liberman, 1995^199^ | Include | NA
Lynn, 2008^97^ | Include | NA
MacLean, 2008^270^ | Exclude | Superseded by new evidence
Manson, 2003^385^ | Exclude | Not osteoporotic women, WHI
Martinez-Aguila, 2007^99^ | Include | NA
Masoni, 2005^386^ | Exclude | Risk prediction instruments predicting BMD with no information on imaging tests screening for BMD.
Mauck, 2005^100^ | Include | NA
McClung, 2004^285^ | Include | NA
Meunier, 1997^229^ | Include | NA
Minnock, 2008^117^ | Include | NA
Mortensen, 1998^224^ | Include | NA
Mulleman, 2002^387^ | Exclude | Not a key question reviewed in the current report (DXA in men)
Nayak, 2006^120^ | Exclude | Superseded by the current meta-analysis in this update.
Neer, 2001^388^ | Exclude | Wrong population
Nelson, 2009^73^ | Include | NA
Nelson, 2009^74^ | Include | NA
Nguyen, 2004 ^103^ | Include | NA
Odvina, 2005^264^ | Exclude | Wrong or no comparator
Office of Drug Safety, 2004^257^ | Exclude | Wrong population
Orwoll, 2003^240^ | Include | NA
Overgaard, 1992^389^ | Exclude | Wrong intervention
Pols, 1999^201^ | Include | NA
Pouilles, 1997^230^ | Exclude | Wrong population
Reid, 2002^217^ | Include | NA
Richards, 2008^390^ | Exclude | Not in externally validated cohort
Richy, 2004^80^ | Include | NA
Rico, 1995^391^ | Exclude | calcitonin was not an Included intervention
Robbins, 2007^151^ | Exclude | Not osteoporotic women, WHI
Rossouw, 2002^392^ | Exclude | Not osteoporotic women, WHI
Rossouw, 2007^393^ | Exclude | Not osteoporotic women, WHI
Rud, 2005^109^ | Include | NA
Rud, 2007^394^ | Exclude | Study does not look at fracture outcomes
Russell, 2001^395^ | Exclude | Risk prediction instruments predicting BMD with no information on imaging tests screening for BMD.
Salaffi, 2005^396^ | Exclude | Risk prediction instruments predicting BMD with no information on imaging tests screening for BMD.
Sandhu, 2010^142^ | Include | NA
Sawka, 2005^397^ | Exclude | Superseded by the current meta-analysis in this update.
Schuit, 2004^23^ | Exclude | Wrong or no outcome
Sedrine, 2002^158^ | Exclude | Risk prediction instruments predicting BMD with no information on imaging tests screening for BMD.
Shepherd, 2007^110^ | Include | NA
Shiraki, 2003^283^ | Include | NA
Sinnott, 2006^111^ | Include | NA
Sorensen, 2008^247^ | Include | NA
Stefanick, 2006 ^398^ | Exclude | Not osteoporotic women, WHI
Stewart, 2006^162^ | Include | NA
Tracz, 2006^399^ | Exclude | Wrong or no intervention-- testosterone
Valimaki, 2007^225^ | Include | NA
Van der Klift, 2002^400^ | Exclude | Not a key question reviewed in the current report (DXA in men)
Van Staa, 1997^347^ | Include | NA
Varenna, 2005^358^ | Exclude | No AUCs
Vestergaard, 2007^401^ | Exclude | Wrong or no comparator
Wallace, 2003^402^ | Exclude | Risk prediction instruments predicting BMD with no information on imaging tests screening for BMD.
Wassertheil-Smoller, 2003 ^403^ | Exclude | Not osteoporotic women, WHI
Wei, 2004^141^ | Exclude | Bone measurement happens after outcome
Wells, 2008^404^ | Exclude | Wrong population
Wells, 2008^405^ | Exclude | Wrong population
Wells, 2008^406^ | Exclude | Wrong or no intervention

Abbreviations: AUC=area under the curve; BMD=bone mineral density; DXA=dual energy x-ray absorptiometry; MA=meta-analysis; NA=not applicable; WHI=Women’s Health Initiative.