# Appendix D: Risk of Bias Tables

Table 1 KQ 1 Risk of Bias Assessment: Part 1

First Author, Year | Describe Interventions and Comparators | Study Design | FOR RCTs: Was Method of Randomization Adequate? | FOR RCTs: Was Allocation Concealment Adequate? | For RCTs: Were There Baseline Imbalances That Suggest a Problem with Randomization?
Barr, 2010^317^ | G1: invitation to osteoporosis screening G2: control (no invitation to screen) | RCT parallel | Yes | Probably yes | No
Shepstone, 2017^72^ | G1: invitation to osteoporosis screening G2: control (no invitation to screen) | RCT parallel | Yes | Probably yes | No

Abbreviations: DXA=dual energy x-ray absorptiometry; G=group; KQ=key question; NA=not applicable; RCT=randomized controlled trial.

Table 2 KQ 1 Risk of Bias Assessment: Part 2

First Author, Year | FOR COHORTs: Was Selection into the Study Unrelated to Intervention or Unrelated to Outcome? | FOR COHORTs: Do Start of Follow-up and Start of Intervention Coincide for Most Subjects? | FOR COHORTs: Were Adjustment Techniques Used That Are Likely To Correct for the Presence of Selection Biases? | FOR CASE-CONTROLS: Were the Controls Sampled from the Population That Gave Rise to the Cases, or Using Another Method That Avoids Selection Bias? | Bias Arising from Randomization or Selection? | Comments
Barr, 2010^317^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | NR
Shepstone, 2017^72^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Some concerns | Participants healthier than nonparticipants but also more likely to have a parental history of hip fractures; however similar prevalence of parental hip fracture between screening and control group.

Abbreviations: KQ=key question; NA=not applicable; NR=not reported.

Table 3 KQ 1 Risk of Bias Assessment: Part 3

First Author, Year | FOR COHORTS AND CASE CONTROLS: Is Confounding of the Effect of Intervention Unlikely in This Study? | FOR COHORTS: Were Participants Analyzed According to Their Initial Intervention Group Throughout Followup? | FOR COHORT STUDIES: Were Intervention Discontinuations or Switches Unlikely To Be Related to Factors That Are Prognostic for the Outcome? | FOR COHORT AND CASE-CONTROL STUDIES: Did the Authors Use an Appropriate Analysis Method That Adjusted for All the Critically Important Confounding Domains?
Barr, 2010^317^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Shepstone, 2017^72^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort

Abbreviations: KQ=key question; NA=not applicable.

Table 4 KQ 1 Risk of Bias Assessment: Part 4

First Author, Year | FOR COHORT STUDIES: Did the Authors Avoid Adjusting for Postintervention Variables? | FOR COHORT STUDIES Did the Authors Use an Appropriate Analysis Method That Adjusted for All the Critically Important Confounding Domains and for Time-Varying Confounding? | Bias Arising from Confounding? | Comments
Barr, 2010^317^ | NA-not a cohort | NA-not a cohort | No | RCT design mitigates risk of confounding from known and unknown factors.
Shepstone, 2017^72^ | NA-not a cohort | NA-not a cohort | No | RCT design mitigates risk of confounding from known and unknown factors.

Abbreviations: KQ=key question; NA=not applicable; RCT=randomized controlled trial.

Table 5 KQ 1 Risk of Bias Assessment: Part 5

First Author, Year | FOR COHORTS AND CASE CONTROLS: Is Intervention Status Well Defined? | FOR COHORTS AND CASE CONTROLS: Was Information on Intervention Status Recorded at the Time of Intervention? | FOR COHORTS AND CASE CONTROLS Was Information on Intervention Status Unaffected by Knowledge of the Outcome or Risk of the Outcome? | Bias Arising from Measurement of the Intervention? | Comments
Barr, 2010^317^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | RCT Design so all items NA.
Shepstone, 2017^72^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | RCT Design so all items NA.

Abbreviations: KQ=key question; NA=not applicable; RCT=randomized controlled trial.

Table 6 KQ 1 Risk of Bias Assessment: Part 6

First Author, Year | FOR RCTS and COHORTS: What Was the Overall Attrition? What Was the Attrition by Group? Did Attrition Vary for Different Outcomes? | FOR RCTS and COHORTS: Did the Study Have High Attrition Raising Concern for Bias? | FOR RCTS and COHORTS: Are the Proportion of Participants and Reasons for Missing Data Similar across Interventions? | FOR CASE-CONTROLS: Are the Proportion of Participants and Reasons for Missing Data Similar across Cases and Controls?
Barr, 2010^317^ | Overall: [%] unclear. Study reports an over 60% response rate but the analysis relevant for this manuscript is the per protocol analysis, and no Ns are provided. (The “ITT” analysis compares responders in the control arm to randomized in the intervention arm and therefore is not a full representation of the randomized arms and would not qualify). | Yes | No | NA
Shepstone, 2017^72^ | Overall by 60 months: 10660/12483=85%. Specific Ns vary by outcome and timing of measurement | No | Yes | NA

Abbreviations: ITT=intent to treat; KQ=key question; N=number; NA=not applicable.

Table 7 KQ 1 Risk of Bias Assessment: Part 7

First Author, Year | FOR ALL STUDIES: Were Appropriate Statistical Methods Used To Account for Missing Data? | Bias Arising from Missing Outcome Data? | Comments
Barr, 2010^317^ | No | Probably yes | Although this level of attrition would be considered high for trials of treatment, it’s not unreasonable given the length of follow up and that this was a trial of invitation to screening.
Shepstone, 2017^72^ | Yes | No | NA

Abbreviations: KQ=key question.

Table 8 KQ 1 Risk of Bias Assessment: Part 8

First Author, Year | [underlined: FOR RCTs of TREATMENT (NA for Screenina):] Were the Patients Unaware of Their Intervention Status of Participants? | [underlined: FOR ALL RCTs:] Were the Trial Personnel and Clinicians Unaware of the Intervention Status of Participants? | [underlined: FOR ALL STUDIES] Was Intervention Fidelity Adequate? | [underlined: FOR ALL STUDIES:] Did the Study Have Enough Cross-Overs or Contamination That Would Raise Concern for Bias? | Bias Arising from Departures from Intended Interventions?
Barr, 2010^317^ | No | No | No information | No information | No information
Shepstone, 2017^72^ | No | No | No information | Yes | Some concerns; no masking of participants or clinicians, standards for usual care changed over the course of the trial, potentially diluting the effect of the intervention

Abbreviations: KQ=key question; NA=not applicable; RCTs=randomized controlled trials.

Table 9 KQ 1 Risk of Bias Assessment: Part 9

First Author, Year | FOR ALL STUDIES: Were Benefit Outcomes (e.g., Fractures) Adequately Described, Pre-Specified, Valid, and Reliable? | FOR ALL STUDIES: Were Similar Techniques Used Among Groups To Ascertain Benefit Outcomes? | FOR ALL STUDIES: Was the Duration of Follow-Up Adequate To Assess Benefit Outcomes? | FOR ALL STUDIES: Were Harm Outcomes Adequately Described, Valid and Reliable?
Barr, 2010^317^ | Probably yes | Yes | Yes | No information
Shepstone, 2017^72^ | Probably yes | Yes | Yes | Yes

Abbreviations: KQ=key question; NA=not applicable.

Table 10 KQ 1 Risk of Bias Assessment: Part 10

First Author, Year | FOR ALL STUDIES: Were Similar Techniques Used among Groups To Ascertain Harm Outcomes? | FOR ALL STUDIES: Was the Duration of Follow-Up Adequate To Assess Harm Outcomes? | Bias Arising from Measurement of Outcomes?
Barr, 2010^317^ | No information | No information | Probably no
Shepstone, 2017^72^ | Yes | Yes | Probably no. Fractures measured from medical records, so likely to have undercounted asymptomatic vertebral fractures; as a result, the study may be have been underpowered to measure these fractures, but this is a precision issue

Abbreviations: KQ=key question; NA=not applicable.

Table 11 KQ 1 Risk of Bias Assessment: Part 11

First Author, Year | FOR RCTS AND COHORTS: Is the Reported Effect Estimate Unlikely To Be Selected, on the Basis of the Results, from Multiple Outcomes Measurements within the Domain, Multiple Analyses, or Different Subgroups? | FOR CASE-CONTROL STUDIES: Is the Reported Effect Estimate Unlikely To Be Selected, on the Basis of the Results, from Multiple Definitions of the Intervention? | Bias Arising from Selection of Reported Results?
Barr, 2010^317^ | No | No | No
Shepstone, 2017^72^ | No | No | No

Abbreviations: KQ=key question; NA=not applicable; RCTs=randomized controlled trials.

Table 12 KQ 1 Risk of Bias Assessment: Part 12

First Author, Year | Rating Overall (if You Rate One of the Domains as Having Bias, the Study Cannot Be High Quality) | Rating Justification | Does Quality Rating of Study Vary by Outcome? | Comments
Barr, 2010^317^ | Poor | The ITT analysis is not eligible because it does not fully account for all randomized; the per-protocol analysis does not account for contamination or crossovers over the long follow up period; also N and loss-to-follow up for per-protocol is unclear but could at least as high as 40 percent. | No | Pulled Torgeson to fully understand randomization procedures (Torgerson DJ, Thomas RE, Campbell MK, Reid DM (1997) Randomized trial of osteoporosis screening. Use of hormone replacement therapy and quality-of-life results. Arch Intern Med 157:2121-2125)
Shepstone, 2017^72^ | Fair | Some concerns regarding potential contamination because of changes in guidelines over time. As a result, the difference between usual care and the intervention arm may have been reduced.Some concerns regarding potentially selection bias (participants potentially healthier but also more likely to have parents with a history of hip fractures) | No | NA

Abbreviations: ITT=intent to treat; KQ=key question; N=number; NR=not reported.

Table 13 KQ 2 Systematic Review Risk of Bias Assessments: Part 1

First Author, Year | Describe Interventions and Comparators (MUST describe usual care and combinations) | Did the Review Adhere to Pre-defined Objectives and Eligibility Criteria? | Were the Eligibility Criteria Appropriate for the Review Question? | Were Eligibility Criteria Unambiguous?
Crandall, 2015^75^ | Not applicable | Yes | Yes | Yes
Marques et al, 2015^76^ | Fracture Risk Prediction Models | Yes | Yes | Yes
Nayak et al, 2014^119^ | Osteoporosis absolute fracture risk assessment instruments | Probably yes | Yes | Yes
Rubin et al, 2013^121^ | Risk assessment tools | Yes | Yes | Yes
Steurer et al, 2011^122^ | Development of instruments and validation | Yes | Yes | Yes

Abbreviations: KQ=key question.

Table 14 KQ 2 Systematic Review Risk of Bias Assessments: Part 2

First Author, Year | Were All Restrictions in Eligibility Criteria Based on Study Characteristics Appropriate (e.g., date, sample size, study quality, outcomes measured)? | Were Any Restrictions in Eligibility Criteria Based on Sources of Information Appropriate (e.g., publication status or format, language, availability of data)? | Concerns Regarding Specification of Study Eligibility Criteria | Did the Review Search an Appropriate Range of Databases/Electronic Sources for Published and Unpublished Reports?
Crandall, 2015^75^ | Yes | Yes | Low | Probably no
Marques et al, 2015^76^ | Yes | Yes | Low | Yes
Nayak et al, 2014^119^ | Yes | Yes | Low | Yes
Rubin et al, 2013^121^ | Yes | Yes | Low | Probably no
Steurer et al, 2011^122^ | Yes | Yes | Low | Yes

Abbreviations: KQ=key question.

Table 15 KQ 2 Systematic Review Risk of Bias Assessments: Part 3

First Author, Year | Were Methods Additional to Database Searching Used To Identify Relevant Reports? | Were the Terms and Structure of the Search Strategy Likely To Retrieve as Many Eligible Studies as Possible? | Were Restrictions Based on Date, Publication Format, or Language Appropriate? | Were Efforts Made To Minimize Error in Selection of Studies?
Crandall, 2015 ^75^ | Probably no | Yes | Yes | No information
Marques et al, 2015^76^ | Yes | Yes | Yes | Yes
Nayak et al, 2014^119^ | Yes | Yes | Yes | Yes
Rubin et al, 2013^121^ | Yes | Yes | No | Yes
Steurer et al, 2011^122^ | Yes | Yes | Yes | Yes

Abbreviations: KQ=key question.

Table 16 KQ 2 Systematic Review Risk of Bias Assessments: Part 4

First Author, Year | Concerns Regarding Methods Used To Identify and/or Select Studies | Were Efforts Made To Minimize Error in Data Collection? | Were Sufficient Study Characteristics Available for Both Review Authors and Readers To Be Able To Interpret the Results? | Were All Relevant Study Results Collected for Use in the Synthesis?
Crandall, 2015 ^75^ | Unclear or some concerns | No information | Yes | Yes
Marques et al, 2015^76^ | Low | Yes | Probably yes | Yes
Nayak et al, 2014^119^ | Low | Yes | Yes | Yes
Rubin et al, 2013^121^ | Unclear or some concerns | No information | Yes | Yes
Steurer et al, 2011^122^ | Low | Yes | Yes | Yes

Abbreviations: KQ=key question.

Table 17 KQ 2 Systematic Review Risk of Bias Assessments: Part 5

First Author, Year | Was Risk of Bias (or Methodological Quality) Formally Assessed Using an Appropriate Tool? | Were Efforts Made To Minimize Error in Risk of Bias Assessment? | Concerns Regarding Methods Used To Collect Data and Appraise Studies | Did the Synthesis Include All Studies That It Should?
Crandall, 2015 ^75^ | No | No information | Unclear or some concerns | Yes
Marques et al, 2015^76^ | Yes | Yes | Low | Yes
Nayak et al, 2014^119^ | Probably yes | No information | Low | Yes
Rubin et al, 2013^121^ | Yes | Yes | Low | Yes
Steurer et al, 2011^122^ | Yes | No information | Low | Yes

Abbreviations: KQ=key question.

Table 18 KQ 2 Systematic Review Risk of Bias Assessments: Part 6

First Author, Year | Were All Pre-defined Analyses Reported or Departures Explained? | Was the Synthesis Appropriate Given the Degree of Similarity in the Research Questions, Study Designs and Outcomes across Included Studies? | Was Between-Study Variation (Heterogeneity) Minimal or Addressed in the Synthesis? | Were the Findings Robust (e.g., as Demonstrated through Sensitivity Analyses)?
Crandall, 2015 ^75^ | Yes | Yes | Probably yes | No information
Marques et al, 2015^76^ | Probably yes | Yes | Probably no | Probably yes
Nayak et al, 2014^119^ | Probably yes | Yes | Yes | No information
Rubin et al, 2013^121^ | Yes | Yes | Yes | Probably yes
Steurer et al, 2011^122^ | Yes | Yes | No information | No information

Abbreviations: KQ=key question.

Table 19 KQ 2 Systematic Review Risk of Bias Assessments: Part 7

First Author, Year | Were Biases in Primary Studies Minimal or Addressed in the Synthesis? | Concerns Regarding the Synthesis | Did the interpretation of Findings Address All of the Concerns Identified in Domains 1 to 4? | Was the Relevance of Identified Studies to the Review’s Research Question Appropriately Considered? | Did the Reviewers Avoid Emphasizing Results on the Basis of Their Statistical Significance? | Risk of Bias in the Review
Crandall, 2015 ^75^ | No | Unclear or some concerns | Probably no | Yes | Yes | Unclear or some concerns
Marques et al, 2015^76^ | Probably yes | Low | Yes | Yes | Yes | Low
Nayak et al, 2014^119^ | Yes | Low | Yes | Yes | Probably yes | Low
Rubin et al, 2013^121^ | Yes | Low | Yes | Yes | Yes | Low
Steurer et al, 2011^122^ | Yes | Unclear or some concerns | No | Yes | Yes | Unclear or some concerns

Abbreviations: KQ=key question.

Table 20 Risk of Bias for Assessing Accuracy of Risk Prediction Instruments for Identifying Osteoporosis: Part 1

First Author’s Last Name; Year | Patients | Index Test(s): | Reference Standard and Target Condition
Adler, 2003^77^ | Men enrolled in a pulmonary clinic (January-May 2001) and a rheumatology clinic (Nov 2001-March 2002) at a single VA medical center; received questionnaire and DXA scan; patients with previous DXA testing ineligble | Osteoporosis Self-assessment Tool (OST) (risk=[(weight in kg-age in years)*0.2, truncated to integer]) | DXA
Bansal, 2015 ^56^ | All women between the ages of 50 and 64.5 years who underwent DXA during a 6-month period (March 1, 2012-August 31, 2012) and were enrolled in a primary care practice of the Mayo Clinic in Rochester, MN | FRAX | DXA
Ben Sedrine, 2001^78^ | all female patients either consulting spontaneously or referred for a BMD measurement between January 1996 and September 1999 to an outpatient osteoporosis center located at the University of Liège, Liège, Belgium. | SCORE | DXA
Brenneman, 2003^81^ | Post-menopausal women ages 60-79 in the OPRA study | SCORE SOF-based screening tool | DXA
Cadarette, 2001^82^ | Post-menopausal women in CaMOS | SCORE ABONE ORAI *weight criterion and NOF also evalated | DXA
Cadarette, 2004^83^ | Women ≥45 years recruited prospectively from university setting and retrospectively analyzed form family practices | ORAI OST | DXA
Cass, 2006^84^ | Primary care, women | ORAI and SCORE | DXA
Cass, 2013^85^ | Primary care, men | MORES | DXA
Cass, 2016^114^ | Primary care, men, NHANES III | MORES, FRAX | DXA
Chan, 2006^86^ | Community-based elderly women | ORAI, SCORE, ABONE, OSTA | DXA
Cook et al, 2005^87^ | UK, DXA scanning clinics, patients referred from general practicioners based on 1+ clinical risk factors for OP | Two QUS systems: CUBA Clinical (BUA, VOS), Sunlight Omnisense (distal radius, proximal phalanx mid finger, mid-shaft tibia) | DXA, LS-4, and total hip
Crandall, 2014^57^ | Postemenopausal women enrolled in the WHI Observational or Clinical Trial Studies | OST, SCORE, USPSTF criteria (FRAX MOF risk >=9.3%) | DXA
D’Amelio, 2005^88^ | Post menopausal women referred to a university-based bone metabolic unit for DXA. | NOF, OST, ORAI | DXA T Score -2.5 or less
D’Amelio, 2013^89^ | Postemenopausal women recruited from general practice | NOF ORAI OST AMMEB | DXA
Geusens, 2002 ^90^ | Postmenopausal women 45 years and older, US and Netherlands, 81.8% white | OST, ORAI, SCORE, SOFSURF | DXA
Gnudi, 2005^91^ | Postmenopausal Italian women requiring a DXA scan | Gnudi et al clinical prediction tool | DXA
Gourlay, 2005^79^ | Post menopausal women referred for DXA scans at an outpatient osteoporosis center in Belgium, based on suspicion of osteoporosis. | OST, ORAI, SCORE | DXA T Score -2.5 or less
Gourlay, 2008 ^92^ | US ambulatory white women age 65 years and older | OST, ORAI, SCORE | DXA
Harrison, 2006^93^ | Caucasian females, 55-80 years (referred to clinical radiology, intended use of index test (QUS x2) underwent DXA and categorized as non-osteoporosis and osteoporosis. Subsequently underwent QUS and risk assessment using demographics and then combined algorithms-QUS used to predict osteoporosis | QUS x2 | DXA
Jimenez-Nunez, 2013^94^ | Women from primary and tertiary care, diagnosis, no prior testing | 4 risk scores + PIXI of the heel | DXA of the hip and spine
Kung, 2003^95^ | Women in Hong Kong recruited from the community | OSTA index and QUI | DXA
Kung, 2005^96^ | Community of Asian (Southern Chinese) men; develop index based on clinical factors; compare clinical index with calcaneal QUS in predicting BMD (T< -2.5) by DXA | Clinical index | Calcaneal QUS; target condition -osteoporosis as determined by BMD at the hip and spine by DXA
Leslie, 2013^113^ | All women ages 50-64 with medical coverage and valid DXA measurements from the lumbar spine and hip, from Manitoba, Canada | FRAX, OST | DXA
Lynn, 2008^97^ | US Caucasian (4658) and Hong Kong Chinese (1914) from the MrOS study with DXA and QUS measurements to compare screening tools (OST, MOST, QUI) to DXA | OST, MOST, QUI | DXA
Machado, 2010^98^ | Population-based sample of Portugese men age 50 or over | OST< 1, OSTA< 2 | DXA T Score -2.5 or less at any of the three sites (LS, FN, TH) measured
Martinez-Aguila, 2007^99^ | Postemenopausal women age 40 to 69 referrred to a local bone densitometry unit from local gynecologists in Spain; 24% with history of prior fracture. | ORAI (>=9), OST (<2), OSIRIS(<=1) | DXA T Score -2.5 or less at FN or LS
Mauck, 2005^100^ | Population-based sample of postmenopausal women age 45 years and older in Rochester, MN | SCORE >=6 ORAI >=9 NOF >=1 | DXA T Score -2.5 or less at FN or LS
McLeod, 2015^101^ | Women referred for screening in Canada, no prior testing | QUS and OST | DXA
Morin, 2009^102^ | Population-based sample of all women age 40 to 59 and over that received DXA testing in Manitoba, Canada. Note criteria for BMD testing in women younger than 65 include premature ovarian failure, history of steroid use, prior fracture, xray evidence of osteopenia, and other pertinent clinical risk factors. | OST <=1 | DXA T Score -2.5 or less at FN or LS or Total Hip
Nguyen, 2004^103^ | Women from the Dubbo Osteoporosis Epidemiology Study, a population-based cohort of men and women from Dubbo, Australia. | DOESCore, FOSTA, SOFSURF, ORAI | DXA T Score < -2.5 (Reference ranges unspecified)
Oh, 2013^104^ | National, population-based health and nutrition cohort. | OSTA | DXA
Oh, 2016^105^ | Population based sample of Korean men age 50 and older | OSTA | DXA
Pang, 2014^106^ | Persons age 70 and over recruited from general practice, excluded persons with history of fracture | OST, FRAX w/o BMD MOF and Hip | DXA
Richards, 2014^108^ | Male VA patients | OST | DXA
Richy, 2004^80^ | Postmenopausal White women | OST | DXA
Shepherd, 2007^110^ | Men 50 years or older with DXA scan in NHANES III | MORES | DXA
Shepherd, 2010^115^ | men ≥50 included in NHANES | MORES | BMD dxa osteo
Sinnott, 2006^111^ | AA men, age 35 and older (outpatient general medicine clinics at veteran hospital; intended use of clinical assessment tools and calcaneous ultrasound compared with the reference measure of BMD by DXA; no description of presentation in article; no prior testing): index text is ultrasound of calcaneous on non-dominant foot, OUTCOME is low bone mass | Ultrasound of calcaneous on non-dominant foot | BMD by DXA at the 1) lumbar spine(L1-L4) and 2)non-dominant hip(femoral neck, trochanter, total hip)
Zimering, 2007^112^ | Men age 40 years or older, ambulatory veterans attending general medicine clinics, endocrinology clinics, or osteoporosis clinics | Mscore OST MSCORE (age-weight) | DXA

Abbreviations: AA=African American; ABONE=assessing age, body size, and estrogen use; AMMEB=Age, Years after Menopause, Age at Menarche, Body Mass Index; BMD=bone mineral density; BUA=broadband attenuation; CaMOS=Canadian Multicentre Osteoporosis Study; DOEScore=Dubbo Osteoporosis Epidemiology Score; DXA=dual energy x-ray absorptiometry; DXA T=dual energy x-ray _; FN=femoral neck; FOSTA=Female Osteoporosis Self-assessment Tool for Asia; FRAX=Fracture Rsk Assessment tool; LS=lumbar spine; LS-4=lumbar spine 4; MOF=major osteoporotic fracture defined as fractures of the proximal femur, distal radius, proximal humerus, and clinical vertebral fractures; MORE=Multiple Outcomes of Raloxifene Trial; MOST=Male Osteoporosis Screening Tool; MrOS=evaluation of osteoporosis screening tools for the osteoporotic fractures in men; MSCORE=male, simple calculated osteoporosis risk estimation; NFIANES III=National Health And Nutrition Examination Survey III; NOF=National Osteoporosis Foundation; OP=osteoporosis; OPRA=Osteoporosis Population-based Rsk Assessment; ORAI=Osteoporosis Risk Assessment Instrument; OST=osteoporosis self-assessment tool; QUI=ultrasound index; QUS=quantitative ultrasound; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; SOF=Study of Osteoporotic Fractures; SOFSURF=Study of Osteoporotic Fractures Simple Useful Rsk Factors; UK=United Kingdom; US=United States; USPSTF=United States Preventive Services Task Force; VA=Veterans’ Administration; VOS=velocity of sound; WHI=Women’s Health Initiative.

Table 21 Risk of Bias for Assessing Accuracy of Risk Prediction Instruments for Identifying Osteoporosis: Part 2

First Author’s Last Name; Year | Describe Methods of Patient Selection | Was a Consecutive or Random Sample of Patients Enrolled? | Was a Case-Control Design Avoided? | Did the Study Avoid Inappropriate Exclusions?
Adler, 2003^77^ | Data from two cross-sectional studies conducted among patients enrolled in a pulmonary clinic (evaluated from Jan-May 2001) and a rheumatology clinic (evaluated from Nov 2001-Mar 2002) at a single VA medical center. | Unclear | Yes | Yes
Bansal, 2015 ^56^ | Conducted retrospective record review of women ages 50–64.5 years old to determine clinical factors and FRAX scores of women undergoing a DXA at researcher’s institution over a 6-month period. | Yes | Yes | Yes
Ben Sedrine, 2001^78^ | Gathered data from patients consulting spontaneously or referred for a BMD measurement between Jan 1996 and Sep 1999 to outpatient osteoporosis center located at University of Liege. | Unclear | Yes | Yes
Brenneman, 2003^81^ | Data from first arm of OPRA study where BME testing was aimed at all women. Eigible subjects were contacted by a mailing that invited all women to receive a DXA bone scan free of charge. | Yes | Yes | Unclear
Cadarette, 2001^82^ | Menopausal women age 45 years or older with DXA data at the femoral neck were included from 6 sites in the CaMos study. In the CaMos, an age-, sex-, and region-stratefied random sample of the Canadian population was selected using a telephone-based sampling frame. | Yes | Yes | Yes
Cadarette, 2004^83^ | Two groups of women were studied. Women 45 years or older presenting for BMD testing between Nov 11, 1999, and May 25, 2000, at an ambulatory care center affiliated with the University of Toronto were recruited prospectively. Women taking bone active medications other than hormone replacement, with a prior fragility fracture, or with major risk factors for secondary osteoporosis were excluded. The records of a second group of women attending two family practice clinics affiliated with the University of Toronto were reviewed retrospectively. Women age 45 years and older with a baseline DXA report since January 1997 were eligible. | Yes | Yes | Yes
Cass, 2006^84^ | Postmenopausal women age 45 years or older receiving usual care at a university-based family practice clinic. | Yes | Yes | Yes
Cass, 2013^85^ | Cross-sectional study of men who attended primary care outpatient clinics for usual care. | Yes | Yes | Yes
Cass, 2016^114^ | Men age 50 years or older from the NHANES III data set. | Yes | Yes | Yes
Chan, 2006^86^ | Chinese postmenopausal women age 55 years and older were recruited from the Tanjong Rhu community in the eastern part of Singapore. | Unclear | Yes | Unclear
Cook et al, 2005^87^ | Patients referred by general practitioner to DXA screening clinic | Unclear | Yes | Unclear
Crandall, 2014^57^ | Participants from 3 clinical centers (Tucson and Phoenix, Arizona; Pittsburgh, Pennsylvania; and Birmingham, Alabama) that were part of the WHI. | Yes | Yes | Yes
D’Amelio, 2005^88^ | Postmenopausal women who came to the Department of Internal Medicine to undergo bone densitometry with DXA from Aug 10, 2003, to Sep 15, 2003. | Unclear | Yes | Yes
D’Amelio, 201S^89^ | Postmenopausal women referred from 32 general practitioners. Physicians were asked to send patients according to a randomization list. | Yes | Yes | Yes
Geusens, 2002 ^90^ | Postmenopausal women 45 years and older from US clinics and general practice in the Netherlands | yes | yes | yes
Gnudi, 2005^91^ | White, postmenopausal women living in the district of Bologna, Italy and requiring DXA for BMD measurement at both the spine and hip for clinical reasons or checkups. | Yes | Yes | Yes
Gourlay, 2005^79^ | Postmenopausal women age 45 and older either self-referred or w ere referred by a physician for a bone mineral density scan between january 1996 and September 1999 to an outpatient osteoporosis center at the University of Liege, Liege, Belgium. | Yes | Yes | Yes
Gourlay, 2008 ^92^ | US ambulatory white women age 65 years and older, from poulatio based listings | yes | yes | yes
Harrison, 2006^93^ | White Caucasian females ages 55 to 70 (mean 61, SD 4) years who were referred to Clinical Radiology, Imaging Science and Biomedical Engineering, University of Manchester for routine bone densitometry scans were invited to take part in the study | Unclear | Yes | Unclear
Jimenez-Nunez, 2013^94^ | Described as random from 2 sites | Yes | Yes | Yes
Kung, 2003^95^ | Women from community, all comers who did not meet exclusion | Unclear | Yes | Yes
Kung, 2005^96^ | Men from community, all comers who did not meet exclusion | Yes | Yes | Yes
Leslie, 2013^113^ | From a database of all DXA results performed from 1990 to March 2007 in Manitoba, Canada | Yes | Yes | Yes
Lynn, 2008^97^ | US participants were recruited using population-based listings at six clinical settings in Birmingham, AL; Minneapolis, MN; Palo Alto, CA; Pittsburgh, PA; Portland, OR; and San Diego, CA. Hong Kong participants were recruited using a combination of private solicitation and public advertising from community centers, housing estates, and the general community. Men who had bilateral hip replacements or who were unable to walk without the assistance of another person were excluded. | Yes | Yes | Unclear
Machado, 2010^98^ | Participants were randomly selected from a list of registered voters in Santo Antonio dos Olivais, Coimbra, Portugal. People were invited to participate by mail explaining the nature and purposes of the study. | Yes | Yes | Yes
Martinez-Aguila, 2007^99^ | Questionnaire mailed to all postmenopausal patients referred by gynecologists to the rheumatology department of the Hospital Universitari de Bellvitge. | No | Yes | Unclear
Mauck, 2005^100^ | Secondary data analysis of an existing population-based cohort of postmenopausal women in Rochester, MN who were participating in an ongoing, prospective study designed to assess osteoporosis prevalence, risk factors, and outcomes. Women were recruited from an age-stratified random sample of Rochester women using the medical records linkage system of the Rochester Epidemiology Project. | Yes | Yes | Yes
McLeod, 2015^101^ | Patients referred for screening to one facility | Yes | Yes | Yes
Morin, 2009^102^ | Designed retrospective historical cohort study of women ages 40 to 59 years who underwent clinical BMD testing in the province for evaluation of fracture risk using a comprehensive health care databases of the Province of Manitoba in Canada. | Yes | Yes | Unclear
Nguyen, 2004^103^ | All men and women age 60 or above living in Dubbo, Australia were invited to participate in the study. | Yes | Yes | Yes
Oh, 2013^104^ | Study data is based on data acquired in the KNHANES. The KNHANES is a nationwide survey to assess the health and nutritional status of a non-institutionalized representative sample of the Korean population. A stratified, multi-stage, clustered probability sampling design was used to select participants from residential districts. | Yes | Yes | Yes
Oh, 2016^105^ | Study data is based on data acquired in the KNHANES. The KNHANES is a nationwide survey to assess the health and nutritional status of a non-institutionalized representative sample of the Korean population. A stratified, multi-stage, clustered probability sampling design was used to select participants from residential districts. | Yes | Yes | Yes
Pang, 2014^106^ | The study invited the participation of GPs from outer metropolitan areas with poor access to BMD. GPs involved identified individuals age 70 and older from their practice databases. Individuals were invited to have a BMD evaluation at no personal cost. | Yes | Yes | Yes
Park, 2003^107^ | From a menopause clinic, not referred from elsewhere | Unclear | Yes | Yes
Rchards, 2014^108^ | Attending primary care clinics at 4 participating VA Medical Centers | Unclear | Yes | Yes
Rchy, 2004^80^ | Patients seen at an out-patient osteoporosis centre | Unclear | Yes | Yes
Shepherd, 2007^110^ | Analysis of men age 50 years and older included in the NHANES III data set who had a valid DXA test. | Unclear | Yes | Unclear
Shepherd, 2010^115^ | Men age 50 years and older who had been included in any of the NHANES 1999 to 2000, 2001 to 2002, and 2003 to 2004 datasets and who had a valid whole-body DXA scan. | Yes | Yes | Yes
Sinnott, 2006^111^ | Subjects were recruited from outpatient general medicine clinics at the Jesse Brown VA Medical Center over an 11-month period in 2004 | Unclear | Yes | Yes
Zimering, 2007^112^ | Men age 40 years or older were screened by 7 investigators from a population of ambulatory, community-dwelling veterans who attended general medical clinics (70%), endocrinology clinics (20%), or osteoporosis clinics (10%) at the Department of Veterans Affairs Medical Center in Lyons, New Jersey between September 1998 and September 2000. | Unclear | Yes | Yes

Abbreviations: AL=Alabama; CA=California; DXA=dual energy x-ray absorptiometry; GP=general practitioner; KNHANES=Korea National Health and Nutrition Examination Survey; MN=Minnesota; NHANES III=National Health and Nutrition Examination Survey III; OPRA=Osteoporosis Population-based Rsk Assessment; PA=Pennsylvania; SD=standard deviation; US=United States; VA=Veterans’ Administration; WHI=Women’s Health Initiative.

Table 22 Risk of Bias for Assessing Accuracy of Risk Prediction Instruments for Identifying Osteoporosis: Part 3

First Author’s Last Name; Year | Could the Selection of Patients Have Introduced Bias? | Patient Selection Comments | Describe the Index Test and How It Was Conducted and Interpreted | Were the Index Test Results Interpreted without Knowledge of the Results of the Reference Standard?
Adler, 2003^77^ | Unclear | Risk of spectrum bias used this ref for patient selection methods - appears random, majority of sample (107 of 181): Adler, Osteoporosis in Pulmonary Clinic Patientsa : Does Point-of-Care Screening Predict Central Dual-Energy X-ray Absorptiometry? Chest | Yes | Unclear
Bansal, 2015^56^ | Unclear | Women of this age group likely had some recognized risk of osteoporosis or fracture risk (a majority [69.7%] had a previous DXA), so potential for spectrum bias | FRAX, MOF risk >=9.3% | Unclear
Ben Sedrine, 2001^78^ | Unclear | Risk of spectrum bias. | Yes | Yes
Brenneman, 2003^81^ | Low | Patients recruited by mailing to random sample | Yes | Unclear
Cadarette, 2001^82^ | Low | Age-, sex-, and region-stratified random sample of the Canadian population selected using telephone-based sampling frame | Yes | Unclear
Cadarette, 2004^83^ | Low | NA | Yes | Unclear
Cass, 2006^84^ | Low | NR | Yes | Yes
Cass, 2013^85^ | Low | NR | Yes | Yes
Cass, 2016^114^ | Low | NHANES III is based on a probability sample of 40,000 civilian noninstitutionalized individuals | Yes | Yes
Chan, 2006^86^ | Unclear | No information on participant inclusion/exclusion criteria. | Yes | Unclear
Cook et al, 2005^87^ | Unclear | Sample has potential for bias toward low BMD due to recruitment from DXA clinic (all patients referred by doctor for clinical risk factors) | Tw o QUS tests - CUBA clinical and Sunlight Omnisense measurements. Performed on non-dominant side with same ultrsaound gel. System quality verification tests each day. | Unclear
Crandall, 2014^57^ | Low | NA | Yes | Unclear
D’Amelio, 2005^88^ | Unclear | Potential for spectrum bias, given the study population was referred specifically for DXA testing, in some cases for suspected secondary osteoporosis. | Yes | Unclear
D’Amelio, 2013^89^ | Low | NA | Yes | Unclear
Geusens, 2002 ^90^ | Low | NR | OST: age and weight ORAI: age, weight, estrogen use SCORE race, rheumatoid arthritis, history of non-traumatic fracture, HRT usage, age and weight SOFSURF: age, weight, current smoker, history of postmenopausal fracture | Unclear
Gnudi, 2005^91^ | Low | Patient refered to densitometry unit, possible spectrum bias | Yes | Yes
Gourlay, 2005^79^ | Unclear | Potential for spectrum bias, given the study population was referred specifically for DXA testing. | Yes | Yes
Gourlay, 2008 ^92^ | Low | NR | OST: age and weight ORAI: age, weight, estrogen use SCORE race, rheumatoid arthritis, history of non-traumatic fracture, HRT usage, age and weight | Low
Harrison, 2006^93^ | Low | No details on setting or how participants were selected | QUS x2 | Unclear
Jimenez-Nunez, 2013^94^ | Low | Approach to randomization using “cards” is more casual than best practice | 4 risk scores + PIXI of the heel, algorithms were developed | Yes
Kung, 2003^95^ | Low | Interesting that the study claims to be early postmenopausal but the age mean is 62 which makes it seem unlikely that this is actually the case | Index characteristics through interview and qui of right heel by technician | Unclear
Kung, 2005^96^ | Low | Unclear who chose to participate relative to larger group, excluded abnormal TSH group | Index developed by authors based on characteristics | Unclear
Leslie, 2013^113^ | Low | NR | OST, FRAX without BMD | Unclear
Lynn, 2008^97^ | Low | Only exclusions listed were hip replacement and inability to walk without a cane | OST, MOST, QUI | Unclear
Machado, 2010^98^ | Low | NR | Yes | Unclear
Martinez-Aguila, 2007^99^ | Unclear | Patients were all referred for DXA, so potential for spectrum bias. | Yes | Unclear
Mauck, 2005^100^ | Low | NR | Yes | Unclear
McLeod, 2015^101^ | Low | NA | QUS of BUA and SOS of left calcaneus & personal data based on questionnaire | Yes
Morin, 2009^102^ | Unclear | Population is younger women 40-59 that received a DXA, however, in this province younger women are only eligible to have coverage for DXA testing if they have clinical risks for secondary osteoporosis, history of prior fracture, or xray evidence of osteop | Yes | Unclear
Nguyen, 2004^103^ | Low | NA | Yes | Unclear
Oh, 2013^104^ | Low | NA | Yes | Unclear
Oh, 2016^105^ | Low | NR | Yes | Unclear
Pang, 2014^106^ | Low | NA | Yes | Unclear
Park, 2003^107^ | Low | NR | OSTA: age and weight. | Unclear
Richards, 2014^108^ | Low | NR | OST: age and weight. | Unclear
Richy, 2004^80^ | Low | NR | SCORE race, rheumatoid arthritis, history of non-traumatic fracture, HRT usage, age and weight ORAI: age, weight, estrogen use OSIRIS: age, weight, HRT use, history of low trauma fracture OST: age and weight | Unclear
Shepherd, 2007^110^ | Low | NHANES uses a complex, multistage, probability sampling design to select participants representative of the civilian, non-institutionalized population of the coterminous United States, excluding Indian reservations. (i.e. not random or consecutive sampling) | Yes | Unclear
Shepherd, 2010^115^ | Low | NR | Yes | Unclear
Sinnott, 2006^111^ | Low | Selection of participants may be a convenience sample but unclear. Men were recruited from general medicine clinics so selection bias likely low | Ultrasound of calcaneous on non-dominant foot | Unclear
Zimering, 2007^112^ | Unclear | Convenience sample 30% came from specialty clinics (endo or OP) for total cohort, but unknown for valdiation cohort Excluded those unable to assess risk factors or DXA, though did not exclude based on known medical comorbidities or bone active medications (glucocorticoids). Reported only 14% on glucocorticoids, and 4% with RA | Yes | Unclear

Abbreviations: BMD=bone mineral density; BUA=broadband attenuation; DXA=dual energy x-ray absorptiometry; HRT=hormone replacement therapy; MOST=Male Osteoporosis Screening Tool; NA=not applicable; NHANES=National Health And Nutrition Examination Survey; NR=not reported; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=Osteoporosis Index of Risk; OSTA=Osteoporosis Self-assessment Tool for Asians; OST=osteoporosis self-assessment tool; QUI=ultrasound index; QUS=quantitative ultrasound; RA=radiographic absorptiometry; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; SOS=speed of sound; TSH=thyroid stimulating hormone.

Table 23 Risk of Bias for Assessing Accuracy of Risk Prediction Instruments for Identifying Osteoporosis: Part 4

First Author’s Last Name; Year | If a Threshold Was Used, Was It Pre-specified? | Could the Conduct or Interpretation of the Index Test Have Introduced Bias? | Index Test Comments | Describe the Reference Standard and How It Was Conducted and Interpreted
Adler, 2003^77^ | Yes | Low | Used three cutoffs for OST - tw o based on published literature, one cutoff based on what they thought was appropriate | HANES reference database for hip Hologic reference source for spine Age, gender, race of reference group not reported
Bansal, 2015^56^ | Yes | Low | NA | DXA, T-score < -2.5 but no other details provided
Ben Sedrine, 2001^78^ | Yes | Low | Authors did report on outcomes of clinical prediction tools using a priori cutoffs. But also did calibrate tool for this population using AUC curve. | Hologic QDR reference values specifically established for the population of Liege, Belgium (local reference values)
Brenneman, 2003^81^ | Yes | Low | SCORE cutoff was recalibrated using study data to achieve sensitivity of approximately 90%. Developer cut off >=6 Study cutoff >=8 | NHANES III, do not specify age or gender of reference group
Cadarette, 2001^82^ | Yes | Low | Used cutoffs based on those of the developers of the study | Canadian young adult normal values at the femoral neck. (Authors note that the Canadian young adult normal reference at the femoral neck (mean [SD], 0.857 [0.125] g/cm3) is similar to that reported by NHANES III for non-Hispanic white Americans (mean [SD], 0.858 [0.120] g/cm3).
Cadarette, 2004^83^ | Yes | Low | Unclear timing of DXA, reference test, in relationship to index test in prospective and retrospective parts of the study sample | Unclear
Cass, 2006^84^ | Yes | Low | NR | NHANES III non-Hispanic White women age 20-29 years old.
Cass, 2013^85^ | Yes | Low | NR | NHANES III non-Hispanic White women age 20-29 years old.
Cass, 2016^114^ | Yes | Low | Threshold was determined in a split sample, using a development cohort, reported in Shepherd et al, 2007.^110^ This analysis focuses on the validation cohort only | NHANES III non-Hispanic White women age 20-29 years old
Chan, 2006^86^ | Yes | Low | Study only reports outcomes for Femoral Neck at the prespecified thresholds, the Lumbar Spine outcomes are reported using empirically derived thresholds. | Unclear
Cook et al, 2005^87^ | Yes | Unclear | Threshold question - yes and no used a 90% sensitivity threshold, but also created a cut off level based on the highest combined value of Sn and Sp. | T-scores were computed using the databases supplied with the systems
Crandall, 2014^57^ | Unclear | Unclear | The study mentions the existing thresholds used for the instruments from the literature, but outcomes are not reported by these thresholds. | NHANES III normative reference database (presumably young non-hispanic white females 20-29, though this is not specifically reported)
D’Amelio, 2005^88^ | Yes | Low | NR | Unclear
D’Amelio, 2013^89^ | Yes | Low | The thresholds mentioned in study do not correspond entirely to thresholds used by other studies. | Unclear
Geusens, 2002 ^90^ | Yes | Low | NR | FN: non-hispanic female white women age 20-29 (NHANES) LS: unclear
Gnudi, 2005^91^ | Yes | Low | Do not report on blinded index test assessment. Had three apriori cutoffs from development cohort to achieve 97%, 98% and 99% sensitivity | Reference values were those reported by Norland for the European female population
Gourlay, 2005^79^ | No | Unclear | Did not use pre-specified cutoffs for ORAI, OST, or SCORE. Instead, picked cut-off to achieve Sn 90% for each age group under and over 65 years. (last para p.922 | T score reference range was NHANES III non-Hispanic white women age 20-29 years at the femoral neck
Gourlay, 2008 ^92^ | Yes | Low | NR | FN: non-hispanic female white women age 20-29 (NHANES) LS: manufacturers norms for women age 30 years
Harrison, 2006^93^ | Yes | Low | NR | Hologic reference data for the T and z scores calculated using Hologic reference dataa for the lumbar spine and NHANES reference data for the proximal femur
Jimenez-Nunez, 2013^94^ | Yes | Low | NR | Manufacturer’s reference for the Spanish population
Kung, 2003^95^ | Yes | Low | Index based on characteristics can be biased based on analysis decisions | Peak young Chinese mean values used for calculating T-scores: L1-L4 BMD
Kung, 2005^96^ | Yes | Low | The authors are developing their own index test and so by definition are experimenting withtheir data | Unclear
Leslie, 2013^113^ | Yes | Low | NR | Femoral T-scores calculated based on NHANES III white female reference; lumbar spine used T-scores used manufacturer’s USA white female reference values
Lynn, 2008^97^ | Yes | Low | NR | US: NHANES Hong Kong: local Chinese reference ranges
Machado, 2010^98^ | Yes | Low | NR | NHANES III young normal references values (sex unspecified) for FN; manufacturer’s database for male Caucasian references values for LS (age unspecified)
Martinez-Aguila, 2007^99^ | Yes | Low | NR | T -Scores from reference range from a study conducted in a Spanish population of healthy subjects of same sex with peak bone mass
Mauck, 2005^100^ | Yes | Low | NR | T scores based on references ranges for young healthy women age 20-29 years in the local community area
McLeod, 2015^101^ | Yes | Low | NR | NHANES III
Morin, 2009^102^ | Yes | Low | Sn and Sp reported for multiple thresholds, the threshold of <=1 is what has been used in other studies, so data was only extracted for this threshold. | Reports T Scores for LS used manufacturers US white female reference ranges, based on revised NHANES III, but these are only applicable to FN, and the study states this reference range was used for LS.
Nguyen, 2004^103^ | Yes | Low | Validation cohort only. | Used BMD values of young Australian women at either the femoral neck or lumbar spine as reference to determine T score
Oh, 2013^104^ | No | Unclear | The authors do not report findings for the predefined threshold of OSTA< instead they report findings for a different threshold that they selected to maximize discriminative ability. | Sexspecific norms for young Japanese women
Oh, 2016^105^ | Unclear | Unclear | Unclear whether OSTA threshold used was prespecified. | Sex specific norms for young Japanese men
Pang, 2014^106^ | No | Unclear | Thresholds were not prespecified, rather they were chosen to maximize discriminative ability. | Manufacturer’s sex specific normative databse and an ethnic database.
Park, 2003^107^ | Yes | Low | NR | Reference range for young Korean women
Richards, 2014^108^ | Yes | Low | NR | NHANES III
Richy, 2004^80^ | Yes | Low | NR | Reference values specifically established for the population of Liege.
Shepherd, 2007^110^ | Yes | Low | Do not report on blinded index test assessment. Threshold is determined in development cohort in this study. Applied to validation cohort. | T scores derived from race/ethnicity and sex-specific bone mineral density for Hispanic, non-Hispanic white, and non-Hispanic black men ages 20-29.
Shepherd, 2010^115^ | Yes | Low | NR | White men age 20-29; whole body DXA Hologic QDR-4500A
Sinnott, 2006^111^ | Unclear | Low | NR | T-scores were calculated using the manufacturer’s reference values, namely a young Caucasian male database for the hip and a Caucasian female database for the spine
Zimering, 2007^112^ | Yes | Low | Do not report on blinded index test assessment. Threshold is determined in development cohort in this study. Applied to validation cohort. | T score <= -2.5 compared to NHANES III young male, ethnicity/race- specific reference data

Abbreviations: AUC=area under the curve; BMD=bone mineral density; DXA=dual energy x-ray absorptiometry; GE=General Electric; NR=not reported; ORAI=Osteoporosis Risk Assessment Instrument; OST=osteoporosis self-assessment tool; OSTA=Osteoporosis Self-assessment Tool for Asians; QUI=ultrasound index; QUS=quantitative ultrasound; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; Sn=sensitivity; Sp=specificity.

Table 24 Risk of Bias for Assessing Accuracy of Risk Prediction Instruments for Identifying Osteoporosis: Part 5

First Author’s Last Name; Year | Is the Reference Standard Likely To Correctly Classify the Target Condition? | Were the Reference Standard Results Interpreted without Knowledge of the Results of the Index Test? | Could the Reference Standard, Its Conduct, or Its Interpretation Have Introduced Bias? | Reference Standard Comments
Adler, 2003^77^ | Yes | Unclear | Low | NR
Bansal, 2015^56^ | Yes | Unclear | Low | NR
Ben Sedrine, 2001^78^ | Yes | Yes | Low | From discussion: “All of our DXA tests come from the same densitometers and from the same clinical unit.
Brenneman, 2003^81^ | Yes | Unclear | Low | NR
Cadarette, 2001^82^ | Yes | Unclear | Low | NR
Cadarette, 2004^83^ | Yes | Unclear | Low | Unclear timing of DXA, reference test, in relationship to index test in prospective and retrospective parts of the study sample
Cass, 2006^84^ | Yes | Yes | Low | Specific reference range for T scores not reported, but used manufacturer’s ranges, so likely NHANES.
Cass, 2013^85^ | Yes | Yes | Low | NR
Cass, 2016^114^ | Yes | Yes | Low | NR
Chan, 2006^86^ | Unclear | Unclear | Unclear | No information on the specific reference ranges used to determine T-Score.
Cook et al, 2005^87^ | Yes | Unclear | Unclear | NR
Crandall, 2014^57^ | Yes | Unclear | Low | NR
D’Amelio, 2005^88^ | Yes | Unclear | Low | No information about masking of test results, but given objective calculations that go into both the index and reference test, low chance of bias.
D’Amelio, 2013^89^ | Unclear | Unclear | Unclear | Reference range for T score NR.
Geusens, 2002 ^90^ | Yes | Unclear | Low | NR
Gnudi, 2005^91^ | Yes | Yes | Low | Do not report on blinded reference test assessment.
Gourlay, 2005^79^ | Yes | Yes | Low | NR
Gourlay, 2008 ^92^ | Yes | Unclear | Low | NR
Harrison, 2006^93^ | Yes | Unclear | Low | NR
Jimenez-Nunez, 2013^94^ | Yes | Yes | Low | NR
Kung, 2003^95^ | Yes | Unclear | Low | NR
Kung, 2005^96^ | Yes | Yes | Low | NR
Leslie, 2013^113^ | Yes | Unclear | Low | NR
Lynn, 2008^97^ | Yes | Unclear | Low | All obtained from MrOS (sequence of data collection not described)
Machado, 2010^98^ | Yes | Unclear | Low | NR
Martinez-Aguila, 2007^99^ | Yes | Unclear | Low | Did not use NHANES reference standards; but may be appropriate since conducted in a Spanish population.
Mauck, 2005^100^ | Yes | Unclear | Low | Used a local reference range for T score values.
McLeod, 2015^101^ | Yes | Yes | Low | NR
Morin, 2009^102^ | Yes | Yes | Low | NR
Nguyen, 2004^103^ | Yes | Unclear | Low | Local reference range for young Australian women at the FN or LS was used.
Oh, 2013^104^ | Yes | Unclear | Low | NR
Oh, 2016^105^ | Yes | Unclear | Low | NR
Pang, 2014^106^ | Yes | Unclear | Low | NR
Park, 2003^107^ | Yes | Unclear | Unclear | NR
Richards, 2014^108^ | Yes | Yes | Unclear | NR
Richy, 2004^80^ | Yes | Unclear | Unclear | NR
Shepherd, 2007^110^ | Yes | Yes | Low | Index test was developed after DXA done, so presumably reference test interpretation blinded.
Shepherd, 2010^115^ | Yes | Unclear | Low | NR
Sinnott, 2006^111^ | Yes | Unclear | Low | Threshold values not explicity provided.
Zimering, 2007^112^ | Yes | Unclear | Low | Do not report on blinded reference test assessment.

Abbreviations: BMD=bone mineral density; DXA=dual energy x-ray absorptiometry; FN=femoral neck; LS=lumbar spine; MrOS=evaluation of osteoporosis screening tools for the osteoporotic fractures in men; NHANES III=National Health And Nutrition Examination Survey; NR=not reported.

Table 25 Risk of Bias for Assessing Accuracy of Risk Prediction Instruments for Identifying Osteoporosis: Part 6

First Author’s Last Name; Year | Describe Any Patients Who Did Not Receive the Index Test(s) and/or Reference Standard or Who Were Excluded | Describe the Time Interval and Any Interventions between Index Test(s) and Reference Standard | Was There an Appropriate Interval between Index Test(s) and Reference Standard? | Did All Patients Receive a Reference Standard? | Did Patients Receive the Same Reference Standard? | Were All Patients Included in the Analysis?
Adler, 2003^77^ | Excluded patients who had previously had a DXA scan (i.e. the reference test) | 1 month | Yes | Unclear | Yes | Yes
Bansal, 2015^56^ | None | FRAX input collected at time of DXA or from review of medical records. | Yes | Yes | Yes | Yes
Ben Sedrine, 2001^78^ | Data on those with missing data for index and DXA test were not reported | Not reported: gathered retrospective medical data on BMD measurement and risk factors between January 1996 and 1999. | Unclear | Yes | Yes | Unclear
Brenneman, 2003^81^ | 1986 recruited 428 consented 416 had complete data | Occurred concurrently | Yes | Yes | Yes | Yes
Cadarette, 2001^82^ | 69 participants missing data to calculate clinical decision rules | Not specifically reported. All baseline data collected 2/2016-9/2017, presumably includes questionnaire and DXA testing. | Unclear | Yes | Yes | No
Cadarette, 2004^83^ | Of retrospective sample, 66 did not have data on estrogen use. Assumed to be negative. Only patients with DXA included. | Unclear | Unclear | Yes | Yes | No
Cass, 2006^84^ | Yes | Yes | Yes | Yes | Yes | No
Cass, 2013^85^ | Yes | Yes | Yes | Yes | Yes | No
Cass, 2016^114^ | Details NR | NR | Unclear | Yes | Yes | Yes
Chan, 2006^86^ | No | Yes | Yes | Yes | Yes | Unclear
Cook et al, 2005^87^ | None | None | Yes | Yes | Yes | Yes
Crandall, 2014^57^ | No | Yes | Yes | Yes | Yes | Yes
D’Amelio, 2005^88^ | NR | Clinical risk factors collected at the time of DXA scan | Yes | Yes | Yes | Yes
D’Amelio, 2013^89^ | Yes | Yes | Yes | Yes | Yes | No
Geusens, 2002 ^90^ | NA | Unclear | Unclear | Yes | Yes | Yes
Gnudi, 2005^91^ | NR | NR | Unclear | Yes | Yes | Unclear
Gourlay, 2005^79^ | NR | NR | Unclear | Yes | Yes | Unclear
Gourlay, 2008 ^92^ | NA | Unclear | Unclear | Yes | Yes | Yes
Harrison, 2006^93^ | NR | NR | Unclear | Yes | Yes | Unclear
Jimenez-Nunez, 2013^94^ | Nursing home, homebound, prior diagnosis of osteo, on osteo drugs, serious acute or chronic disease, hip replacement, steroids | Same day | Unclear | Yes | Yes | Unclear
Kung, 2003^95^ | History or evidence of metabolic bone disease, menopause before 40, history of cancer, evidence of sig renal impariment, both hips previously fractured or replaced, prior use of any bisphosphonates, fluoride or calcitonin | NR | Unclear | Yes | Yes | Yes
Kung, 2005^96^ | History or evidence of metabolic bone disease, hightory of cancer, evidence of sig renal impariment, both hips previously fractured or replaced, prior use of any bisphosphonates, fluoride or calcitonin, abnormal biochemisty including renal and liver function, serum calcium, phosphate, total alkaline phosphatase, and TSH | NR | Unclear | Yes | Yes | Yes
Leslie, 2013^113^ | NR | NR | Unclear | Yes | Yes | Yes
Lynn, 2008^97^ | NR | NR | Unclear | Yes | Yes | Na
Machado, 2010^98^ | NR | NR | Unclear | Yes | Yes | Yes
Martinez-Aguila, 2007^99^ | Yes | NR | Unclear | Yes | Yes | No
Mauck, 2005^100^ | NR | Yes | Yes | Yes | Yes | Yes
McLeod, 2015^101^ | Previous diagnosis, progressive terminal illness | Within 3 weeks | Yes | Yes | Yes | Yes
Morin, 2009^102^ | NR | Unclear | Unclear | Yes | Yes | Yes
Nguyen, 2004^103^ | NR | Not explicitly, but given study design presume it was concurrent. | Yes | Yes | Yes | Yes
Oh, 2013^104^ | Yes | Yes | Yes | Yes | Yes | Yes
Oh, 2016^105^ | Yes | Yes | Yes | Yes | Yes | Yes
Pang, 2014^106^ | Yes | Yes | Yes | Yes | Yes | Yes
Park, 2003^107^ | NA | Unclear | Unclear | Yes | Yes | Yes
Richards, 2014^108^ | NA | Unclear | Unclear | No | Yes | No
Richy, 2004^80^ | NA | Unclear | Unclear | Yes | Yes | Yes
Shepherd, 2007^110^ | From Looker et al Bone mineral measurements were performed on 3176 older men in NHANES III, but 86, or 3%, were rejected for technical reasons after review, leaving 3090 with acceptable data | NR | Unclear | Yes | Yes | Yes
Shepherd, 2010^115^ | Yes | Yes | Yes | Yes | Yes | Yes
Sinnott, 2006^111^ | NR | NR | Unclear | Yes | Yes | Yes
Zimering, 2007^112^ | NR | Not reported, presumably concurrent testing | Unclear | Yes | Yes | No

Abbreviations: BMD=bone mineral density; DXA=dual energy x-ray absorptiometry; NHANES III=National Health And Nutritionexamination Survey III; NR=not reported; TSH=thyroid stimulating hormone.

Table 26 Risk of Bias for Assessing Accuracy of Risk Prediction Instruments for Identifying Osteoporosis: Part 7

First Author’s Last Name; Year | Could the Patient Flow Have Introduced Bias? | Patient Flow Comments | Overall Judgement | Overall Comments
Adler, 2003^77^ | Low | From Adler, Osteoporosis in Pulmonary Clinic Patientsa : Does Point-of-Care Screening Predict Central Dual-Energy X-ray Absorptiometry? Chest Volume 123, Issue 6, June 2003, Pages 2012-2018 98 or 107 patients received DXA scan from pulmonary cohort; unknown | Low | Unclear for domain of patient selection. Also unclear how many excluded for no DXA, but from pulmonary cohort appears small. Would give it a FAIR for ROB
Bansal, 2015^56^ | Low | None | Unclear | Potential for spectrum bias because younger women with DXA likely have had some unspecified risk factors. Some risk of bias introduced by retrospective design as women age 50-64 would typically not have DXA ordered in the absence of increased risks for osteoporosis.
Ben Sedrine, 2001^78^ | Unclear | No report of timing between index and reference test | Low | Risk of spectrum bias. No mention of who was excluded or if any dropped out; unclear if results looked at independently blind; Unclear for domain of flow and timing.
Brenneman, 2003^81^ | Low | 416 includes those with complete information not sure how many were dropped due to incomplete data; sounds like data collected all at the same time | Low | 416 includes those with complete information not sure how many were dropped due to incomplete data; sounds like data collected all at the same time; not sure if blinded interpretation
Cadarette, 2001^82^ | Low | Multisite study with different DXA machines in each site. T scores were calculated from cross-calibrated Hologic BMD equivalent. Baseline period < 2 years. | Low | Unclear it assessments were blind; unclear on timing of assessments; excluded those who had osteoporosis and taking bone sparing medications, those with secondary osteoporosis, those with missing data
Cadarette, 2004^83^ | Low | Study authors collected clinical risk factors taken at the same time as the DXA scan for the retrospective sample of patients For prospective study, presumably concurrent. | Low | Unclear on assessment timing; unclear on blinding; looks like those with missing data were excluded
Cass, 2006^84^ | Low | 23 enrolled patients did not undergo DXA scan so were not included. 173 eligible patients declined to participate. | Low | NR
Cass, 2013^85^ | Low | 40 patients did not undergo DXA so were dropped from the analysis. | Low | NR
Cass, 2016^114^ | Low | NR | Low | NR
Chan, 2006^86^ | Unclear | The Number eligible is not reported, the number of dropouts is not reported, only the final N analyzed is reported. | Unclear | Some concerns in multiple domains of risk of bias lead to an overal rating of uncler.
Cook et al, 2005^87^ | Low | NR | Unclear | Patient selection has the potential to skew the sample toward low BMD
Crandall, 2014^57^ | Low | Main analysis was restricted to a subgroup of non HRT users by design (, supplemental analyses include HRT users and all women [including those with preventive use of HRT]) | Low | NR
D’Amelio, 2005^88^ | Low | NR | Low | NR
D’Amelio, 2013^89^ | Low | Some patients initially enrolled were excluded because it was determined they did not meet study criteria. | Low | NR
Geusens, 2002 ^90^ | Unclear | Unclear because of lack of clarity around timing of the tests | Unclear | No details on how the reference standard data were collected or the time interval between it and the index test
Gnudi, 2005^91^ | Low | While authors don’t report on timing between reference and index test, validation cohort was recruited over 6 months (<2 years) | Low | NR
Gourlay, 2005^79^ | Unclear | NR | Unclear | NR
Gourlay, 2008 ^92^ | Unclear | Unclear because of lack of clarity around timing of the tests | Unclear | No details on how the reference standard data were collected or the time interval between it and the index test
Harrison, 2006^93^ | Unclear | Participants underwent DXA and were categorized as non -osteo or osteo prior to QUS or risk indices | Low | Low-to-high given that osteoporosis status determined first
Jimenez-Nunez, 2013^94^ | Low | random sample done with some sort of cards | Low | NR
Kung, 2003^95^ | Low | NR | Low | NR
Kung, 2005^96^ | Low | It is not clear what the time frame between clinical assessment of risk factors and QUS; however should be little impact; I put that all participants received the same reference standard (referring to the validated group here) | Low | NR
Leslie, 2013^113^ | Low | NR | Low | NR
Lynn, 2008^97^ | Low | NR | Low | Data was collected prospectively from MrOS study and then analyzed as part of this study focus.
Machado, 2010^98^ | Low | Interval between clinical risks and BMD inferred to be < 2 years. | Low | NR
Martinez-Aguila, 2007^99^ | Unclear | 30 eligible patients were excluded for missing data. Clinical risk factors assessed retrospectively by asking participants to answer them based on the date of their BMD testing. | Unclear | NR
Mauck, 2005^100^ | Low | NR | Low | NR
McLeod, 2015^101^ | Low | Effort made to contact patient, enroll and conduct OST and QUS within 3 weeks of DXA scan to complete study assessments prior to provider receiving DXA results and talking with patient. | Low | NR
Morin, 2009^102^ | Unclear | Unclear for timing between DXA and index test | Unclear | NR
Nguyen, 2004^103^ | Low | NR | Low | NR
Oh, 2013^104^ | Low | Some patients meeting prelim criteria based on age were not eligible for a variety of reasons. | Low | Low ROB for the test thresholds used by study authors.
Oh, 2016^105^ | Low | Excluded some men for probably valid reasons | Low | NR
Pang, 2014^106^ | Low | Some patients meeting prelim age criteria not eligible to be included. | Low | Low ROB for the test thresholds used by study authors.
Park, 2003^107^ | Unclear | Unclear because of lack of clarity around timing of the tests | Unclear | No details on how the reference standard data were collected or the time interval between it and the index tes
Richards, 2014^108^ | Unclear | Unclear because of lack of clarity around timing of the tests. 2 patients were excluded from the analysis because no bmd tests were done but not the primary cause of the unclear rating | Unclear | No details on how the reference standard data were collected or the time interval between it and the index tes
Richy, 2004^80^ | Unclear | Unclear because of lack of clarity around timing of the tests | Unclear | No details on how the reference standard data were collected or the time interval between it and the index tes
Shepherd, 2007^110^ | Low | NR | Low | NR
Shepherd, 2010^115^ | Low | Excluded men without DXA available, though not specifically reported NHANES enrolls subjects prospectively so clinical risks and DXA likely collected concurrently. | Low | NR
Sinnott, 2006^111^ | Low | The flow was not specifically described, but appears sequence was clinical assessment followed by ultrasound and then DXA. | Low | Primarily due to: 1) no information on the type of sampling. Assuming conveneience sampling; 2) not clear about the sequence of testing, but low risk of bias.
Zimering, 2007^112^ | Unclear | No report of timing between index and reference test or on missing data in the validation cohort; presumably concurrent testing | Unclear | NR

Abbreviations: BMD=bone mineral density; DXA=dual energy x-ray absorptiometry; HRT=hormone replacement therapy; MrOS=evaluation of osteoporosis screening tools for the osteoporotic fractures in men; NHANES=National Health And Nutritionexamination Survey; NR=not reported; OST=osteoporosis self-assessment tool; QUS=quantitative ultrasound; ROB=risk of bias.

Table 27 Risk of Bias Assessment for KQ 2a Imaging Studies Predicting Bone Density Status: Part 1

First Author, Year | Patients (Setting, Intended Use of Index Test, Presentation, Prior Testing) | Index Test(s) | Reference Standard and Target Condition | Describe Methods of Patient Selection | Was a Consecutive or Random Sample of Patients Enrolled? | Was a Case-Control Design Avoided? | Did the Study Avoid Inappropriate Exclusions? | Could the Selection of Patients Have Introduced Bias? | Comments
Boonen et al, 2005^116^ | Commmunty dwelling postmenopausal women, | QUS | t-score below 2.5 using dxa | Community dwelling postmenopausal women who had been referred for bone densitometry at 1 facility in Belgium | Yes | Yes | Yes | Low | NR
Cook et al, 2005^87^ | UK, DXA scanning clinics, patients referred from general practicioners based on 1+ clinical risk factors for OP | Two QUS systems: CUBA Clinical (BUA, VOS), Sunlight Omnisense (distal radius, proximal phalanx mid finger, mid-shaft tibia) | DXA, LS-4, and total hip | Patients referred by general practitioner to DXA screening clinic | Unclear | Yes | Unclear | Unclear | Sample has potential for bias toward low BMD due to recruitment from DXA clinic (all patients referred by MD for clinical risk factors)
Harrison et al, 2006^93^ | Caucasian females, 55-80 years (referred to clinical radiology, intended use of index test (QUS x2) underwent DXA and categorized as non-osteoporosis and osteoporosis. Subsequently underwent QUS and risk assessment using demographics and then combined algorithms-QUS used to predict osteoporosis | QUS x2 | DXA | White Caucasian females ages 55 to 70 years (mean 61, SD 4) who were referred to Clinical Radiology, Imaging Science and Biomedical Engineering, University of Manchester for routine bone densitometry scans were invited to take part in the study | Unclear | Yes | Unclear | Low | No details on setting or how participants were selected
Jimenez-Nunez et al, 2013^94^ | Women from primary and tertiary care, diagnosis, no prior testing | 4 risk scores + PIXI of the heel | DXA of the hip and spine | Described as random from 2 sites | Yes | Yes | Yes | Low | NR
Kung et al, 2003^95^ | Women in Hong Kong recruited from the community | OSTA index and QUI | DXA | Women from community, all comers who did not meet exclusion | Unclear | Yes | Yes | Low | Although noted to be early post-menopausal, mean age is 62
Kung et al, 2005^96^ | Community of Asian (Southern Chinese) men; develop index based on clinical factors; compare clinical index with calcaneal QUS in predicting BMD (T<-2.5 by DXA | Clinical index | Calcaneal QUS; target condition is osteoporosis, determined by BMD at the hip and spine by DXA | Men from community, all comers who did not meet exclusion | Yes | Yes | Yes | Low | Unclear who chose to participate relative to larger group, excluded abnormal TSH group
Lynn et al, 2008^97^ | US Caucasian (4658) and Hong Kong Chinese (1914) from the MrOS study with DXA and QUS measurements to compare screening tools (OST, MOST, QUI) to DXA | OST, MOST, QUI | DXA | US participants were recruited using population-based listings at 6 clinical settings in Birmingham, AL; Minneapolis, MN; Palo Alto, CA; Pittsburgh, PA; Portland, OR; San Diego, CA. Hong Kong participants were recruited using combination of private solicitation and public ads from community centers, housing estates, and the general community. Men who had bilateral hip replacements or were unable to wall without the assistance of another person were excluded. | Yes | Yes | Unclear | Low | NR
McLeod et al, 2015^101^ | Women referred for screening in Canada, no prior testing | QUS and OST | DXA | Patients referred for screening to one facility | Yes | Yes | Yes | Low | NA
Minnock et al, 2008^117^ | Causian women underwent clinical risk factor questionnaire, QUS and DXA in order to determine whether a combined clinical assessment tool + QUS would be predictive of osteoporosis (low bone mass) by DXA | Combined clinical risk facors+ QUS | DXA | Women were referred to DXA scanning clinic at Great Western Hospital, Swindon, UK. Referral was performed by the patients GPs, or hospital based clinics | Unclear | Yes | Unclear | Unclear | Insufficient information
Richy et al, 2004^118^ | Two cohorts of postmenopasual women, age 45 and older; purpose was to study #1 -develop an clinical algorithm tool+ QUS (n=407 women)with bone mass as the outcome measure, as derived from DXA, and then in study #2 used a second cohort (202 women) to validate the algorithm by comparing it to QUS alone and to the OST; community screening clinic; no prior testing | Clinical algorithm; QUS | DXA for low bone mass; osteoporosis | Women who attended public screening for Osteoporosis | Yes | Yes | Yes | Low | NR
Sinnott et al, 2006^111^ | AA men, age 35 and older (outpatient general medicine clinics at veteran hospital; intended use of clinical assessment tools and calcaneous ultrasound compared with the reference measure of BMD by DXA; no description of presentation in article; no prior testing): index text is ultrasound of calcaneous on non-dominant foot, outcome is low bone mass | ultrasound of calcaneous on non-dominant foot | BMD by DXA at the 1) lumbar spine (L1-L4) and 2) non-dominant hip(femoral neck, trochanter, total hip) | Subjects were recruited from outpatient general medicine clinics at the Jesse Brown VA Medical Center over an 11-month period in 2004 | Unclear | Yes | Yes | Low | Selection of participants may be a convenience sample but unclear. Men were recruited from general medicine clinics so selection bias likely low

Abbreviations: AL=Alabama; BMD=bone mineral density; BUA=broadband attenuation; CA=California; DXA=dual energy x-ray absorptiometry; GPs=general practitioners; KQ=key question; LS-4=lumbar spine 4; MD=medical doctor; MN=Minnesota; MOST=Male Osteoporosis Screening Tool; MrOS=evaluation of osteoporosis screening tools for the osteoporotic fractures in men; NA=not applicable; OR=osteoporosis; OR=Oregon; OST=osteoporosis self-assessment tool; OSTA=Osteoporosis Self-assessment Tool for Asians; PA=Pennsylvania; QUI=ultrasound index; QUS=quantitative ultrasound; SD=standard deviation; TSH=thyroid-stimulating hormone; UK=United Kingdom; US=United States; VA=Veterans’ Administration; VOS=velocity of sound.

Table 28 Risk of Bias Assessment for KQ 2a Imaging Studies Predicting Bone Density Status: Part 2

First Author, Year | Describe the Index Test and How It Was Conducted and Interpreted | Were the Index Test Results Interpreted without Knowledge of the Results of the Reference Standard? | If a Threshold Was Used, Was It Pre-Specified? | Could the Conduct or Interpretation of the Index Test Have Introduced Bias? | Comments
Boonen et al, 2005^116^ | QUS, DXR, RA | Yes | Yes | Low | NR
Cook et al, 2005^87^ | Two QUS tests - CUBA clinical and Sunlight Omnisense measurements. Performed on non-dominant side with same ultrsaound gel. System quality verification tests each day. | Unclear | Yes | Unclear | Threshold question - yes and no used a 90% sensitivity threshold, but also created a cut off level based on the highest combined value of Sn and Sp. ROB assessment - depends on if QUS studies read independently of DXA imaging.
Harrison et al, 2006^93^ | QUS x2 | Unclear | Yes | Unclear | Osteoporosis status determined before index tests conducted, but unclear if results available
Jimenez-Nunez et al, 2013^94^ | 4 risk scores + PIXI of the heel, algorithms were developed | Yes | Yes | Low | NR
Kung et al, 2003^95^ | Index characteristics through interview and QUI of right heel by technician | Unclear | Yes | Low | Index based on characteristics can be biased based on analysis decisions
Kung et al, 2005^96^ | Index developed by authors based on characteristics | Unclear | Yes | Low | NR
Lynn et al, 2008^97^ | OST, MOST, QUI | Unclear | Yes | Low | NR
McLeod et al, 2015^101^ | QUS of BUA and SOS of left calcaneus & personal data based on questionnaire | Yes | Yes | Low | NR
Minnock et al, 2008^117^ | Combined clinical risk facors+ QUS | Unclear | Yes | Low | NR
Richy et al, 2004^118^ | Clinical algorithm; QUS | Unclear | Yes | Low | NR
Sinnott et al, 2006^111^ | Ultrasound of calcaneous on non-dominant foot | Unclear | Unclear | Low | NR

Abbreviations: BUA=broadband attenuation; DXR=digital x-ray radiogrammetry; MOST=Male Osteoporosis Screening Tool; NR=not reported; OST=osteoporosis self-assessment tool; QUI=ultrasound index; QUS=quantitative ultrasound; RA=radiographic absorptiometry; Sn=sensitivity; SOS=speed of sound; Sp=specificity.

Table 29 Risk of Bias Assessment for KQ 2a Imaging Studies Predicting Bone Density Status: Part 3

First Author, Year | Describe the Reference Standard and How It Was Conducted and Interpreted | Is the Reference Standard Likely To Correctly Classify the Target Condition? | Were the Reference Standard Results Interpreted without Knowledge of the Results of the Index Test? | Could the Reference Standard, Its Conduct, or Its Interpretation Have Introduced Bias? | Comments
Boonen et al, 2005^116^ | DXA, BMD of the lumbar spiine and proximal femur | Yes | Unclear | Low | NR
Cook et al, 2005^87^ | DXA. BMD of the lumbar spine and total hip | Yes | Unclear | Unclear | NR
Harrison et al, 2006^93^ | DXA, BMD of the femoral neck and total hip | Yes | Unclear | Low | NR
Jimenez-Nunez et al, 2013^94^ | DXA, BMD of the hip and spine | Yes | Yes | Low | NR
Kung et al, 2003^95^ | DXA: BMD of the lumbar spine, femoral neck | Yes | Unclear | Low | NR
Kung et al, 2005^96^ | DXA: BMD of the lumbar spine, femoral neck | Yes | Yes | Low | NR
Lynn et al, 2008^97^ | DXA, lumbar spine and proximal femur | Yes | Unclear | Low | All obtained from MrOS (sequence of data collection not described)
McLeod et al, 2015^101^ | DXA: BMD of the lumbar spine, left and right femoral neck | Yes | Yes | Low | NR
Minnock et al, 2008^117^ | DXA, BMD of the lumbar spine, femoral neck, and total hip | Yes | Unclear | Low | NR
Richy et al, 2004^118^ | DXA, BMD of the femoral neck | Yes | Yes | Low | NR
Sinnott et al, 2006^111^ | DXA; BMD of the hip, spine | Yes | Unclear | Low | NR

Abbreviations: BMD=bone mineral density; DXA=dual energy x-ray absorptiometry; KQ=key question; MrOS=evaluation of osteoporosis screening tools for the osteoporotic fractures in men; NR=not reported; QUS=quantitative ultrasound.

Table 30 Risk of Bias Assessment for KQ 2a Imaging Studies Predicting Bone Density Status: Part 4

First Author, Year | Describe Any Patients Who Did Not Receive the Index Test(s) and/or Reference Standard or Who Were Excluded | Describe the Time Interval and Any Interventions between Index Test(s) and Reference Standard | Was There an Appropriate Interval between Index Test(s) and Reference Standard? | Did All Patients Receive a Reference Standard? | Did Patients Receive the Same Reference Standard? | Were All Patients Included in the Analysis?
Boonen et al, 2005^116^ | On treatment for osteo, peripheral oedema | Same day | Yes | Yes | Yes | Yes
Cook et al, 2005^87^ | None | None | Yes | Yes | Yes | Yes
Harrison et al, 2006^93^ | NR | NR | Unclear | Yes | Yes | Unclear
Jimenez-Nunez et al, 2013^94^ | Nursing home, homebound, prior diagnosis of osteo, on osteo drugs, serious acute or chronic disease, hip replacement, steroids | Same day | Unclear | Yes | Yes | Unclear
Kung et al, 2003^95^ | History or evidence of metabolic bone disease, menopause before 40, history of cancer, evidence of sig renal impariment, both hips previously fractured or replaced, prior use of any bisphosphonates, fluoride or calcitonin | NR | Unclear | Yes | Yes | Yes
Kung et al, 2005^96^ | History or evidence of metabolic bone disease, hightory of cancer, evidence of sig renal impariment, both hips previously fractured or replaced, prior use of any bisphosphonates, fluoride or calcitonin, abnormal biochemisty including renal and liver function, serum calcium, phosphate, total alkaline phosphatase, and TSH | NR | Unclear | Yes | Yes | Yes
Lynn et al, 2008^97^ | NR | NR | Unclear | Yes | Yes | NA
McLeod et al, 2015^101^ | Previous diagnosis, progressive terminal illness | Within 3 weeks | Yes | Yes | Yes | Yes
Minnock et al, 2008^117^ | NR | NR | Unclear | Yes | Yes | No
Richy et al, 2004^118^ | NR | NR | Unclear | Yes | Yes | Yes
Sinnott et al, 2006^111^ | NR | NR | Unclear | Yes | Yes | Yes

Abbreviations: NA=not applicable; NR=not reported; TSH=thyroid-stimulating hormone.

Table 31 Risk of Bias Assessment for KQ 2a Imaging Studies Predicting Bone Density Status: Part 5

First Author, Year | Could the Patient Flow Have Introduced Bias? | Comments | Overall Judgement | Overall Comments
Boonen et al, 2005^116^ | Low | NR | Low | Not a community-based sample. Women referred for bone densitometry.
Cook et al, 2005^87^ | Low | NR | Unclear | Patient selection has the potential to skew the sample toward low BMD
Harrison et al, 2006^93^ | Unclear | Participants underwent DXA and were categorized as non -osteo or osteo prior to QUS or risk indices | Unclear | Osteoporosis status determined first
Jimenez-Nunez et al, 2013^94^ | Low | Random sample done with some sort of cards | Low | NR
Kung et al, 2003^95^ | Low | NR | Low | NR
Kung et al, 2005^96^ | Low | It is not clear what the time frame between clinical assessment of risk factors and QUS; however should be little impact; I put that all participants received the same reference standard (referring to the validated group here) | Low | NR
Lynn et al, 2008^97^ | Low | NR | Low | NR
McLeod et al, 2015^101^ | Low | Effort made to contact patient, enroll and conduct OST and QUS within 3 weeks of DXA scan to complete study assessments prior to provider receiving DXA results and talking with patient. | Low | NR
Minnock et al, 2008^117^ | Low | NR | Unclear | Initial sample is 274 but number in analysis is 235 because of missing data, impact of missing data unclear
Richy et al, 2004^118^ | Low | NR | Low | NR
Sinnott et al, 2006^111^ | Low | The flow was not specifically described, but appears sequence was clinical assessment followed by ultrasound and then DXA. | Low | NR

Abbreviations: BMD=body mineral density; DXA=dual energy x-ray absorptiometry; KQ=key question; MrOS=evaluation of osteoporosis screening tools for the osteoporotic fractures in men; NR=not reported; OST=osteoporosis self-assessment tool; QUS=quantitative ultrasound.

Table 32 KQ 2a Prediction Studies Risk of Bias: Part 1

First Author, Year | Describe Screening or Treatment Interventions and Comparators | Prediction Model Development as well as Testing of Predictive Performance in Other Individuals (External Validation), Both in the Same Publication | Testing the Predictive Performance of a Previously Developed Prediction Model in Other Individuals (External Validation) | For Validity Were Appropriate Data Sources Used ?
Ahmed, 2014^129^ | 1. Garvan FRC with BMD, adjusted for age, prior fracture, prior fall 2. Garvan FRC, adjusted for body weight, age, prior fracture, prior fall. | No | Yes- Val only | Yes
Azagra, 2011^181^ | FRAX (Spain) | No | No | Probably no
Bauer, 2007^163^ | Quantitative US | No | No | Yes
Berry, 2013^195^ | Assess contribution of repeat BMD in 4 years to fx risk : 1. BMD at basline and Fx risk 2. BMD percent change and Fx risk 3. BMD at baseline and BMD Percent change and Fx risk | No | Yes- Val only | Yes
Chan, 2012^168^ | 1. FNBMD (adjusted for age, falls, prior fracture) 2. QUS (BUA) plus FNBMD (adjusted for age, falls, prior fracture) | No | Yes- Val only | Yes
Chan, 2013^192^ | 1. FNplus BMD (adjusted for age, falls, prior fracture) 2. QUS (BUA) plus FNBMD (adjusted for age, falls, prior fracture) | No | Yes- Val only | Yes
Crandall, 2014^58^ | Comparison of three screening strategies for women age 50-64: 1. USPSTF Strategy (FRAX 3.0 without BMD, with followup BMD testing for fx risk >= 9.3%)- 10 yr horizon 2. OST-horizon unknown, this was developed to identify osteoporosis, not fracture 3. SCORE-horizon unknown, this was developed to identify osteoporosis, not fracture | No | Yes- Val only | Yes
Hans, 2011^165^ | TBS alone, DXA alone, TBS plus DXA | No | No | Probably yes
Hillier, 2007^194^ | Imaging screening: DXA, initial BMD, repeat BMD, change in BMD, initial BMD plus change in BMD | No | No | Yes
Hippisley-Cox, 2012^130^ | Qfracture updated with additional clinical predictors and outcomes | Yes- Dev and Val | Yes- Val only | Yes
Iki, 2014^164^ | DXA - spine areal BMD, trabecular bone score | No | No | Yes
Iki, 2015 ^132^ | FRAX and TBS | No | Yes- Val only | Yes
Kalveston, 2016^133^ | FRAX and BMD | Yes- Val only | Yes- Val only | Yes
Kanis, 2007^32^ | FRAX | Yes- Dev and Val | No | Yes
Kwok, 2012^167^ | Imaging screening: QUS (BUA, SOS, QUI measures), DXA (tHIP, fnHIP, spine BMD) | No | No | Yes
Leslie, 2010^131^ | CAROC | No | Yes | Yes
Leslie, 2012^127^ | FRAX | No | Yes- Dev and Val | Yes
Leslie, 2012^123^ | FRAX with and without DXA | No | Yes | Yes
Leslie, 2013^166^ | Trabecular bone score | No | No | Yes
Lo, 2011^159^ | FRC | No | Yes- Val only | Probably yes
Lundin, 2015 ^179^ | FRAX and BMD | No | Yes- Val only | Yes
Melton, 2005^342^ | NOF model including femoral neck BMD and clinical risk factors (personal fx history, FHx, low BWT, smoking status) | No | Yes- Val only | Yes
Miller, 2002^180^ | Heel SXR, Heel QUS, forearm DXA, finger DXA; NORA study | No | No | Yes
Morin, 2009^102^ | body weight, BMI, OST (OST was developed to predict osteoporosis) | No | Yes | Yes
Nguyen, 2004^144^ | QUS. DOES | No | No | Yes
Rubin, 2013^128^ | FRAX (no BMD), OST, ORAI, OSIRIS, SCORE (all but FRAX were developed to predict osteoporosis not fracture), Age alone | No | Yes- Val only | Yes
Stewart, 2006^162^ | DXA | No | Yes- Val only | Yes
van Geel, 2014^124^ | FRAX, Garvan FRC | No | Yes- Val only | Yes

Abbreviations: BMD=bone mineral density; BMI=body mass index; BUA=broadband attenuation; BWT=body weight; CAROC=Canadian Association of Radiologists and Osteoporosis Canada; DOES=Dubbo Osteoporosis Epidemiology Study; DXA=dual energy x-ray absorptiometry; FNBMD=femoral neck bone mineral density; fnHIP=femoral neck of hip; FNplus=femoral neck plus; FRAX=Fracture Risk Assessment tool; FRC=Fracture Risk Calculator; Fx=fracture; NOF=National Osteoporosis Foundation; NORA=National Osteoporosis Risk Assessment; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=Osteoporosis Index of Risk; OST=osteoporosis self-assessment tool; QUI=ultrasound index; QUS=quantitative ultrasound; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; SOS=speed of sound; SXR=single x-ray absorptiometry; TBS=trabecular bone score; tHIP=total hip; US=United States; USPSTF=United States Preventive Services Task Force.

Table 33 KQ 2a Prediction Studies Risk of Bias: Part 2

First Author, Year | For Validity Were All Inclusions and Exclusions of Participants Appropriate? | For Validity Were Participants Enrolled at a Similar State of Health, or Were Predictors Considered To Account for Any Dissimilarities? | Risk of Bias Introduced by Selection of Participants | Justification of Bias Rating | Comments
Ahmed, 2014^129^ | Yes | Yes | Low | NR | NR
Azagra, 2011^181^ | Yes | Yes | Unclear | Cohort was assembled from participants referred for screening by primary or specialty care physicians. Thus, the cohort does not represent an entirely unselected population. | NR
Bauer, 2007^163^ | Yes | Yes | Low | NR | NR
Berry, 2013^195^ | Yes | Yes | Low | NR | NR
Chan, 2012^168^ | Yes | Yes | Low | NR | NR
Chan, 2013^192^ | No | Yes | High | High concern for spectrum bias in the subgroup analysis, since participants in the analysis were limited to those with BMD < -2.5 | NR
Crandall, 2014^58^ | Yes | Yes | Low | NR | NR
Hans, 2011^165^ | Probably yes | Probably yes | Low | NR | NR
Hillier, 2007^194^ | Probably yes | Yes | Low | NR | NR
Hippisley-Cox, 2012^130^ | Probably yes | Probably yes | Low | NR | NR
Iki, 2014^164^ | Yes | Yes | Low | NR | NR
Iki, 2015 ^132^ | Yes | Yes | Low | Population-based cohort | None
Kalvesten, 2016^133^ | Yes | Yes | Low | Population-based recruitment into study. | None
Kanis, 2007^32^ | No information | Probably yes | Low | NR | Inclusion/exclusion criteria for the 11 independent validation cohorts is not included.
Kwok, 2012^167^ | Yes | Yes | Low | NR | NR
Leslie, 2010^131^ | No information | Probably no | Low | Database covers population in Manitoba age 50 with a first bone desnity measurement, and all citizens of Manitoba have university access to publicly funded medical care including BMD. | NR
Leslie, 2012^127^ | No information | Probably no | Low | Database covers population in Manitoba age 50 with a first bone desnity measurement, and all citizens of Manitoba have university access to publicly funded medical care including BMD. | NR
Leslie, 2012^123^ | No information | Probably no | Low | Database covers population in Manitoba age 50 with a first bone desnity measurement, and all citizens of Manitoba have university access to publicly funded medical care including BMD. | NR
Leslie, 2013^166^ | No information | Probably no | Low | Database covers all women in Manitoba age 50 with a first bone desnity measurement, and all citizens of Manitoba have university access to publicly funded medical care including BMD. | NR
Lo, 2011^159^ | Probably no | Probably yes | Unclear | Possible spectrum bias due to use of population of women referred for DXA testing. Other exclusions may also have introduced some selection bias. Impact of these cannot be determined. Only about 94,000 of an eligible population of 500,000 were analyzed. | Study limited to women age 50 to 85 who were referred to have bone density scanning. Women without continuous membership both prior and following DXA scans, and those for whom DXA results were not electronically accessible and those with missing race/eth
Lundin, 2015 ^179^ | Yes | Yes | Low | Population based recruitment strategy. | None
Melton, 2005^342^ | No information | No information | Unclear | NR | NR
Miller, 2002^180^ | Yes | No information | Unclear | It is unclear whether sites selected people with similar underlying characteristics. | NR
Morin, 2009^102^ | No information | Probably no | Low | Database covers all women in Manitoba 40 to 59 with a first bone desnity measurement, and all citizens of Manitoba have university access to publicly funded medical care including BMD. | NR
Nguyen, 2004^144^ | No information | No information | Unclear | unclear whether patients selected from database similar underlying characteristics | NR
Rubin, 2013^128^ | Yes | Yes | Low | NR | NR
Stewart, 2006^162^ | Yes | No information | Low | NR | NR
van Geel, 2014^124^ | Probably yes | Yes | Low | NR | NR

Abbreviations: BMD=bone mineral density; DXA=dual energy x-ray absorptiometry; KQ=key question; NR=not reported.

Table 34 KQ 2a Prediction Studies Risk of Bias: Part 3

First Author, Year | For Validity Were Predictors Defined and Assessed in a Similar Way for All Participants? | For Validity Were Predictors Defined and Assessed in a Similar Way to Predictors in the Development Model? | Risk of Bias Introduced by Predictors or Their Assessment | Justification of Bias Rating | Comments
Ahmed, 2014^129^ | Yes | Yes | Low | NR | NR
Azagra, 2011^181^ | Yes | Yes | Low | NR | NR
Bauer, 2007^163^ | Yes | Yes | YesLow | NR | NR
Berry, 2013^195^ | Yes | Yes | Low | NR | NR
Chan, 2012^168^ | Yes | Yes | Low | NR | NR
Chan, 2013^192^ | Yes | Yes | Low | NR | NR
Crandall, 2014^58^ | Yes | Yes for FRAX and OST, probably no for SCORE | Low | Authors show that use of different age cut off for prior history of fracture would likely have little impact. | NR
Hans, 2011^165^ | NA-NOT VAL | NA-NOT VAL | Low | NR | NR
Hillier, 2007^194^ | NA-NOT VAL | NA-NOT VAL | Low | NR | NR
Hippisley-Cox, 2012^130^ | Yes | Yes | Low | NR | NR
Iki, 2014^164^ | Yes | NA-NOT VAL | Low | NR | NR
Iki, 2015 ^132^ | Yes | Yes | Low | In person interviews | None
Kalvesten, 2016^133^ | Yes | Yes | Low | Questionnaire-based assessment, all relevant predictors assessed. | None
Kanis, 2007^32^ | Probably yes | Probably yes | Low | NR | NR
Kwok, 2012^167^ | NA-NOT VAL | NA-NOT VAL | Low | Imaging prediction of fracture - not clinical prediction tool | NR
Leslie, 2010^131^ | Yes | No | Unclear | The final risk category was modified to reflect the presence of additional risk factors: any prior osteoporotic fracture (from 1987 to the date of BMD testing) and/or recent systemic corticosteroid use (in the year before BMD testing). | NR
Leslie, 2012^127^ | Yes | No | Unclear | Parental hip fracture information missing for FRAX probability estimates prior to 2005, adjusted using age- and sex- specific adjustment factors derived from 2005 to 2008 parental hip fracture responses | NR
Leslie, 2012^123^ | Yes | No | Unclear | Parental hip fracture information missing for FRAX probability estimates prior to 2005, adjusted using age- and sex-specific adjustment factors derived from 2005 to 2008 parental hip fracture responses | NR
Leslie, 2013^166^ | Yes | NA | Low | TBS assessed the same way for all | NR
Lo, 2011^159^ | Yes | Probably yes | Low | NR | NR
Lundin, 2015 ^179^ | Yes, for DXA No, for FRAX | Yes, for DXA No information, for FRAX | low for DXA unclear for FRAX | The study does not describe how inputs to FRAX were obtained | NR
Melton, 2005^342^ | Yes | Probably yes | Low | NR | NR
Miller, 2002^180^ | Yes | NA | Low | Peripheral bone densitometry done in simarl ways for all | NR
Morin, 2009^102^ | Yes | No information | Unclear | Unclear whether data for OST (age, weight) was collected before fracture for all participants | NR
Nguyen, 2004^144^ | Yes | NA | NALow | QUS done in similar ways for all | NR
Rubin, 2013^128^ | Yes | No information | Low | NR | NR
Stewart, 2006^162^ | Yes | Yes | Low | NR | NR
van Geel, 2014^124^ | Probably yes | Probably yes | Low | NR | NR

Abbreviations: BMD=bone mineral density; BMI=body mass index; BUA=broadband attenuation; BWT=body weight; CAROC=Canadian Association of Radiologists and Osteoporosis Canada; DOES=Dubbo Osteoporosis Epidemiology Study; DXA=dual energy x-ray absorptiometry; FHx=fracture history; FNBMD=femoral neck BMD; fnHIP=femoral neck of hip; FNplus=femoral neck plus; FRAX=Fracture Risk Assessment tool; FRC=Fracture Risk Calculator; Fx=fracture; KQ=key question; NOF=National Osteoporosis Foundation; NORA=National Osteoporosis Risk Assessment; NR=not reported; ORAI=Osteoporosis Risk Assessment Instrument; OSIRIS=Osteoporosis Index of Risk; OST=osteoporosis self-assessment tool; QUI=ultrasound index; QUS=quantitative ultrasound; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; SOS=speed of sound; SXR=single x-ray absorptiometry; TBS=trabecular bone score; tHIP=total hip; US=United States; USPSTF=United States Preventive Services Task Force; VAL=validity.

Table 35 KQ 2a Prediction Studies Risk of Bias: Part 4

First Author, Year | For Validity Wasa Pre-Specified Outcome Definition Used? | For Validity Was the Outcome Defined and Determined in a Similar Way for All Participants? | For Validity Was the Outcome Defined and Determined in a Similar Way to the Outcome in the Development Model? | For Validity Was the Outcome Determined without Knowledge of Predictor Information?
Ahmed, 2014^129^ | Yes | Yes | Yes | No information
Azagra, 2011^181^ | Yes | Yes | Yes | Yes
Bauer, 2007^163^ | Yes | Yes | Yes | No information
Berry, 2013^195^ | Yes | Yes | Yes | No information
Chan, 2012^168^ | Yes | Yes | Probably yes | No information
Chan, 2013^192^ | Yes | Yes | Probably yes | No information
Crandall, 2014^58^ | Yes | Yes | No for OST and SCORE, Yes for FRAX | No information
Hans, 2011^165^ | Yes | Yes | NA-NOT VAL | Yes
Hillier, 2007^194^ | Yes | Yes | NA-NOT VAL | Yes
Hippisley-Cox, 2012^130^ | Yes | Yes | Yes | Yes
Iki, 2014^164^ | Yes | Yes | NA-NOT VAL | Yes
Iki, 2015 ^132^ | Yes | Yes | Yes | no information
Kalvesten, 2016^133^ | Yes | Yes | Yes | no information
Kanis, 2007^32^ | No information | No | Probably yes | No information
Kwok, 2012^167^ | Yes | Yes | NA-NOT VAL | Yes
Leslie, 2010^131^ | Yes | Yes | No information | Probably yes
Leslie, 2012^127^ | Yes | Yes | No information | Probably yes
Leslie, 2012^123^ | Yes | Yes | No information | Probably yes
Leslie, 2013^166^ | Yes | Yes | Yes | Yes
Lo, 2011^159^ | Yes | Yes | Probably yes | No information
Lundin, 2015 ^179^ | Yes | Yes | Yes | no information
Melton, 2005^342^ | Yes | Yes | Probably no | Yes
Miller, 2002^180^ | Yes | Yes | Yes | Yes
Morin, 2009^102^ | Yes | Yes | No information | No information
Nguyen, 2004^144^ | Yes | Yes | Yes | Yes
Rubin, 2013^128^ | Yes | Yes | No information | Yes
Stewart, 2006^162^ | Yes | Yes | Yes | No information
van Geel, 2014^124^ | Yes | Yes | Probably yes | Yes

Abbreviations: FRAX=Fracture Risk Assessment tool; KQ=key question; OST=osteoporosis self-assessment tool; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; VAL=validity.

Table 36 KQ 2a Prediction Studies Risk of Bias: Part 5

First Author, Year | Risk of Bias Introduced by the Outcome or Its Determination | Justification of Bias Rating | Comments
Ahmed, 2014^129^ | Low | NR | NR
Azagra, 2011^181^ | Low | NR | NR
Bauer, 2007^163^ | Low | NR | NR
Berry, 2013^195^ | Low | NR | NR
Chan, 2012^168^ | Low | NR | NR
Chan, 2013^192^ | Low | NR | NR
Crandall, 2014^58^ | Unclear | Both OST and SCORE were initially developed and validated for prediction of low BMD. In this study they are being used to predict fracture. It’s unclear what impact this will have. | NR
Hans, 2011^165^ | Low | NR | NR
Hillier, 2007^194^ | Low | NR | NR
Hippisley-Cox, 2012^130^ | Low | NR | NR
Iki, 2014^164^ | Low | NR | NR
Iki, 2015 ^132^ | Low | fractures were confirmed | None
Kalvesten, 2016^133^ | Low | Confirmation of all self-reported fractures. Outcomes censored at 10 years. | NR
Kanis, 2007^32^ | Unclear | Fracture ascertainment was by self-report in some cohorts and by medical record or radiology report confirmation in other cohorts. | NR
Kwok, 2012^167^ | Low | Did not exclude traumatic fractures; would just have to take fragility fracture #s | NR
Leslie, 2010^131^ | Low | NR | NR
Leslie, 2012^127^ | Low | NR | NR
Leslie, 2012^123^ | Low | NR | NR
Leslie, 2013^166^ | Low | NR | NR
Lo, 2011^159^ | Low | NR | NR
Lundin, 2015 ^179^ | Low | Identification of fractures from population based claims/diagnosis data. | None
Melton, 2005^342^ | High | 13.3% fractures were due to severe trauma, another 18.3% unclear cause | NR
Miller, 2002^180^ | High | self-reported factures | NR
Morin, 2009^102^ | Unclear | unclear whether OST variables collected for all women before fracture outcome, OST developed and validated for prediction of low BMD | NR
Nguyen, 2004^144^ | Low | NR | NR
Rubin, 2013^128^ | Unclear for all but FRAX (low) | OST, SCORE, ORAI, OSIRIS developed and validated for prediction of low BMD, not fracture risk. | NR
Stewart, 2006^162^ | Low | NR | NR
van Geel, 2014^124^ | Low | NR | NR

Abbreviations: BMD=bone mineral density; KQ=key question; NR=not reported; OST=osteoporosis self-assessment tool; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool.

Table 37 KQ 2a Prediction Studies Risk of Bias: Part 6

First Author, Year | Describe Missing Data on Predictors and Outcomes as well as Methods Used for Missing Data (What Was the Missing Data, How Was It Managed? Focus on Diff between N Eligible and N Analyzed, Other Data Issues) | For Validity Were There a Reasonable Number of Outcome Events? (Bring Up for Discussion if Low) | For Validity Was the Time Interval Between Predictor Assessment and Outcome Determination Appropriate? | For Validity Were All Enrolled Participants Included in the Analysis?
Ahmed, 2014^129^ | Subjects with missing data were excluded. | Yes | Yes for 5 years, No for 10 years | Yes
Azagra, 2011^181^ | Not clear how missing data handled. | Yes | Yes | No
Bauer, 2007^163^ | No missing data. | Yes | Yes | Yes
Berry, 2013^195^ | No data on parental history of hip fracture, set to “no”. | Yes | Yes | Yes
Chan, 2012^168^ | No missing data described | Yes | Yes | Probably no
Chan, 2013^192^ | No missing data described | Yes | Yes | Probably no
Crandall, 2014^58^ | Missing data set to “not present”. Most common predictor missing was parental hip fx history. | Yes | Yes | Yes
Hans, 2011^165^ | N eligble NR (over 34,000, see comments) N included 29407 | Yes | Probably yes | Probably yes
Hillier, 2007^194^ | 9704 enrolled in SOF, 8141 women had followup (93%), 4124 had repeat BMD measurement, excluded patients with incident hip or non-spine fractures between BMD measurement (72, 513 respectively) | Yes | Yes | Probably no
Hippisley-Cox, 2012^130^ | Did not report amount of missing data (particularly for BMI, smoking Status, alcohol intake), though report mulitple imputation was used. Qresearch database > 13,000,000 patients but only 4,726,046 used for development and validation cohorts. Only inclusi | Yes | Probably yes | No
Iki, 2014^164^ | 789 eligible 665 analyzed 112 lost to followup 4 unassessable VFA 8 developed disease affecting bone metabolism | Yes | Yes | Probably yes
Iki, 2015 ^132^ | No information about the men excluded from the analysis. | probably no | probably no | probably yes
Kalvesten, 2016^133^ | Only subjects with complete data were included in analysis. | Yes | Yes | probably no
Kanis, 2007^32^ | Sensitivity analyses used to assess impact of missing predictor information. | Probably yes | Yes | No information
Kwok, 2012^167^ | N (eligible)=2000, N (analyzed)=1921, those missing QUS or DXA readings excluded, invalid QUS readings excluded | Probably yes | Probably yes | No
Leslie, 2010^131^ | Unclear | Yes | Yes | Yes
Leslie, 2012^127^ | Unclear | Yes | Yes | Yes
Leslie, 2012^123^ | Unclear | Yes | Yes | Yes
Leslie, 2013^166^ | NR | Yes | Yes | Probably yes
Lo, 2011^159^ | Women with missing data on race/ethnicity and BMD were excluded from analysis. | Yes | Yes | Yes
Lundin, 2015^179^ | Missing data for 5 participants | Yes | Yes | Yes
Melton, 2005^342^ | 1,479 approached, 1,315 eligible, 655 consented, only 393 included in analysis - unclear why | Probably yes | Yes | No
Mller, 2002^180^ | NR | Yes | No | Unclear
Morin, 2009^102^ | NR | Yes | Yes | Unclear
Nguyen, 2004^144^ | NR | Yes | Unclear | Unclear
Rubin, 2013^128^ | Eligible: 5000 Analysis: 3614 Exclusion: 334 missing questionnaire data, 246 diagnosed with/treated for OP, reported “near complete followup” in registry | Probably yes | Probably no | Yes
Stew art, 2006^162^ | Nonresponse analysis done. | Yes | Yes | Yes
van Geel, 2014^124^ | Random sample: 1686, analysis sample: 506 Missing: no coop with MD (272), no coop with patient (448), untraceable/deceased (207), age <60 (110) | Probably yes | Probably no | Yes

Abbreviations: BMD=bone mineral density; BMI=body mass index; DXA=dual energy x-ray absorptiometry; KQ=key question; MD=medical doctor; N=number; NR=not reported; OP=osteoporosis; QUS=quantitative ultrasound; SOF=study of osteoporotic fractures; VFA=vertebral fracture assessment.

Table 38 KQ 2a Prediction Studies Risk of Bias: Part 7

First Author, Year | For Validity Were Participants with Missing Data Handled Appropriately? | Risk of Bias Introduced by Sample Size or Participant Flow | Justification of Bias Rating | Comments
Ahmed, 2014^129^ | Yes | Low for 5 yr outcomes; unclear for 10 yr outcomes | Inadequate duration of follow-up for 10 year risk predictions. | NR
Azagra, 2011^181^ | No information | Unclear | Unclear eligible N | NR
Bauer, 2007^163^ | Yes | Low | NR | No mention of missing data
Berry, 2013^195^ | Yes | Low | NR | NR
Chan, 2012^168^ | Yes | Unclear | Some members of the cohort began before the use of QUS was introduced, so they would not be eligible. It’s still not clear why of the 3678 eligible in the cohort, < 1,000 comprised the analytic sample | NR
Chan, 2013^192^ | Yes | Unclear | NR | NR
Crandall, 2014^58^ | Yes | Low | NR | NR
Hans, 2011^165^ | Probably yes | Low | NR | No mention of missing data Only says matching of personal identifier information with the administrative data repository in over 34,000 DXA patients was achieved in over 99%
Hillier, 2007^194^ | Yes | Low | NR | NR
Hippisley-Cox, 2012^130^ | Probably yes | Unclear | Unclear exclusion criteria | Over 13 million in database, only 4.7 million used
Iki, 2014^164^ | Probably yes | Low | NR | NR
Iki, 2015^132^ | probably yes | Unclear | Follow-up was only 4.5 yrs, but using a 10 year risk prediction. 93% of those enrolled were included in the analysis. | NR
Kalvesten, 2016^133^ | probably yes | unclear | The entire study cohort was about 9000, but not all had complete data for calculation of FRAX and DXA measurement. Thus, analysis restricted to those with complete data, those included were younger and a little healthier and had lower prevalence of prior fracture; though BMD measures were similar. | NR
Kanis, 2007^32^ | Probably yes | Low | NR | NR
Kwok, 2012^167^ | Probably yes | Low | 2.5% excluded for missing data (small) | NR
Leslie, 2010^131^ | No information | Unclear | NR | NR
Leslie, 2012^127^ | No information | Unclear | NR | NR
Leslie, 2012^123^ | No information | Unclear | NR | NR
Leslie, 2013^166^ | Probably yes | Low | 99% accuracy and completeness | NR
Lo, 2011^159^ | Probably yes | Low | NR | NR
Lundin, 2015 ^179^ | Yes | Low | No concerns | NR
Melton, 2005^342^ | No information | High | Only about 50% of eligible patietns consented, and of those only 2/3 included for analysis | NR
Miller, 2002^180^ | No information | Unclear | Unclear whether followup window is sufficient | NR
Morin, 2009^102^ | No information | Unclear | Unclear what proportion of cohort did not have information on predictors | NR
Nguyen, 2004^144^ | No information | Unclear | The average time between imaging and fractures is unclear | NR
Rubin, 2013^128^ | No information | Unclear | Only 3 year follow-up while FRAX predicts 10 year fracture for women over 40 years old | NR
Stewart, 2006^162^ | Probably yes | Low | NR | NR
van Geel, 2014^124^ | Probably yes | Unclear | FRAX and Garvan predict 10 year risk - follow-up only for 5 years. Likely underestimates risk. 124 of 630 patients lost to follow-up | NR

Abbreviations: DXA=dual energy x-ray absorptiometry; FRAX=Fracture Risk Assessment tool; KQ=key question; N=number; NR=not reported; QUS=quantitative ultrasound.

Table 39 KQ 2a Prediction Studies Risk of Bias: Part 8

First Author, Year | For Validity Were Non-Binary Predictors Handled Appropriately? | For Validity Were Any Complexities in the Data Accounted for Appropriately? | For Validity Was the Model Recalibrated or Was It Likely That Recalibration Was Not Needed? | Risk of Bias Introduced by the Analysis
Ahmed, 2014^129^ | Probably yes | No information | Probably no | Unclear for AUC High for NRIs at both 5 and 10 yrs.
Azagra, 2011^181^ | Yes | Probably yes | Yes | Low
Bauer, 2007^163^ | Yes | No information | No information | Low
Berry, 2013^195^ | Yes | No information | Probably yes | Low
Chan, 2012^168^ | Probably yes | No information | Yes | Varies by outcome
Chan, 2013^192^ | Probably yes | No information | Yes | Varies by outcome
Crandall, 2014^58^ | Yes | No information | No information | Unclear
Hans, 2011^165^ | Yes | Probably yes | Probably yes | Low
Hillier, 2007^194^ | Probably yes | Yes | Yes | Low
Hippisley-Cox, 2012^130^ | Probably yes | Yes | Yes | Low
Iki, 2014^164^ | Yes | Probably yes | Yes | Low
Iki, 2015^132^ | Yes | no information | Yes | Low
Kalvesten, 2016^133^ | Yes | no information | Yes | Low
Kanis, 2007^32^ | Yes | Probably yes | Probably yes | Low
Kwok, 2012^167^ | Yes | Yes | NA-NOT VAL | Low
Leslie, 2010^131^ | Yes | No information | No | Low
Leslie, 2012^127^ | Yes | No information | No | Low
Leslie, 2012^123^ | Yes | No information | No | Low
Leslie, 2013^166^ | Yes | No information | No | Low
Lo, 2011^159^ | Yes | No information | Probably yes | Low
Lundin, 2015 ^179^ | Yes | no | Yes | Low
Melton, 2005^342^ | Yes | Probably yes | Yes | Low
Miller, 2002^180^ | Yes | No information | No | Low
Morin, 2009^102^ | Yes | No information | No | Low
Nguyen, 2004^144^ | Yes | No information | No | Low
Rubin, 2013^128^ | Yes | Yes | Yes | Low
Stewart, 2006^162^ | NA | Probably no | Na | Low
van Geel, 2014^124^ | Yes | Probably yes | Yes | Low

Abbreviations: AUC=area under the curve; KQ=key question; NA=not applicable; NRI=net reclassification improvement; VAL=validity.

Table 40 KQ 2a Prediction Studies Risk of Bias: Part 9

First Author, Year | Justification of Bias Rating | Comments | Overall Judgement of Risk of Bias | Justification of Bias Rating
Ahmed, 2014^129^ | Except for perhaps hip fx in women at 5 yrs, calibration plots suggest underestimation of risk at lower risk levels, and overestimation of risk at higher risk levels. | The NRI thresholds used were based on quintiles of the sample distribution of fracture risks. Thresholds used for NRI should be based on sensible and accepted thresholds to define risk groups. | Unclear for AUCs, High for NRIs | NRI risk thresholds not based on sensible/acceptable categories to define risk, they were based on sample distribution. Inadequate followup for 10 year risk prediction.
Azagra, 2011^181^ | NR | NR | Unclear | Some concerns about selection bias due to source of study population and attrition of subjects over period of followup.
Bauer, 2007^163^ | NR | NR | Low | NR
Berry, 2013^195^ | NR | NR | Low | NR
Chan, 2012^168^ | Low for AUC, High for NRI | The NRI thresholds used were based on tertiles of the sample distribution. Thresholds used for NRI should be based on sensible and accepted thresholds to define risk groups. | Varies by outcome | Unclear for AUC, High For NRI
Chan, 2013^192^ | Low for AUC, High for NRI | The NRI thresholds used were based on tertiles of the sample distribution. Thresholds used for NRI should be based on sensible and accepted thresholds to define risk groups. | High | Spectrum bias introducted by subgroup analysis.
Crandall, 2014^58^ | NR | NR | Unclear | OST and SCORE were not developed and validated to predict fractures; they were developed and validated to predict low BMD/osteoporosis.
Hans, 2011^165^ | NR | If multiple DXA scans, just took first one | Low | NR
Hillier, 2007^194^ | Removed patients with incident fractures. | NR | Low | NR
Hippisley-Cox, 2012^130^ | NR | NR | Unclear | Unclear because of partipant flow
Iki, 2014^164^ | NR | NR | Low | NR
Iki, 2015 ^132^ | Evidence of good calibration | None | unclear | Length of follow-up only 4.5 years for a 10-year prediction.
Kalvesten, 2016^133^ | NR | None | Low | No serious risks of bias. Eligible Outcomes include the discrimination of DXA for predicting fracture, and FRAX (without DXA BMD) for predicting fracture. The diagnostic performance of FRAX for predicting osteoporosis is not eligible because there was 2.1 years between FRAX assessment and DXA measurement. For same reason FRAX w/BMD not eligible as well.
Kanis, 2007^32^ | NR | NR | Low | NR
Kwok, 2012^167^ | NR | NR | Low | Did not exclude traumatic fractures in definition of “all fractures” but we can just take the data for fragility fractures)
Leslie, 2010^131^ | NR | NR | Unclear | Effect of adjustment to final risk category unclear
Leslie, 2012^127^ | Model demonstrates the effect of using various non-femoral neck BMD measures | NR | Unclear | Effect of adjustments of absence of data on parental hip fractures unclear
Leslie, 2012^123^ | Model demonstrates the effect of not using BMD | NR | Unclear | Effect of adjustments of absence of data on parental hip fractures unclear
Leslie, 2013^166^ | NR | NR | Low | NR
Lo, 2011^159^ | NR | NR | Unclear | Selection bias and spectrum bias due to how cohort w as assembled.
Lundin, 2015 ^179^ | Most of the items are NA. | None | Low | No serious risks of bias
Melton, 2005^342^ | for patients with multiple fractures, only included the first fracture, but unclear if different types of fractures in same person or same types of fracture | NR | High | Due to sampling, definition of outcome
Miller, 2002^180^ | NR | NR | High | Self-reported fracture outcomes
Morin, 2009^102^ | NR | NR | Unclear | Unclear whether data for OST (age, weight) was collected before fracture for all participants, unclear what proportion of cohort did not have information on predictors. OST was not developed and validated to predict fractures.
Nguyen, 2004^144^ | NR | NR | Unclear | Proportion and management of missing data unclear
Rubin, 2013^128^ | NR | NR | Unclear | For short follow-up duration to predict 10 year risk. All but FRAX were not developed and validated to predict fractures.
Stewart, 2006^162^ | NR | NR | Low | NR
van Geel, 2014^124^ | NR | NR | Unclear | Follow-up period shorter than instrument

Abbreviations: AUC=area under the curve; BMD=bone mineral density; DXA=dual energy x-ray absorptiometry; NR=not reported; NRI=net reclassification improvement; OST=osteoporosis self-assessment tool; SCORE=Simple Calculated Osteoporosis Risk Estimation Tool; Yrs=years.

Table 41 KQ 4 and KQ5 Systematic Review Risk of Bias Assessments: Part 1

First Author, Year | Describe Interventions and Comparators (MUST Describe Usual Care and Combinations) | Did the Review Adhere to Pre-defined Objectives and Eligibility Criteria? | Were the Eligibility Criteria Appropriate for the Review Question? | Were Eligibility Criteria Unambiguous?
Crandall et al, 2012^221^ | Treatments to prevent fractures vs. Pacebo | Yes | Yes | Yes

Abbreviations: KQ=key question.

Table 42 KQ 4 and KQ5 Systematic Review Risk of Bias Assessments: Part 2

First Author, Year | Were All Restrictions in Eligibility Criteria Based on Study Characteristics Appropriate? | Were Any Restrictions in Eligibility Criteria Based on Sources of Information Appropriate? | Concerns Regarding Specification of Study Eligibility Criteria | Did the Review Search an Appropriate Range of Databases/Electronic Sources for Published and Unpublished Reports?
Crandall et al, 2012^221^ | Yes | Yes | Low | Yes

Abbreviations: KQ=key question.

Table 43 KQ 4 and KQ5 Systematic Review Risk of Bias Assessments: Part 3

First Author, Year | Were Methods Additional to Database Searching Used To Identify Relevant Reports? | Were the Terms and Structure of the Search Strategy Likely To Retrieve as Many Eligible Studies as Possible? | Were Restrictions Based on Date, Publication Format, or Language Appropriate? | Were Efforts Made To Minimize Error in Selection of Studies?
Crandall et al, 2012^221^ | Yes | Yes | Probably yes | Yes

Abbreviations: KQ=key question.

Table 44 KQ 4 and KQ5 Systematic Review Risk of Bias Assessments: Part 4

First Author, Year | Concerns Regarding Methods Used To Identify and/or Select Studies | Were Efforts Made To Minimize Error in Data Collection? | Were Sufficient Study Characteristics Available for Both Review Authors and Readers To Be Able To Interpret The Results? | Were All Relevant Study Results Collected for Use in the Synthesis?
Crandall et al, 2012^221^ | Low | No information | Yes | Yes

Abbreviations: KQ=key question.

Table 45 KQ 4 and KQ5 Systematic Review Risk of Bias Assessments: Part 5

First Author, Year | Was Risk of Bias (or Methodological Quality) Formally Assessed Using an Appropriate Tool? | Were Efforts Made To Minimize Error in Risk of Bias Assessment? | Concerns Regarding Methods Used To Collect Data and Appraise Studies | Did the Synthesis Include All Studies That It Should?
Crandall et al, 2012^221^ | Yes | No information | Low | Yes

Abbreviations: KQ=key question.

Table 46 KQ 4 and KQ5 Systematic Review Risk of Bias Assessments: Part 6

First Author, Year | Were All Pre-defined Analyses Reported or Departures Explained? | Was the Synthesis Appropriate Given the Degree of Similarity in the Research Questions, Study Designs and Outcomes across Included Studies? | Was Between-Study Variation (Heterogeneity) Minimal or Addressed in the Synthesis? | Were the Findings Robust?
Crandall et al, 2012^221^ | Yes | Yes | Yes | Yes

Abbreviations: KQ=key question.

Table 47 KQ 4 and KQ5 Systematic Review Risk of Bias Assessments: Part 7

First Author, Year | Were Biases in Primary Studies Minimal or Addressed in the Synthesis? | Concerns Regarding the Synthesis | Did the Interpretation of Findings Address All of the Concerns Identified in Domains 1 to 4? | Was the Relevance of Identified Studies to the Review’s Research Question Appropriately Considered? | Did the Reviewers Avoid Emphasizing Results on the Basis of Their Statistical Significance? | Risk of Bias in the Review
Crandall et al, 2012^221^ | Yes | Unclear or some concerns | Yes | Yes | Yes | Low

Abbreviations: KQ=key question.

Table 48 KQ 4 and 5 Risk of Bias Assessment: Part 1

First Author, Year | Describe Interventions and Comparators | Study Design | FOR RCTs: Was Method of Randomization Adequate? | FOR RCTs: Was Allocation Concealment Adequate? | For RCTs: Were There Baseline Imbalances That Suggest a Problem with Randomization?
Abrahamsen, 2010^273^ | G1: Alendronate G2: Untreated | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT
Adachi, 2009^250^ | G1: alendronate 10 mg daily (generic preparation) G2: Placebo | RCT parallel | Yes | Yes | Probably yes
Barrett-Connor, 2002^311^ | G1: Raloxifene (60mg/day) G2: Raloxifene (120mg/day) G2: Pacebo | Fbst-hoc or subgroup analysis of RCT | Yes | Yes | No
Barrett-Connor, 2004^310^ | G1: Raloxifene (60mg/day or 120mg/day) G2: Pacebo | RCT parallel | Yes | Yes | No
Bone, 2000^216^ | G1: Alendonate 10 mg /day G2: conjugage equine estrogen 0.625 mg /day) G3: Alendronate + CEE G4: placebo | RCT parallel | Yes | No information | No
Bone, 2008^237^ | G1: Denosumab G2: Pacebo | RCT parallel | Probably yes | Probably yes | No
Boonen, 2012^218^ | G1: intravenous infusion of zoledronic acid (5 mg) for 12 months G2: Pacebo | RCT parallel | Yes | Yes | No
Cartsos, 2008 ^297^ | Intervention: Bisphosphonate use Comparator: no bisphosphonate use | Case-control (how they described) | NA-not an RCT | NA-not an RCT | NA-not an RCT
Chapurlat, 2013^284^ | G1: ibandronate G2: placebo | RCT parallel | Probably yes | Yes | No
Cryer, 2005^252^ | G1: alendronate 70 mg weekly G2: placebo | RCT parallel | Yes | Yes | No
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | G1: alendronate 5mg per day for 2 years, then 10 mg per day for 3 years G2: placebo | RCT parallel | Yes | Yes | No
Cummngs, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | G1: Denosumab G2: Pacebo | RCT parallel | Probably yes | Probably yes | No
Eisman, 2004^255^ | G1:alendronate 70 mg weekly G2: placebo | RCT parallel | Yes | Yes | No
Fogelman, 2000^226^ | G1: Risedronate 5 mg/d X 24 months G2: Pacebo | RCT parallel | No information | No information | No
Greenspan, 2002^254^ | G1: alendronate 70 mg weekly G2: placebo | RCT parallel | No information | No information | No
Greenspan, 2003^249^ | G1: Alendonate 10 mg /day G2: conjugated equine estrogen 0.625 mg /day with or without medroxyprogesterone 2.5mg daily based on uterus presence G3: Alendronate + CEE G4: placebo | RCT parallel | Yes | Yes | No
Grey, 2010^274^ | G1: Zolendronate 5 mg IV x 1 dose G2: Placebo | RCT parallel | Yes | Yes | Probably yes
Hosking, 2003^202^ | G1: Risedronate 5 mg/d X 3 months G2: Alendronate 70 mg/once weekly X 3 months G3: Pacebo | RCT parallel | Yes | Yes | No
Hosking, 2003^202^ | G1: alendronate 70 mg weekly G2: Risendronate 5 mg daily G3: Pacebo | RCT parallel | Yes | Yes | No
Johnell, 2002^246^ | RLX 60, placebo | RCT parallel | Yes | Yes | Probably no
Keech, 2005^312^ | G1: Raloxifene 60 mg / day G2 : Pacebo | Post-hoc or subgroup analysis of RCT | Yes | Yes | No
Kung, 2000^343^ | G1: alendronate 10 mg daily G2: placebo | RCT parallel | No information | No information | No
Lasco, 2011^241^ | G1: Teriparatide + calcium + vitamin D G2: Calcium + vitamin D | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT
Lewiecki, 2007^236^ | G1: Denosumab (included varying dosages over 3 and 6 months) G2: Alenbronate G3: Pacebo | RCT parallel | Probably yes | Probably yes | No
McCloskey, 2012^245^ | G1: 60 mg Denosumab SC q 6 mos for 36 mos G2: Pacebo | RCT parallel | No information | No information | No
McClung, 2004^285^ | G1: 0.5mg ibandronate daily G2: 1.0mg ibandronate daily G3: 2.5mg ibandronate daily G4:placebo | RCT parallel | No information | No information | No
McClung, 2006^306^ | G1: Lasofoxifene 0.25 mg/day G2: Lasofoxifene 1.0 mg/day G3: Raloxifene 60 mg/day G4: Pacebo | RCT parallel | No information | No information | No
McClung, 2006^209^ | G1: Denosumab 6 mg Q3mo G2: Denosumab 14 mg Q3mo G3: Denosumab 30 mg Q3mo G4: Denosumab 14 mg Q6mo G5: Denosumab 60 mg Q6mo G6: Denosumab 100 mg Q6mo G7: Denosumab 210 mg Q6mo G8: Alendronate 70 mg weekly G9: placebo | RCT parallel | No information | No information | No
McClung, 2009^275^ | G1: Zoledronic acid 5 mg IV q 12 mos for 2 doses G2: Zoledronic acic 5mg IV once and placebo at 12 mos G3: Placebo at baseline and 12 mos | RCT parallel | Yes | Yes | No
Meunier, 1999^307^ | raloxifene, 60 mg, 150 mg or placebo | RCT parallel | No information | Probably yes | No
Miller, 2008^308^ | G1: Bazedoxifene 10 mg G2: Bazedoxifene 20 mg G3: Bazedoxifene 40 mg G4: Raloxifene 60 mg G5: Pacebo | RCT parallel | Yes | Yes | No
Morii, 2003^309^ | raloxifene, 2 dosage amounts vs placebo | RCT parallel | No information | No information | Probably no
Murphy, 2001^272^ | G1: MK-677 25 mg daily G2: alendronate 10 mg daily G3: MK-677 and alendronate G4: placebo **pull out G2 and G4 data only for KQ5 | RCT parallel | Yes | Yes | No
Nakamura, 2012^239^ | G1: Denosumab 14 mg G2: Denosumab 60 mg G3: Denosumab 100 mg G4: Pacebo | RCT parallel | No information | No information | No
Orwoll, 2003^240^ | G1: 20 μg teriparatide: 151 G2:40 μg teriparatide: 139 G3: placebo: 147 | RCT parallel | Yes | Yes | No
Pazianas, 2008 ^298^ | Intervention: oral bisphosphate use Comparator: No bisphosphate use | case-control (how they described) | NA-not an RCT | NA-not an RCT | NA-not an RCT
Ravn, 1996^286^ | G1: 0.25mg ibandronate daily G2: 0.5mg ibandronate daily G3: 1.0mg ibandronate daily G4: 2.5mg ibandronate daily G5: 5.0 mg ibandronate daily G6: placebo | RCT parallel | No information | No information | No
Reginster, 2005^287^ | G1: 50mg ibandronate monthly 1 month, followed by 50 mg monthly 2 months for half the sample and 100 mg monthly for 2 months for the other half G2: 100mg ibandronate monthly for 3 months G3: 150mg ibandronate monthly for 3 months G4: placebo for 3 months | RCT parallel | No information | No information | Yes
Rhee, 2012^344^ | G1: Bisphosphonate use G2: non bisphosphonate use | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT
Riis, 2001^288^ | G1: 2.5mg ibandronate daily continuous therapy G2: 20mg ibandronate intermittent cyclical therapy G3: Placebo | RCT parallel | No information | No information | No
Samelson, 2014^345^ | G1: 60 mg Denosumab SC q 6 mos for 36 mos G2: Pacebo | Post-hoc or subgroup analysis of RCT | No information | No information | Probably no
Shiraki, 2003^283^ | G1: Risedronate 5 mg/d X 36 weeks G2: Pacebo | RCT cluster | No information | No information | No
Simon, 2013^346^ | G1: 60 mg Denosumab SC q 6 mos for 36 mos G2: Pacebo | RCT parallel | No information | No information | No
Sontag, 2010^242^ | G1: Raloxifene in women without baseline prevalent vertebral fracture G2: Pacebo in women without baseline prevalent vertebral fracture | Post-hoc or subgroup analysis of RCT | Yes | Yes | No
Sorensen, 2008^247^ | G1: bisphosphonate therapy* G2: placebo *Study examined all busphosphonates used in Danish prescription database, predominently alendronate, etidronate. Only 5 control patients used risendronate. No patients used zolendronic acid. | Case-control | NA-not an RCT | NA-not an RCT | NA-not an RCT
Tanko, 2003^289^ | G1: 5mg ibandronate weekly G2: 10mg ibandronate weekly G3: 20mg ibandronate weekly G4: placebo | RCT parallel | No information | No information | No
Thiebaud, 1997^290^ | G1: 2.5mg ibandronate IV every 3 months G2:.5mg ibandronate IV every 3 months G3: 1mg ibandronate IV every 3 months G4: 2mg ibandronate IV every 3 months G5: placebo | RCT parallel | No information | No information | No
Tucci, 1996^253^ | G1: Alendronate 5mg daily G2: Alendronate 10 mg daily G3: Alendronate 20 daily for 2 years then 5 mg daily for 1 year G4: placebo | RCT parallel | Yes | Yes | No
Van Staa, 1997^347^ | G1: Cyclinical Etidronate (1 or more cyclical etidronate prescriptions) G2: Nonosteoporosis control (as recorded in their medical records and no bisphosphonate use) | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT
Vestergaard, 2010^348^ | Gastric & esophagus events | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT
Vestergaard, 2011^349^ | Stroke | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT
Vestergaard, 2012^350^ | Cardiac and atherosclerosis | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT
Vestergaard, 2011^351^ | Femoral shaft and subtrochanteric fractures | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT
Vestergaard, 2012^352^ | Jaw disease | Cohort study | NA-not an RCT | NA-not an RCT | NA-not an RCT

Abbreviations: CEE=conjugated equine estrogen; G=group; KQ=key question; mg=milligram; mg/d=milligram per day; mo=month; NA=not applicable; RCT=randomized controlled trials.

Table 49 KQ 4 And 5 Risk Of Bias Assessment: Part 2

First Author, Year | FOR COHORTs: Was Selection into the Study Unrelated to Intervention or Unrelated to Outcome? | FOR COHORTs: Do Start of Follow-Up and Start of Intervention Coincide for Most Subjects? | FOR COHORTs: Were Adjustment Techniques Used That Are Likely To Correct for the Presence of Selection Biases? | FOR CASE-CONTROLS: Were the Controls Sampled from the Population That Gave Rise to the Cases, or Using Another Method That Avoids Selection Bias? | Bias Arising from Randomization or Selection? | Comments
Abrahamsen, 2010^273^ | Probably no | Yes | Yes | NA-not a case-control | Probably no | Women treated with alendronate by definition have increased risk of fracture, prompting their treatment with the drug.
Adachi, 2009^250^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably yes | Alendronate group had greater proportion of patients with history of UGI disease, active UGI disease, esophogeal disease, no statistical comparison is given, but the differences are large enough to warrant some concern for risk of bias as it does not appear that these differences were corrected for in the analysis.
Barrett-Connor, 2002^311^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Barrett-Connor, 2004^310^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | Not enough information on randomization process.
Bone, 2000^216^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Bone, 2008^237^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | No information on allocation concealment
Boonen, 2012^218^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Cartsos, 2008^297^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | Yes | data comes from medical claims data; possible errors in coding; does not include uninsured; sample not representative of total population
Chapurlat, 2013^284^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Cryer, 2005^252^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | No information on allocation concealment
Bsman, 2004^255^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Fogelman, 2000^226^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | NR
Greenspan, 2002^254^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | The article does not include information on randomization or concealment
Greenspan, 2003^249^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Grey, 2010^274^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably yes | The authors did not clearly adjust for baseline fracture.
Hosking, 2003^202^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Hosking, 2003^202^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Johnell, 2002^246^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Keech, 2005^312^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Kung, 2000^343^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | The article does not include information on randomization or concealment
Lasco, 2011^241^ | no | Yes | NA | NA-not a case-control | Yes | One arm has osteoporosis and other has osteopenia; the differences between arms could have served as a prognostic factor and contribute to confounding.
Lewiecki, 2007^236^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | No information on allocation concealment.
McCloskey, 2012^245^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No information | NR
McClung, 2004^285^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | no information provided on method of randomization or concealment
McClung, 2006^306^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | Not enough information on randomization process
McClung, 2006^209^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | NR
McClung, 2009^275^ | No | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | NR
Meunier, 1999^307^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | NR
Miller, 2008^308^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | NR
Morii, 2003^309^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | Some missing info
Murphy, 2001^272^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Nakamura, 2012^239^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | No information provided on method of randomization or concealment
Orwoll, 2003^240^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Pazianas, 2008 ^298^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | Yes | data comes from medical claims data; possible errors in coding; does not include uninsured; sample not representative of total population
Ravn, 1996^286^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | No information provided on method of randomization or concealment
Reginster, 2005^287^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | Absence of specific BMD criteria led to the inclusion of some participants were not osteoporotic
Rhee, 2012^344^ | Yes | No | No information | NA-not a case-control | Probably yes | Although the authors attempt to create an new user cohort by excluded anyone with a prescription for 16 months prior to the observation of the outcome, it’s unclear whether and how many participants might have been exposed to osteoporosis drugs before that period and stopped taking medications.
Riis, 2001^288^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | no information provided on method of randomization or concealment
Samelson, 2014^345^ | Yes | Yes | No information | NA-not a case-control | Probably no | NR
Shiraki, 2003^283^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | Probably no | NR
Simon, 2013^346^ | Yes | Yes | Probably yes | NA-not a case-control | Probably no | No detail on method of randomization and allocation concealment.
Sontag, 2010^242^ | Yes | Yes | NA | NA-not a case-control | Probably no | NR
Sorensen, 2008^247^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | Yes | No | NR
Tanko, 2003^289^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | no information provided on method of randomization or concealment
Thiebaud, 1997^290^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | no information provided on method of randomization or concealment Slight differences length of menopause
Tucci, 1996^253^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a case-control | No | NR
Van Staa, 1997^347^ | Yes | Yes | Yes | NA-not a case-control | Probably no | NR
Vestergaard, 2010^348^ | Yes | Yes | irrelevant, claim there is no missing data | NA-not a case-control | No | NR
Vestergaard, 2011^349^ | Yes | Yes | irrelevant, claim there is no missing data | Yes | No | NR
Vestergaard, 2012^350^ | Yes | Yes | irrelevant, claim there is no missing data | NA-not a case-control | No | NR
Vestergaard, 2011^351^ | Yes | Yes | irrelevant, claim there is no missing data | NA-not a case-control | No | NR
Vestergaard, 2012^352^ | Yes | Yes | irrelevant, claim there is no missing data | NA-not a case-control | No | NR

Abbreviations: NA=not applicable; NR=not reported.

Table 50 KQ 4 And 5 Risk Of Bias Assessment: Part 3

First Author, Year | FORCOHORTS AND CASE CONTROLS: Is Confounding of the Effect of Intervention Unlikely in This Study? | FOR COHORTS: Were Participants Analyzed According to Their Initial Intervention Group throughout Followup? | FOR COHORT STUDIES: Were Intervention Discontinuations or Switches Unlikely To Be Related to Factors That Are Prognostic for the Outcome? | FOR COHORT AND CASE-CONTROL STUDIES: Did the Authors Use an Appropriate Analysis Method That Adjusted for all the Critically Important Confounding Domains?
Abrahamsen, 2010^273^ | Probably no | Yes | No information | Probably yes
Adachi, 2009^250^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Barrett-Connor, 2002^311^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Barrett-Connor, 2004^310^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Bone, 2000^216^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Bone, 2008^237^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Boonen, 2012^218^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Cartsos, 2008 ^297^ | Probably no | NA-not a cohort | NA-not a cohort | No information
Chapurlat, 2013^284^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Cryer, 2005^252^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Bsman, 2004^255^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Fogelman, 2000^226^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Greenspan, 2002^254^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Greenspan, 2003^249^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Grey, 2010^274^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Hosking, 2003^202^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Hosking, 2003^202^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Johnell, 2002^246^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Keech, 2005^312^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Kung, 2000^343^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Lasco, 2011^241^ | No | Yes | No information | No information
Lewiecki, 2007^236^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
McCloskey, 2012^245^ | Probably yes | Yes | Yes | Probably yes
McClung, 2004^285^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
McClung, 2006^306^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
McClung, 2006^209^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
McClung, 2009^275^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Meunier, 1999^307^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Miller, 2008^308^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Morii, 2003^309^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Murphy, 2001^272^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Nakamura, 2012^239^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Orwoll, 2003^240^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Pazianas, 2008 ^298^ | Probably no | NA-not a cohort | NA-not a cohort | Yes
Ravn, 1996^286^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Reginster, 2005^287^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Rhee, 2012^344^ | Yes | Yes | Unclear, all switches dropped from analysis | NA
Riis, 2001^288^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Samelson, 2014^345^ | Probably yes | Yes | Yes | Probably yes
Shiraki, 2003^283^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Simon, 2013^346^ | Probably yes | Yes | Yes | Probably yes
Sontag, 2010^242^ | Yes | NA | Yes | No
Sorensen, 2008^247^ | No | NA-not a cohort | NA-not a cohort | Yes
Tanko, 2003^289^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Thiebaud, 1997^290^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Tucci, 1996^253^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort
Van Staa, 1997^347^ | Yes | NA | NA | NA
Vestergaard, 2010^348^ | No | No information | No information | No
Vestergaard, 2011^349^ | No | No information | No information | No
Vestergaard, 2012^350^ | No | No information | No information | No
Vestergaard, 2011^351^ | No information | No information | No | Yes
Vestergaard, 2012^352^ | No | No information | No information | No

Abbreviations: KQ=key question; NA=not applicable.

Table 51 KQ 4 And 5 Risk Of Bias Assessment: Part 4

First Author, Year | FOR COHORT STUDIES: Did the Authors Avoid Adjusting for Postintervention Variables? | FOR COHORT STUDIES Did the Authors Use an Appropriate Analysis Method That Adjusted for All the Critically Important Confounding Domains and for Time-Varying Confounding? | Bias Arising from Confounding? | Comments
Abrahamsen, 2010^273^ | Yes | Probably yes | Probably yes | NR
Adachi, 2009^250^ | NA-not a cohort | NA-not a cohort | No | NR
Barrett-Connor, 2002^311^ | NA-not a cohort | NA-not a cohort | NA | NR
Barrett-Connor, 2004^310^ | NA-not a cohort | NA-not a cohort | NA | NR
Bone, 2000^216^ | NA-not a cohort | NA-not a cohort | No | NR
Bone, 2008^237^ | NA-not a cohort | NA-not a cohort | no | NR
Boonen, 2012^218^ | NA-not a cohort | NA-not a cohort | No | NR
Cartsos, 2008 ^297^ | NA-not a cohort | NA-not a cohort | Probably yes | Possible patients could have been taking other treatments that were not documented; no mention of how confounding was handled or if considered
Chapurlat, 2013^284^ | NA-not a cohort | NA-not a cohort | N/A | NR
Cryer, 2005^252^ | NA-not a cohort | NA-not a cohort | No | NR
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | NA-not a cohort | NA-not a cohort | No | NR
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | NA-not a cohort | NA-not a cohort | no | NR
Eisman, 2004^255^ | NA-not a cohort | NA-not a cohort | No | NR
Fogelman, 2000^226^ | NA-not a cohort | NA-not a cohort | No information | NR
Greenspan, 2002^254^ | NA-not a cohort | NA-not a cohort | No | NR
Greenspan, 2003^249^ | NA-not a cohort | NA-not a cohort | No | NR
Grey, 2010^274^ | NA-not a cohort | NA-not a cohort | No | NR
Hosking, 2003^202^ | NA-not a cohort | NA-not a cohort | No information | NR
Hosking, 2003^202^ | NA-not a cohort | NA-not a cohort | No | NR
Johnell, 2002^246^ | NA-not a cohort | NA-not a cohort | Probably no | NR
Keech, 2005^312^ | NA-not a cohort | NA-not a cohort | NA | NR
Kung, 2000^343^ | NA-not a cohort | NA-not a cohort | No | NR
Lasco, 2011^241^ | No information | No information | Yes | One arm has osteoporosis and other has osteopenia; the differences between arms could have served as a prognostic factor and contribute to confounding
Lewiecki, 2007^236^ | NA-not a cohort | NA-not a cohort | No | NR
McCloskey, 2012^245^ | Probably yes | NA | No information | The analysis was prespecified according to the methods and does not appear to be a subgroup. The are looking at efficacy across the range of baseline FRAX risk.
McClung, 2004^285^ | NA-not a cohort | NA-not a cohort | NA | NA, Not a cohort or case control
McClung, 2006^306^ | NA-not a cohort | NA-not a cohort | No | Not a cohort or case control
Mc Clung, 2006^209^ | NA-not a cohort | NA-not a cohort | No | NR
Mc Clung, 2009^275^ | NA-not a cohort | NA-not a cohort | No | RCT design mitigates risk of confounding from known and unknown factors.
Meunier, 1999^307^ | NA-not a cohort | NA-not a cohort | Probably no | NR
Miller, 2008^308^ | NA-not a cohort | NA-not a cohort | No | NR
Morii, 2003^309^ | NA-not a cohort | NA-not a cohort | Probably no | NR
Murphy, 2001^272^ | NA-not a cohort | NA-not a cohort | No | NR
Nakamura, 2012^239^ | NA-not a cohort | NA-not a cohort | NA | NR
Orwoll, 2003^240^ | NA-not a cohort | NA-not a cohort | No | Not a cohort study
Pazianas, 2008 ^298^ | NA-not a cohort | NA-not a cohort | Probably no | possible patients could have been taking other treatments that were not documented
Ravn, 1996^286^ | NA-not a cohort | NA-not a cohort | NA, Not a cohort or case control | NR
Reginster, 2005^287^ | NA-not a cohort | NA-not a cohort | NA, Not a cohort or case control | NR
Rhee, 2012^344^ | No | No | Yes | They also dropped all patients with switches, which potentially selectively drops patients with reactions to initial drug therapy
Riis, 2001^288^ | NA-not a cohort | NA-not a cohort | NA, Not a cohort or case control | NR
Samelson, 2014^345^ | Yes | NA, if item 10 is yes/probably yes | Probably no | Treatment assignment is random; CV risks were balanced between groups.
Shiraki, 2003^283^ | NA-not a cohort | NA-not a cohort | No information | NR
Simon, 2013^346^ | Probably yes | NA | Probably no | NR
Sontag, 2010^242^ | No | NA | Yes | During a 1-year extension phase, women were permitted to take other bone-active agents, except for oral estrogen or estrogen-progestin therapy. 16.4% and 12.3% of women in the placebo and raloxifene 60 mg/day groups, respectively, used other bone-active agent
Sorensen, 2008^247^ | NA-not a cohort | NA-not a cohort | No | NR
Tanko, 2003^289^ | NA-not a cohort | NA-not a cohort | NA, Not a cohort or case control | NR
Thiebaud, 1997^290^ | NA-not a cohort | NA-not a cohort | NA, Not a cohort or case control | NR
Tucci, 1996^253^ | NA-not a cohort | NA-not a cohort | No | NR
Van Staa, 1997^347^ | NA | NA | No | NR
Vestergaard, 2010^348^ | Yes | Probably no | Probably yes | Given the results it’s likely that there were other underlying variables that they didn’t fully account for. For example, are all NSAIDS in the drugs registry? What about OTC NSAIDS? Given that a third of their sample had fractures, likely they had pain t
Vestergaard, 2011^349^ | Yes | Probably no | Probably yes | NR
Vestergaard, 2012^350^ | Yes | Probably no | Probably yes | Given the results it’s likely that there were other underlying variables that they didn’t fully account for. For example, did they fully control for all other causes of MI such as smoking and hypertension.
Vestergaard, 2011^351^ | Probably no | Probably yes | No | NR
Vestergaard, 2012^352^ | Yes | Probably no | Probably yes | NR

Abbreviations: FRAX=Fracture Risk Assessment tool; KQ=key question; MI=myocardial infarction; NA=not applicable; NR=not reported; NSAIDS=nonsteroidal anti-inflammatory drugs; OTC=over the counter.

Table 52 KQ 4 And 5 Risk Of Bias Assessment: Part 5

First Author, Year | FORCOHORTS AND CASE CONTROLS: Is Intervention Status Well Defined? | FOR COHORTS AND CASE CONTROLS: Was Information on Intervention Status Recorded at the Time of Intervention? | FOR COHORTS AND CASE CONTROLS Was Information on Intervention Status Unaffected by Knowledge of the Outcome or Risk of the Outcome? | Bias Arising from Measurement of the Intervention? | Comments
Abrahamsen, 2010^273^ | Yes | Yes | Yes | Probably no | NR
Adachi, 2009^250^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Barrett-Connor, 2002^311^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA | NR
Barrett-Connor, 2004^310^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Bone, 2000^216^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Bone, 2008^237^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Boonen, 2012^218^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA-not a cohort | NR
Cartsos, 2008 ^297^ | No | No | Probably yes | Yes | intervention based on dispensing information from claims data, information on dose not available
Chapurlat, 2013^284^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA | NR
Cryer, 2005^252^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Eisman, 2004^255^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Fogelman, 2000^226^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No information | NR
Greenspan, 2002^254^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Greenspan, 2003^249^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Grey, 2010^274^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Hosking, 2003^202^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No information | NR
Hosking, 2003^202^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Johnell, 2002^246^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | NR
Keech, 2005^312^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA | NR
Kung, 2000^343^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Lasco, 2011^241^ | Yes | Yes | No information | Probably no | NR
Lewiecki, 2007^236^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
McCloskey, 2012^245^ | Yes | Yes | Yes | No | It was prespecified.
McClung, 2004^285^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA, not a cohort or case control | NR
McClung, 2006^306^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | not a cohort or case control
McClung, 2006^209^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
McClung, 2009^275^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | RCT Design so all items NA.
Meunier, 1999^307^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | NR
Miller, 2008^308^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | no | NR
Morii, 2003^309^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | Probably no | NR
Murphy, 2001^272^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Nakamura, 2012^239^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA | NR
Orwoll, 2003^240^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | no | NR
Pazianas, 2008 ^298^ | No | No | Probably yes | Yes | intervention based on dispensing information from claims data, information on dose etc. not available
Ravn, 1996^286^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA, not a cohort or case control | NR
Reginster, 2005^287^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA, not a cohort or case control | NR
Rhee, 2012^344^ | Yes | Yes | Yes | No | NR
Riis, 2001^288^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA, not a cohort or case control | NR
Samelson, 2014^345^ | Probably yes | Yes | Yes | Probably no | NR
Shiraki, 2003^283^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No information | NR
Simon, 2013^346^ | Yes | Yes | Yes | Probably no | NR
Sontag, 2010^242^ | Yes | Yes | Yes | Probably no | NR
Sorensen, 2008^247^ | Yes | Yes | Yes | No | NR
Tanko, 2003^289^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA, not a cohort or case control | NR
Thiebaud, 1997^290^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | NA, not a cohort or case control | NR
Tucci, 1996^253^ | NA-not a cohort | NA-not a cohort | NA-not a cohort | No | NR
Van Staa, 1997^347^ | No | Yes | Yes | Yes | intervention status defined as patients who had received a prescription
Vestergaard, 2010^348^ | No | No information | Yes | Probably yes | NR
Vestergaard, 2011^349^ | No | No information | Yes | Probably yes | NR
Vestergaard, 2012^350^ | No | No information | Yes | Probably yes | NR
Vestergaard, 2011^351^ | Yes | Probably yes | None | No | NA, no attrition
Vestergaard, 2012^352^ | No | No information | Yes | Probably yes | NR

Abbreviations: NA=not applicable; NR=not reported; RCT=randomized controlled trials.

Table 53 KQ 4 And 5 Risk Of Bias Assessment: Part 6

First Author, Year | FOR RCTS and COHORTS: What Was the Overall Attrition? What Wasthe Attrition by Group? Did Attrition Vary for Different Outcomes? | FOR RCTS and COHORTS: Did the Study Have High Attrition Raising Concern for Bias? | FOR RCTS and COHORTS: Are the Proportion of Participants and Reasons for Missing Data Similar across Interventions? | FOR CASE-CONTROLS: Are the Proportion of Participants and Reasons for Missing Data Similar across Cases and Controls?
Abrahamsen, 2010^273^ | Overall: NR G1: 3.1% G2: 3.0% Vary by outcome: Probably no | No | Yes | NA-not a case-control
Adachi, 2009^250^ | Overall: 16.2 [%] G1: 18.6 [%] G2: 11.6% [%] Vary by Outcome? No | No | Yes | NA-not a case-control
Barrett-Connor, 2002^311^ | Overall:26% G1: 26% G2: 25% G3: 26% Vary by Outcome? No | Yes | No | NA
Barrett-Connor, 2004^310^ | Overall: 26% G1: 26.2 G2: 25.2 G3: 26.4 Vary by Outcome? no | No | Yes | NA
Bone, 2000^216^ | Overall: 24.7 [%] G1: 24/92 = 26% G4: 16/50 = 32% Other reasons for attrition: withdrew conset, lost to follow-up, protocol violations, no signficant varation between groups | Yes | Yes | NA-not a case-control
Bone, 2008^237^ | Overall attrition: 3/332=0.09% G1: 2/166 (1.2%) G2: 1/166 (0.06%) | No | Yes | NA-not a cohort
Boonen, 2012^218^ | Overall: 11% G1: 10% G2: 12% Vary by Outcome? No | No | Yes | na-not a case control
Cartsos, 2008^297^ | NA-no attrition | NA-no attrition | NA-no attrition | NA-no attrition
Chapurlat, 2013^284^ | Overall:0.67 G1: 0 G2: 1.3 Vary by Outcome? No Follow-up Overall: Unclear G1: Unclear G2: Unclear | No | Yes | NA-no attrition
Cryer, 2005^252^ | Overall: 13.7 [%] G1: 13.8 [%] G2: 13.5[%] G3: [%] No | No | Probably yes | NA-not a case-control
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | Patients missing follow-up xray Overall: 379 / 6459 (5.9%) G1: 198 / 3195 (6.2%) G2: 181 /3183 (5.7) | No | Yes | NA-not a case-control
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | Attrition varies by outcome, lowest for fractures: 475/7868 (6.03%) G1: 231/3933 (5.87%) G2: 244/3935 (6.20%) | No | Yes | NA-not a cohort
Eisman, 2004^255^ | Overall: 6.2 [%] G1: 8.0 [%] G2: 4.5 [%] Vary by Outcome? No | No | Probably yes | NA-not a case-control
Fogelman, 2000^226^ | G1: 40/179 = 22% G2: 37/180 = 21% | Yes | Yes | NA-not a case control
Greenspan, 2002^254^ | Overall: 6.9% G1: 6.3% G2: 7.5% Vary by Outcome? No | No | Yes | NA-not a case-control
Greenspan, 2003^249^ | Overall: 10[%] G1: 8.6% G2: 9.7 % G3: 9.6 % G4: 10.8% Vary by Outcome? No | No | Yes | NA-not a case-control
Grey, 2010^274^ | Overall: 2 [%] G1: 4 [%] G2: 0 [%] Vary by Outcome? No Information | No | Yes | NA-not a case-control
Hosking, 2003^202^ | Attrition was only reported at 3 months. G1: 19.8% G2: 21.5% G2: 17.6% | No | No | NA-not a case control
Hosking, 2003^202^ | Overall: 25[%] G1: 21.5 [%] G2: 19.8 [%] G3: 17.6 [%] Vary by Outcome? Yes Clincal AE leading to discontinuation: Overall: 17 [%] G1: 14.1 [%] G2: 14.0 [%] G3: 11.1 [%] **of note these are attrition % at 3 months. The study went on for 12 months, b | Yes | Yes | No
Johnell, 2002^246^ | Overall: 17%; differences by group NR | No | Yes | NA-no attrition
Keech, 2005^312^ | Overall: NR G1: 29% G2: 33% Vary by Outcome? No | Yes | No | NA
Kung, 2000^343^ | Overall:80 [%] G1: 80[%] G2: 80 [%] G3: [%] Vary by Outcome? No | Yes | Yes | NA-not a case-control
Lasco, 2011^241^ | Overall:0 | NA-no attrition | NA-no attrition | NA
Lewiecki, 2007^236^ | Overall attrition: 5/365=1.00% G1: 0/46 (0%) G2: 5/319 (1.57%) | No | Yes | NA-not a cohort
McCloskey, 2012^245^ | Overall:82% G1: NR G2: NR Vary by Outcome? Probably No | No | No information | NA-not a case-control
McClung, 2004^285^ | Overall: 16% G1: 15% G2: 13% G3: 18% G4: 17% no | No | Yes | NA-not a case-control
Mc Clung, 2006^306^ | Overall:36% G1: 37% G2: 30% G3: 29% G4: 31% Vary by Outcome? No | Yes | No information | NA-not a case-control
Mc Clung, 2006^209^ | Overall: 10 [%] Not reported by group overal. For below only reported by drug (not dosing group) Vary by Outcome? Yes Withdrawal of consent G1-G7: 8 [%] G8: 2 [%] G9: 7 [%] Adverse effects G1-G7: 2 [%] G8: 0 [%] G9: 2 [%] | No | Yes | NA-not a case-control
Mc Clung, 2009^275^ | Overall:90% (Calculated) G1: 91.4% G2: 85.1% G3: 93.1% Vary by Outcome? No | No | no | NA-not a case-control
Meunier, 1999^307^ | Overall: 20 of 129 at 24 months (19%), of these, 14 in year 1; differences by group NR | No | Yes | NA-no attrition
Miller, 2008^308^ | Overall:[%] 29.7 percent (N=470) discontinued treatment, another 2.9 % (46) failed to return. Additionally the flow chart shows patients who did not complete because of “subject request” and “other.” | Yes | Yes | NA-not a case-control
Morii, 2003^309^ | Overall: 13%; differences by group NR | No | Yes | NA-no attrition
Murphy, 2001^272^ | Overall:15% at 6 mo, 30% at 12 months, 41% at 18 months No data by group G1: [%] G2: [%] G3: [%] Vary by Outcome? No Information | No for 6 months, Yes for 12 and 18 months. | Probably yes | NA-not a case-control
Nakamura, 2012^239^ | Overall:8.0 G1: (5/53)9.4 G2: (4/54) 7.4 G3: (5/50)10 G4: (3/55) 5.5 Vary by Outcome? Probably No | No | No information | NA
Orwoll, 2003^240^ | Overall:77[17.6%] G1:17 [12%] G2:28 [19%] G3:36 [26%] No Information by outcome | Yes | No | NA-no attrition
Pazianas, 2008 ^298^ | NA-no attrition | NA-no attrition | NA-no attrition | NA-no attrition
Ravn, 1996^286^ | Overall: 39/180, 22% G1: 4/30,13% G2: 8/30, 27% G3: 4/30, 13% G4: 6/30, 20% G5: 12/30, 40% G6: 5/30, 17% no | Yes | Yes | NA-not a case-control
Reginster, 2005^287^ | Overall: 3% G1: 0 G2: 0 G3: 0 G4: 3% G5: 8% no | No | Yes | NA-not a case-control
Rhee, 2012^344^ | No attrition because data are from registry | NA-no attrition | NA-no attrition | NA-no attrition
Riis, 2001^288^ | Overall: 14% G1: 15% G2: 15% G3: 11% no | No | Yes | NA-not a case-control
Samelson, 2014^345^ | Overall:82% for the main FREEDOM trial, but this analysis was a subgroup analysis of patients at increased CV risk and with adequate imaging studies. Only 1045 of 2363 patients eligible had evaluation data at baseline and followup. G1: NR G2: NR Vary by | Yes | No information | NA-not a case-control
Shiraki, 2003^283^ | G1: 9/56=16% G2: 9/54=17% | No | No information | NA-not a case control
Simon, 2013^346^ | Overall:82% (This is for the overall FREEDOM study; 83% in DXA substudy, 86% in QCT substudy, attrition by treatment group NR) Vary by Outcome? Probably No | No | No information | NA-not a case-control
Sontag, 2010^242^ | This article reports only ITT results, but based on original trial, Overall:26% G1: 26% G2: 25% G3: 26% Vary by Outcome? no | Yes | No | NA
Sorensen, 2008^247^ | NA-not an RCT | NA-not an RCT | NA-not an RCT | Yes
Tanko, 2003^289^ | Overall: 14% G1: NR G2: NR G3: NR G4: NR G5: NR no | No | Yes | NA-not a case-control
Thiebaud, 1997^290^ | Overall: 10% G1: 12.5% (3/24) G2: 3.7% (1/27) G3: 11.5% (3/26) G4: 8.7% (2/23) G5: 7.7% (2/26) Vary by Outcome? No | No | Yes | NA-not a case-control
Tucci, 1996^253^ | Overall:29/478 = 6.0% (from Ns in Table IV) G1: 9.2% G2: 6.4% G3: 8.5% G4: 3.1% | No | No information | NA-not a case-control
Van Staa, 1997^347^ | No attrition | NA-no attrition | NA | NA
Vestergaard, 2010^348^ | None | No | NA, no attrition | NA, no attrition
Vestergaard, 2011^349^ | None | No | NA, no attrition | NA, no attrition
Vestergaard, 2012^350^ | None | No | NA, no attrition | NA, no attrition
Vestergaard, 2011^351^ | NA, no attrition | NA, no attrition | No | NA-not an RCT
Vestergaard, 2012^352^ | None | No | NA, no attrition | NA, no attrition

Abbreviations: AE=adverse event; DXA=dual energy x-ray absorptiometry; FREEDOM=Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months; G=group; KQ=key question; NA=not applicable; NR=not reported; QCT=quantitative computed tomography; RCT=randomized controlled trials.

Table 54 KQ 4 And 5 Risk Of Bias Assessment: Part 7

First Author, Year | FOR ALL STUDIES: Were Appropriate Statistical Methods Used To Account for Missing Data? | Bias Arising from Missing Outcome Data? | Comments
Abrahamsen, 2010^273^ | Yes | No | NR
Adachi, 2009^250^ | No information | Probably no | Authors do not specifically say they perform an intention to treat analysis.
Barrett-Connor, 2002^311^ | Yes | Probably yes | NR
Barrett-Connor, 2004^310^ | Yes | No | NR
Bone, 2000^216^ | Yes | Probably yes | There was >20% attrition, and over 30% attrition in one of the arms.
Bone, 2008^237^ | Yes | No | NR
Boonen, 2012^218^ | Yes | No | NR
Cartsos, 2008 ^297^ | NA-no attrition | No information | No mention of how missing data was handled
Chapurlat, 2013^284^ | Yes | Probably no | NR
Cryer, 2005^252^ | Yes | Probably no | There is a small difference in reasons for discontinuation. More patients in placebo dropped out due to any clinical AE, however this difference is judged to be small.
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | Yes | No | Missing data = missing xray at follow-up FIT1 (Black, 1996) Overall: 81 / 2027 = 4.0% G1: 41 / 981 = 4.2% G2: 40 / 965 = 4.1% FIT2 (Cummings, 1998 (8400)) Overall: 298/4432 (6.7%) G1: 157 / 2214 (7.1%) G2: 141 / 2218 (6.4%) Combining FIT1 and FIT2
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | Yes | no | NR
Eisman, 2004^255^ | Yes | Probably no | More withdrawals for clinical AE in alendronate group vs placebo, but no testing. Results show no difference in discontinuation for UGI AEs
Fogelman, 2000^226^ | Yes | probably no | NR
Greenspan, 2002^254^ | Yes | No | NR
Greenspan, 2003^249^ | Yes | No | ITT analysis
Grey, 2010^274^ | Yes | No | NR
Hosking, 2003^202^ | Unclear | Probably yes | Unclear what attrition was at 12 months.
Hosking, 2003^202^ | Yes | No information | NR
Johnell, 2002^246^ | Yes | Probably no | NR
Keech, 2005^312^ | Yes | Probably yes | NR
Kung, 2000^343^ | Yes | Probably yes | NR
Lasco, 2011^241^ | NA-no attrition | Probably no | NR
Lewiecki, 2007^236^ | No information | no | NR
McCloskey, 2012^245^ | Probably yes | Probably no | NR
McClung, 2004^285^ | Yes | No | NR
McClung, 2006^306^ | Yes | Probably yes | 17, not a case control; overall attrition a little high
McClung, 2006^209^ | Yes | No | NR
McClung, 2009^275^ | Probably no | unclear | Risk of bias for harms data because it is limited to ITT analysis.
Meunier, 1999^307^ | Yes | No | NR
Miller, 2008^308^ | Yes | probably no | NR
Morii, 2003^309^ | Yes | Probably no | NR
Murphy, 2001^272^ | Probably yes | Probably yes | Per protocol analysis probably okay for harms outcomes. Table 6 suggests similar AE profile, but reasons for discontinuation not provided by group.
Nakamura, 2012^239^ | Yes | Probably no | NR
Orwoll, 2003^240^ | Yes | Probably yes | Differential attrition between arms
Pazianas, 2008 ^298^ | NA-no attrition | No information | No mention of how missing data was handled
Ravn, 1996^286^ | No information | Probably no | high overall and differential attrition; however, safety appears to have been collected and reported on a larger subset of the population
Reginster, 2005^287^ | Yes | No | NR
Rhee, 2012^344^ | NA-no attrition | no | NR
Riis, 2001^288^ | Yes | No | NR
Samelson, 2014^345^ | No | Probably yes | NR
Shiraki, 2003^283^ | Yes | Probably no | NR
Simon, 2013^346^ | Yes | Probably no | NR
Sontag, 2010^242^ | Yes | Probably yes | NR
Sorensen, 2008^247^ | Yes | No | * Authors report Danish registry information is complete.
Tanko, 2003^289^ | Yes | Probably no | Unable to calculate group attrition
Thiebaud, 1997^290^ | Yes | Probably no | Used ITT but one patient who dropped out before treatment because of inability to administer the drug was not included. Missing values were not replaced.
Tucci, 1996^253^ | Yes | Probably no | Study was extended for a third year, 14 subjects did not consent to blinded treatment for a third year, 5 declined third year altogether.
Van Staa, 1997^347^ | NA | No information | The study did not provide any information on attrition or missing data.
Vestergaard, 2010^348^ | NA, no attrition | No | NR
Vestergaard, 2011^349^ | NA, no attrition | No | NR
Vestergaard, 2012^350^ | NA, no attrition | No | NR
Vestergaard, 2011^351^ | NA-not an RCT | No information | NR
Vestergaard, 2012^352^ | NA, no attrition | No | NR

Abbreviations: AE=adverse event; FIT=fracture intervention trial; ITT=intent to treat; KQ=key question; NA=not applicable; NR=not reported; UGI=upper gastrointestinal.

Table 55 KQ 4 And 5 Risk Of Bias Assessment: Part 8

First Author, Year | FOR RCTs OF TREATMENT: Were the Patients Unaware of the Intervention Status of Participants? | FOR ALL RCTs: Were the Trial Personnel and Clinicians Unaware of the Intervention Status of Participants? | FOR ALL STUDIES: Was Intervention Fidelity Adequate? | FOR ALL STUDIES: Did the Study Have Enough Cross-Overs or Contamination That Would Raise Concern for Bias? | Bias Arising from Departures From Intended Interventions? | Departures from Interventions Comments
Abrahamsen, 2010^273^ | NA-not an RCT | NA-not an RCT | Probably yes | No information | Probably no | NR
Adachi, 2009^250^ | Yes | Yes | No information | No information | Probably no | No data on adherence
Barrett-Connor, 2002^311^ | Yes | Yes | Probably yes | Probably no | Probably no | In year 4 could take additional medications.
Barrett-Connor, 2004^310^ | Yes | Yes | Yes | No | No | stated in larger study that 92% of women took more than 80% of study medication
Bone, 2000^216^ | Yes | Yes | No information | No information | No | The authors did not report crossover, but were thorough about patient accounting
Bone, 2008^237^ | Probably no | Probably no | NA (subcutaneous) | No information | Probably no | NR
Boonen, 2012^218^ | Probably no | Probably no | NA (subcutaneous) | No information | Probably no | NR
Cartsos, 2008 ^297^ | NA-not an RCT | NA-not an RCT | No information | No information | No information | Fidelity, not sure if participants took medication correctly; no information on cross-overs but not clear if other treatments were allowed
Chapurlat, sup2013^284^ | Yes | Yes | Yes | No | No | NR
Cryer, 2005^252^ | Yes | Yes | Yes | No | No
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | Yes | Yes | Yes | No | No | NR
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | Probably no | Probably no | NA (subcutaneous) | No information | Probably no | NR
Eisman, 2004^255^ | NR | Yes | Yes | No | No | mean compliance 95% and 96% for alendronate and placebo groups
Fogelman, 2000^226^ | Yes | Yes | No information | Probably no | Probably no | NR
Greenspan, 2002^254^ | Yes | Yes | Probably yes | Probably no | Probably no | NR
Greenspan, 2003^249^ | Yes | Yes | Yes | No | No | NR
Grey, 2010^274^ | Yes | Yes | Yes | No | No | NR
Hosking, 2003^202^ | Yes | Yes | Yes | No | No | NR
Hosking, 2003^202^ | Yes | Yes | Yes | No information | No | >75% adherence to medications
Johnell, 2002^246^ | Yes | Yes | Yes | No | Probably no | NR
Keech, 2005^312^ | Yes | Yes | Yes | No | No | NR
Kung, 2000^343^ | Yes | Yes | No information | No information | Probably no | NR
Lasco, 2011^241^ | NA-not an RCT | NA-not an RCT | Probably yes | Probably no | Probably no | NR
Lewiecki, 2007^236^ | Probably no | Probably no | NA (subcutaneous) | No information | Probably no | NR
McCloskey, 2012^245^ | Yes | Yes | Yes | No information | No | NR
McClung, 2004^285^ | Yes | Yes | Yes | No | No | compliance in mid to high 80s
McClung, 2006^306^ | Yes | Yes | No information | No information | probably yes | adherence unknown
McClung, 2006^209^ | Yes | Yes | Yes | No | No | Of note-double blinding for denosumab but NOT alendronate (open label); all answers are for denosumab. For alendronate (no, no, yes, no information, probably yes)
McClung, 2009^275^ | Yes | Yes | Probably yes | Probably no | Probably no | NR
Meunier, 1999^307^ | Yes | Yes | Probably yes | No | No | NR
Miller, 2008^308^ | Yes | probably yes | No information | No information | Probably no | NR
Morii, 2003^309^ | Yes | No information | Probably yes | No | No | NR
Murphy, 2001^272^ | Yes | Yes | Yes | No | No | Only 4 patients failed to take >75% of assigned drug
Nakamura, 2012^239^ | Probably yes | Probably yes | Yes | No | No | NR
Orwoll, 2003^240^ | Yes | Yes | Yes | Probably no | Probably no | Patient-administered injections of placebo or drug
Pazianas, 2008^298^ | NA-not an RCT | NA-not an RCT | No information | No information | No information | Fidelity, not sure if participants took medication correctly; no information on cross-overs but not clear if other treatments were allowed
Ravn, 1996^286^ | Yes | No | No information | No | Probably no | Data safety review committee (DSRC) was not blinded to treatment, and they monitored adverse events during each step. Information on compliance was not provided
Reginster, 2005^287^ | NA-not an RCT | NA-not an RCT | Probably no | No | Probably yes | No way to determine if participants took dose
Rhee, 2012^344^ | Yes | Yes | Yes | No | No | NR
Riis, 2001^288^ | Probably yes | Probably yes | Yes | No | Probably no | NR
Samelson, 2014^345^ | Yes | Yes | Probably yes | No information | Probably no | NR
Shiraki, 2003^283^ | Yes | Yes | No information | Probably no | Probably no | NR
Simon, 2013^346^ | Yes | Yes | Probably yes | No information | No | NR
Sontag, 2010^242^ | Probably yes | Probably yes | No | Probably no | Probably no | Study reported as double-blind but no other details provided. Placebo arm received active treatment after 1 year but results are not reported separately for before and after receipt of active treatment
Sorensen, 2008^247^ | NA-not an RCT | NA-not an RCT | Probably yes | No information | Probably no | NR
Tanko, 2003^289^ | Yes | Yes | No information | No | Probably no | Large proportion of patients in each study group took ≥75% of study medication: 89% placebo, 88.8% (5 mg), 90.1% (10 mg) and 88.7% (20 mg) patients.
Thiebaud, 1997^290^ | Yes | No | No information | No | Probably no | Information on compliance was not provided Investigator was not blind for all arms
Tucci, 1996^253^ | Yes | Yes | Yes | No | No | Investigators only evaluated blinded results (excluded patients who declined blinding for third year)
Van Staa, 1997^347^ | NA-not an RCT | NA-not an RCT | No information | No | No information | Did not evaluate adherence
Vestergaard, 2010^348^ | NA-not an RCT | NA-not an RCT | No information | No information | No information | NR
Vestergaard, 2011^349^ | NA-not an RCT | NA-not an RCT | No information | No information | No information | NR
Vestergaard, 2012^350^ | NA-not an RCT | NA-not an RCT | No information | No information | No information | NR
Vestergaard, 2011^351^ | No information | NA-no benefits outcomes | NA-no benefits outcomes | NA-no benefits outcomes | Probably no | NR
Vestergaard, 2012^352^ | NA-not an RCT | NA-not an RCT | No information | No information | No information | NR

Abbreviations: KQ=key question; NA=not applicable; RCT=randomized controlled trials.

Table 56 KQ 4 and 5 Risk of Bias Assessment: Part 9

First Author, Year | FOR ALL STUDIES: Were Benefit Outcomes Adequately Described, Pre-specified, Valid, and Reliable? | FOR ALL STUDIES: Were Similar Techniques Used among Groups To Ascertain Harm Outcomes? | FOR ALL STUDIES: Was the Duration of Follow-Up Adequate To Assess Harm Outcomes? | Bias Arising from Measurement of Outcomes? | Comments
Abrahamsen, 2010^273^ | NA-no benefits outcomes | Probably yes | Probably yes | Probably yes | Not able to identify atypia.
Adachi, 2009^250^ | NA-no benefits outcomes | Yes | Yes | Probably no | There was not specific information about how often patient’s assessed for harms, though did describe adequate blinding of patients.
Barrett-Connor, 2002^311^ | NA-no benefits outcomes | Yes | Yes | No | NR
Barrett-Connor, 2004^310^ | Yes | Yes | Yes | No | NR
Bone, 2000^216^ | Probably Yes | Probably yes | Yes | Probably yes | Report that patients were seen at 3, 6, 12, 18, 24 months, but don’t specifically describe clinical assessment (i.e. patient assessed for harms at this time)
Bone, 2008^237^ | Yes | Yes | Probably yes | Probably no | NR
Boonen, 2012^218^ | Yes | Yes | Yes | No | NR
Cartsos, 2008 ^297^ | NA-no benefits outcomes | Probably yes | Probably yes | Probably yes | Not clear how outcomes were measured due to only a code being provided
Chapurlat, 2013^284^ | Yes | Probably yes | Yes | No | NR
Cryer, 2005^252^ | Yes | Yes | Yes | No | NR
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | Yes | Yes | Yes | No | NR
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | Yes | Yes | Probably yes | Probably no | NR
Eisman, 2004^255^ | Yes | Yes | Yes | No | NR
Fogelman, 2000^226^ | Probably Yes | Yes | Yes | Probably no | NR
Greenspan, 2002^254^ | NA-no benefits outcomes | Yes | Yes | No | NR
Greenspan, 2003^249^ | Yes | Yes | Yes | No | NR
Grey, 2010^274^ | Probably yes | Probably yes | Yes | Probably no | Looked at parent article to identify clinical assessment of harms - no information. The antiresorptive effects of a single dose of zoledronate persist for two years: a randomized, placebo-controlled trial in osteopenic postmenopausal women.
Hosking, 2003^202^ | NA-no benefits outcomes | Yes | Probably yes | Probably no | NR
Johnell, 2002^246^ | NA-no benefits outcomes | Yes | Probably yes | Probably no | 12 month study
Keech, 2005^312^ | NA-no benefits outcomes | Yes | Yes | No | NR
Kung, 2000^343^ | NA-no benefits outcomes | Yes | Yes | Probably yes | No information on how harms ascertained
Lasco, 2011^241^ | NA-no benefits outcomes | No information | No information | Probably no | NR
Lewiecki, 2007^236^ | Yes | Yes | Probably yes | Probably no | NR
McCloskey, 2012^245^ | Yes | NA-no harms outcomes | NA-no harms outcomes | No | NR
McClung, 2004^285^ | NA-no benefits outcomes | Yes | Yes | No | NR
McClung, 2006^306^ | NA-no benefits outcomes | Yes | Yes | No | NR
McClung, 2006^209^ | Yes | Yes | Yes | No | NR
McClung, 2009^275^ | NA-no benefits outcomes | Yes | Yes | Probably no | NR
Meunier, 1999^307^ | NA-no benefits outcomes | Yes | Yes | Probably no | Follow up was 2 years
Miller, 2008^308^ | NA-no benefits outcomes | Yes | Yes | Probably no | NR
Morii, 2003^309^ | NA-no benefits outcomes | Yes | Yes | Probably no | NR
Murphy, 2001^272^ | Yes | Yes | Yes | No | NR
Nakamura, 2012^239^ | Yes | Yes | Probably yes | No | NR
Orwoll, 2003^240^ | Yes | Yes | Probably no | Probably no | NR
Pazianas, 2008^298^ | NA-no benefits outcomes | Yes | Probably yes | Probably no | NR
Ravn, 1996^286^ | NA-no benefits outcomes | Yes | Yes | No | NR
Reginster, 2005^287^ | NA-no benefits outcomes | Yes | Yes | No | NR
Rhee, 2012^344^ | NA-no benefits outcomes | Yes | Yes | No | NR
Riis, 2001^288^ | NA-no benefits outcomes | Yes | Yes | No | NR
Samelson, 2014^345^ | NA-no benefits outcomes | Yes | Yes | Probably yes | Post hoc analysis and the approach to reporting cardiovascular events in this analysis is different from reporting in the main FREEDOM trial where cardiovascular events were adjudicated by a panel.
Shiraki, 2003^283^ | NA-no benefits outcomes | Yes | Yes | Probably yes | NR
Simon, 2013^346^ | Probably Yes | NA-no harms outcomes | NA-no harms outcomes | Probably no | NR
Sontag, 2010^242^ | Yes | Yes | Yes | Probably no | NR
Sorensen, 2008^247^ | NA-no benefits outcomes | Yes | Probably yes | Probably no | Case control - harms only identified in the case group
Tanko, 2003^289^ | NA-no benefits outcomes | Yes | Yes | No | NR
Thiebaud, 1997^290^ | NA-no benefits outcomes | Yes | Yes | No | NR
Tucci, 1996^253^ | Yes | Yes | Yes | No | Of note, there are some data on reduction of vertebral fractures, but investigators have planned another arm with future reporting. This study not powered for fracture reduction.
Van Staa, 1997^347^ | NA-no benefits outcomes | Yes | Yes | No | NR
Vestergaard, 2010^348^ | NA-no benefits outcomes | Yes | Probably yes | Probably no | NR
Vestergaard, 2011^349^ | NA-no benefits outcomes | Yes | Probably yes | Probably no | NR
Vestergaard, 2012^350^ | NA-no benefits outcomes | Yes | Probably yes | Probably yes | NR
Vestergaard, 2011^351^ | Probably Yes | Probably no | Yes | Probably yes | NR
Vestergaard, 2012^352^ | NA-no benefits outcomes | Yes | Probably yes | Probably yes | NR

Abbreviations: FREEDOM=Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months; KQ=key question; NA=not applicable; NR=not reported.

Table 57 KQ 4 and 5 Risk of Bias Assessment: Part 10

First Author, Year | FOR RCTS AND COHORTS: Is the Reported Effect Estimate Unlikely To Be Selected, on the Basis of the Results, from Multiple Outcomes Measurements within the Domain, Multiple Analyses, or Different Subgroups? | FOR CASE-CONTROL STUDIES: Is the Reported Effect Estimate Unlikely To Be Selected, on the Basis of the Results, from Multiple Definitions of the Intervention? | Bias Arising from Selection of Reported Results? | Comments
Abrahamsen, 2010^273^ | Probably yes | NA-not a case-control | Probably no | NR
Adachi, 2009^250^ | Yes | NA-not a case-control | No | NR
Barrett-Connor, 2002^311^ | No | NA-not a case-control | No | NR
Barrett-Connor, 2004^310^ | No | NA-not a case-control | No | NR
Bone, 2000^216^ | Yes | NA-not a case-control | No | NR
Bone, 2008^237^ | Probably no | NA-not a case-control | Probably no | NR
Boonen, 2012^218^ | Yes | NA-not a case-control | Probably no | NR
Cartsos, 2008 ^297^ | NA-not an RCT | Probably yes | Probably no | None
Chapurlat, 2013^284^ | No | NA-not a case-control | No | NR
Cryer, 2005^252^ | Yes | NA-not a case-control | No | NR
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | Yes | NA-not a case-control | No | NR
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | Probably no | NA-not a c6ase-control | Probably no | NR
Eisman, 2004^255^ | Yes | NA-not a case-control | No | NR
Fogelman, 2000^226^ | Yes | NA-not a case-control | No | NR
Greenspan, 2002^254^ | Yes | NA-not a case-control | No | NR
Greenspan, 2003^249^ | Yes | NA-not a case-control | No | NR
Grey, 2010^274^ | Yes | NA-not a case-control | No | NR
Hosking, 2003^202^ | Yes | NA-not a case-control | No | NR
Hosking, 2003^202^ | Yes | NA-not a case-control | No | NR
Johnell, 2002^246^ | Probably yes | NA-not a case-control | Probably no | NR
Keech, 2005^312^ | No | NA-not a case-control | No | NR
Kung, 2000^343^ | Yes | NA-not a case-control | No | NR
Lasco, 2011^241^ | Probably no | NA-not a case-control | Probably no | NR
Lewiecki, 2007^236^ | Probably no | NA-not a case-control | Probably no | NR
McCloskey, 2012^245^ | No | NA-not a case-control | Probably no | NR
McClung, 2004^285^ | No | No | No | NR
McClung, 2006^306^ | No | NA-not a case-control | No | NR
McClung, 2006^209^ | Yes | NA-not a case-control | No | Study was powered for primary outcome of urinary markers, not harms. Report nominal p values for harms
McClung, 2009^275^ | probably yes | NA-not a case-control | Probably no | NR
Meunier, 1999^307^ | Yes | NA-not a case-control | Probably no | NR
Miller, 2008^308^ | Probably no | NA-not a case-control | Probably no | NR
Morii, 2003^309^ | Yes | NA-not a case-control | Probably no | NR
Murphy, 2001^272^ | Yes | NA-not a case-control | No | NR
Nakamura, 2012^239^ | No | NA-not a case-control | No | NR
Orwoll, 2003^240^ | Probably yes | NA-not a case-control | Probably no | NR
Pazianas, 2008 ^298^ | NA-not an RCT | Probably yes | Probably no | NR
Ravn, 1996^286^ | No | No | No | NR
Reginster, 2005^287^ | No | No | No | NR
Rhee, 2012^344^ | No | NA-not a case-control | No | NR
Riis, 2001^288^ | No | No | No | NR
Samelson, 2014^345^ | Probably yes | NA-not a case-control | No | It is not clear how the cardiovascular adverse events reported in this study relate to the harms provided in the main FREEDOM trial. This appears to be a post-hoc analysis.
Shiraki, 2003^283^ | Yes | NA-not a case-control | No | NR
Simon, 2013^346^ | Probably yes | NA-not a case-control | Probably no | NR
Sontag, 2010^242^ | Probably no | NA-not a case-control | Probably no | NR
Sorensen, 2008^247^ | NA-not an RCT | Yes | No | NR
Tanko, 2003^289^ | No | No | No | NR
Thiebaud, 1997^290^ | No | No | No | NR
Tucci, 1996^253^ | Yes | NA-not a case-control | No | Stepwise Tukey trend test to adjust for multiple comparisons
Van Staa, 1997^347^ | Yes | NA-not a case-control | No | Intervention status defined as patients who had received a prescription; adherence not measured; attrition and how missing data was handled was not reported
Vestergaard, 2010^348^ | Probably no | NA-not a case-control | Probably no | NR
Vestergaard, 2011^349^ | Probably no | NA-not a case-control | Probably no | NR
Vestergaard, 2012^350^ | Probably no | NA-not a case-control | Probably no | NR
Vestergaard, 2011^351^ | Probably no | NA-not a case-control | Probably no | NR
Vestergaard, 2012^352^ | Probably no | NA-not a case-control | Probably no | NR

Abbreviations: FREEDOM=Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months; KQ=key question; NA=not applicable; NR=not reported; RCT=randomized controlled trials.

Table 58 KQ 4 and 5 Risk of Bias Assessment: Part 11

First Author, Year | Rating Overall | Rating Justification | Does Quality Rating of Study Vary by Outcome?
Abrahamsen, 2010^273^ | Poor | Risk of bias from residual confounding and measurement of outcomes | No
Adachi, 2009^250^ | Fair | Baseline differences between groups raise some concerns for risk of bias. | No
Barrett-Connor, 2002^311^ | Fair | About 25% lost to follow-up. Also year 4 data allows additional therapy for osteoporosis which was different per group though small number (<7%) - this study included year 4 partcipants but didn’t report concomittant medicationss. Additionally, there was differential loss to follow-up due to excessive bone loss in the placebo group (3% vs 1%). | No
Barrett-Connor, 2004^310^ | Fair | About 25% lost to follow-up. Also year 4 data allows additional therapy for osteoporosis which was different per group though small number (<7%) - this study included year 4 partcipants but didn’t report concomittant meds. (No sensitivity analysis looking at 3 years of data where no additional meds.) Additionally, there was differential loss to follow-up due to excessive bone loss in the placebo group (3% vs 1%). | No
Bone, 2000^216^ | Poor | High attrition and no information about how harms were specified or assessed. | No
Bone, 2008^237^ | Fair | Some uncertainties in reporting of randomization, allocation concealment, blinding | no
Boonen, 2012^218^ | Good | NR | No
Cartsos, 2008 ^297^ | Poor | not clear how outcomes were measured. fidelity, not sure if participants took medication correctly; no information on cross-overs but not clear if other treatments were allowed No mention of how missing data was handled sample not representative of total population intervention based on dispensing information from claims data, information on dose not available | No
Chapurlat, 2013^284^ | Fair | Considering IVR with minimization scheme to be just adequate and unclear way drop outs handled. | No
Cryer, 2005^252^ | Good | fair for differential attrition, no information on contamination | No
Cummings, 1998^200^ Quandt, 2005^205^ Bauer, 2000^251^ | Good | NR | No
Cummings, 2009^238^; Watts, 2012^314^; McClung, 2012^243^; Boonen, 2011^244^ | Fair | Some uncertainties in reporting of randomization, allocation concealment, blinding | no
Eisman, 2004^255^ | Good | NR | No
Fogelman, 2000^226^ | Fair | NR | No
Greenspan, 2002^254^ | Fair | missing info on randomization. Also no washout period for patients previously on bisphosphonates. | No
Greenspan, 2003^249^ | Good | NR | No
Grey, 2010^274^ | Fair | Differences in baseline fracture rates, minimal specification of harm outcomes. | No
Hosking, 2003^202^ | Fair | NR | No
Hosking, 2003^202^ | Fair | Fair or Poor depending on how rate Attirtion module | No
Johnell, 2002^246^ | Good | NR | No
Keech, 2005^312^ | Fair | About 25% lost to follow-up. Also year 4 data allows additional therapy for osteoporosis which was different per group though small number (<7%) - this study included year 4 partcipants but didn’t report concomittant medications. (No sensitivity analysis looking at 3 years of data where no additional meds.) Additionally, there was differential loss to follow-up due to excessive bone loss in the placebo group (3% vs 1%). | No
Kung, 2000^343^ | Poor | No information on randomization methods, fidelity, contamination, 20% attrition with not enough info to judge differential attrition, and poorly specified harms outcomes (very specirfic patient self-reported adverse experiences, with no indication as to seriousness of AE, whether the AE resulted in discontinuation, and further, the data offered is number of events, not number of women, making it difficult to know whether the risk is higher in one group, compared to the other. | No
Lasco, 2011^241^ | Poor | Potential for confounding | No
Lewiecki, 2007^236^ | Fair | Some uncertainties in reporting of randomization, allocation concealment, blinding | No
McCloskey, 2012^245^ | Fair | No detail on randomization and allocation concealment prevents this from being rated as Good. No fatal flaws | No
McClung, 2004^285^ | Fair | No information provided on method of randomization or concealment | No
McClung, 2006^306^ | Fair | Overall attrition high, not a lot of information provided on randomization process; Fidelity issue: no information on if participants actually took their assigned doses | No
McClung, 2006^209^ | Good | Good for denosumab. For alendronate Poor for lack of blinding. | No
McClung, 2009^275^ | Fair | Higher risk of bias for harms than benefits (ITT analysis understates harms) | No
Meunier, 1999^307^ | Good | Documentation on randomization missing, outcomes mostly self report | no
Miller, 2008^308^ | Fair | Not possible to say how missing cases were accounted for in the analysis. Study has a potential to underestimate harms by using N randomized in the denominator and N retained in the numerator. | No
Morii, 2003^309^ | Fair | NR | No
Murphy, 2001^272^ | Poor | Very poor attrition at 12 and 18 months, and unable to assess differential attrition, missing information on randomization | No
Nakamura, 2012^239^ | Fair | The article was lacking information on method of randomization and concealment; lack of information on those who discontiuned study | No
Orwoll, 2003^240^ | fair | Differential attrition; higher in treatment arm; used ITT to adjust for analysis | No
Pazianas, 2008 ^298^ | Poor | fidelity, not sure if participants took medication correctly; no information on cross-overs but not clear if other treatments were allowed No mention of how missing data was handled sample not representative of total population intervention based on dispensing information from claims data, information on dose etc. not available | No
Ravn, 1996^286^ | Fair | High attrition, however, safety appears to have been collected and reported on a larger subset of the population. No information provided on method of randomization or concealment. | No
Reginster, 2005^287^ | Fair | No information provided on method of randomization or concealment Information on compliance was not provided | No
Rhee, 2012^344^ | Poor | Potential bias arising from creation of an new user cohort and from restriction to those without switches | No
Riis, 2001^288^ | Fair | No information provided on method of randomization or concealment | No
Samelson, 2014^345^ | Poor | No detail on randomization and allocation concealment prevents the main trial from being rated as Good. Attrition/missing data and outcome measurement in this specific sub-study make this analysis high risk of bias, thus Poor Quality. | No
Shiraki, 2003^283^ | Fair | NR | No
Simon, 2013^346^ | Fair | In the end, the only outcome that is of interest are wrist fractures in subgroups based on baseline risk. | No
Sontag, 2010^242^ | Poor | The open label portion of the trial allowed patient choice, and as result, outcomes could be result of confounding because of prognostic variables | No
Sorensen, 2008^247^ | Good | NR | No
Tanko, 2003^289^ | Fair | No information provided on method of randomization or concealment not able to calculate group attrition | No
Thiebaud, 1997^290^ | Fair | No information provided on method of randomization or concealment Slight differences length of menopause Information on compliance was not provided Investigator was not blind for all arms | No
Tucci, 1996^253^ | Fair | Randomization methods, fidelity, contamination missing info. | No
Van Staa, 1997^347^ | Poor | NR | No
Vestergaard, 2010^348^ | Poor | Concerns include lack of adjustment for all potential confounders, particularly OTC NSAID use and smoking. Additionally, the study does not control for adherence. | no
Vestergaard, 2011^349^ | Poor | Concerns include lack of adjustment for all potential confounders. For example, smoking, hypertension, diabetes could explain the stroke, and it’s possible that these underlying conditions are highly associated with both the osteoporosis medications and the outcome. | No
Vestergaard, 2012^350^ | Poor | Concerns include lack of adjustment for all potential confounders. For example, smoking and hypertension could explain the stroke, and it’s possible that these underlying conditions are highly associated with both the osteoporosis medications and the outcome. | No
Vestergaard, 2011^351^ | Poor | Concerns include lack of adjustment for all potential confounders, particularly underlying disease that might also be related to the choice of medication for steoporosis and the outcome. Additionally the outcome did not distinguish between typical and typical fractures. | No
Vestergaard, 2012^352^ | Poor | Concerns include lack of adjustment for all potential confounders, particularly underlying causes of inflammatory jaw disease (e.g., autoimmune disorders) that might also be related to risk factors for osteoporosis. Additionally the outcome includes many varied conditions with different etiologies that might be unrelated to osteoporosis. | No

Abbreviations: AE=adverse event; ITT=intent to treat; IVR=interactive voice response; KQ=key question; NR=not reported; NSAIDS=nonsteroidal anti-inflammatory drugs; OTC=over the counter.