# Appendix C Reasons for Exclusion

X1: not published in English

X2: not original research

X3: wrong population

X4: wrong study design

X5: wrong geographic setting

X6: wrong clinical setting

X7: wrong or no intervention

X8: wrong or no comparator

X9: wrong or no outcome

X10: article retracted

X11: bone measurement after outcome

X12: exclude not commercially available

X13: not FDA approved

X14: not in externally validated cohort

X15: not in very high HDI country

X16: study superseded by new evidence

X17: only used for hand search

X18: full text article not accessible

X19: insufficient information for abstraction

X20: poor quality

1 Menostar: a low-dose estrogen patch for osteopo rosis. Obstet Gynecol. 2005 Feb;105(2):432-3. PMID: 15684177. Exclusion Code: X2.15684177
2 Bone health may get higher visibility with new approach to fracture risk assessment that considers multiple factors. Dis Manag Advis. 2007 Sep;13(9):104-5, 97. PMID: 17907656. Exclusion Code: X2.17907656
3 Discontinuing denosumab treatmentdoes not increase fracture risk. Bonekey Rep. 2013;2:269. doi: 10.1038/bonekey.2013.3. PMID: 24422041. Exclusion Code: X9.24422041
4 Abendroth K, Mohrke W. Number and incidence of hip fractures in Germany from 2000 to 2013: Is hip fracture prevention by osteoporosis therapy derivable from these epidemiologicaldata?. [German]. In Osteologie Exclusion Code: X18.
5 Abou-Raya S, Abou-Raya A, Khadrawi T. A randomized controlled trial of early initiation of osteoporosis assessment and management in the acute setting of the fracture clinic. In Ann Rheum Dis Exclusion Code: X9.
6 Abrahamsen B, Eiken P, Eastell R. Cumulative alendronate dose and the long-term absolute risk of subtrochanteric and diaphyseal femur fractures: a register-based national cohort analysis. J Clin Endocrinol Metab. 2010 Dec;95(12):5258-65. doi: 10.1210/jc.2010-1571. PMID: 20843943. Exclusion Code: X20.20843943
7 Abrahamsen B, Vestergaard P, Rud B, . Ten-year absolute risk of osteoporotic fractures according to BMDT score at menopause: the Danish Osteoporosis Prevention Study. J Bone Miner Res. 2006 May;21(5):796-800. doi: 10.1359/jbmr.020604. PMID: 16734396. Exclusion Code: X7.16734396
8 Adachi JD, Saag KG, Delmas PD, . Two-year effects of alendronate on bone mineral density and vertebral fracture in patients receiving glucocorticoids: a randomized, double-blind, placebo-controlled extension trial. Arthritis Rheum. 2001 Jan;44(1):202-11. doi: 10.1002/1529-0131(200101)44:1<202::aid-anr27>3.0.co;2-w. PMID: 11212161. Exclusion Code: X3.11212161
9 Adami S, Bianchi G, Brandi ML, . Validation and further development of the WHO 10-year fracture risk assessment tool in Italian postmenopausal women: project rationale and description. Clin Exp Rheumatol. 2010 Jul-Aug;28(4):561-70. PMID: 20497630. Exclusion Code:X4.20497630
10 Adami S, Libanati C, Boonen S, . Denosumab treatment in postmenopausal women with osteoporosis does not interfere with fracture-healing: results from the FREEDOM trial. J Bone Joint Surg Am. 2012 Dec 5;94(23):2113-9. doi: 10.2106/JBJS.K.00774. PMID: 23097066. Exclusion Code: X9.23097066
11 Adomaityte J, Farooq M, Qayyum R. Effect of raloxifene therapy on venous thromboembolism in postmenopausal women. A meta-analysis. Thromb Haemost. 2008 Feb;99(2):338-42. PMID: 18278183. Exclusion Code: X3.18278183
12 Agrawal S, Krueger DC, Engelke JA, . Between-meal risedronate does not alter bone turnover in nursing home residents. J Am Geriatr Soc. 2006 May;54(5):790-5. doi: 10.1111/j.1532-5415.2006.00696.x. PMID: 16696745. Exclusion Code: X3.16696745
13 Ahmed LA, Schirmer H, Fonnebo V, . Validation of the Cummings’ risk score; how well does it identify women with high risk of hip fracture: the Tromso Study. Eur J Epidemiol. 2006;21(11):815-22. doi: 10.1007/s10654-006-9072-3. PMID: 17119878. Exclusion Code: X9.17119878
14 Ahmed LA, Shigdel R, Joakimsen RM, . Measurement of cortical porosity of the proximal femur improves identification of women with nonvertebral fragility fractures. Osteoporos Int. 2015 Aug;26(8):2137-46. doi: 10.1007/s00198-015-3118-x [doi]. PMID: 25876879. Exclusion Code: X7.25876879
15 Albaba M, Cha SS, Takahashi PY. The Elders Risk Assessment Index, an electronic administrative database-derived frailty index, can identify risk of hip fracture in a cohort of community-dwelling adults. Mayo Clin Proc. 2012 Jul;87(7):652-8. doi: 10.1016/j.mayocp.2012.01.020. PMID: 22766085. Exclusion Code: X14.22766085
16 Albanese CV, De Terlizzi F, Passariello R. Quantitative ultrasound of the phalanges and DXA of the lumbar spine and proximal femur in evaluating the risk of osteoporotic vertebral fracture in postmenopausal women. Radiol Med. 2011 Feb;116(1):92-101. doi: 10.1007/s11547-010-0577-1 [doi]. PMID: 20927655. Exclusion Code: X11.20927655
17 Albertsson DM, Mellstrom D, Petersson C, . Validation of a 4-item score predicting hip fracture and mortality risk among elderly women. Ann Fam Med. 2007 Jan-Feb;5(1):48-56. doi: 10.1370/afm.602. PMID: 17261864. Exclusion Code: X14.17261864
18 Allin S, Munce S, Schott AM, . Quality of fracture risk assessment in post-fracture care in Ontario, Canada. Osteoporos Int. 2013 Mar;24(3):899-905. doi: 10.1007/s00198-012-2111-x [doi]. PMID: 22930241. Exclusion Code: X3.22930241
19 Alman AC, Johnson LR, Calverley DC, . Diagnostic capabilities of fractal dimension and mandibular cortical width to identify men and women with decreased bone mineral density. Osteoporos Int. 2012 May;23(5):1631-6. doi: 10.1007/s00198-011-1678-y [doi]. PMID: 21633828. Exclusion Code: X12.21633828
20 Amstrup AK, Jakobsen NF, Lomholt S, . Inverse Correlation at the Hip Between Areal Bone Mineral Density Measured by Dual-Energy X-ray Absorptiometry and Cortical Volumetric Bone Mineral Density Measured by Quantitative Computed Tomography. J Clin Densitom. 2016 Apr-Jun;19(2):226-33. doi: 10.1016/j.jocd.2015.01.002. PMID: 25700661. Exclusion Code: X9.25700661
21 Anastasilakis AD, Polyzos SA, Makras P, . Circulating semaphorin-4D and plexin-B1 levels in postmenopausal women with low bone mass: the 3-month effect of zoledronic acid, denosumab or teriparatide treatment. Expert Opin Ther Targets. 2015 Mar;19(3):299-306. doi: 10.1517/14728222.2014.983078 [doi]. PMID: 25395071. Exclusion Code: X9.25395071
22 Anas tasilakis AD, Toulis KA, Goulis DG, . Efficacy and safety of denosumab in postmenopausal women with osteopenia or osteoporosis: a systematic review and a meta-analysis. Horm Metab Res. 2009 Oct;41(10):721-9. doi: 10.1055/s-0029-1224109. PMID: 19536731. Exclusion Code: X3.19536731
23 Anderson GL, Limacher M, Assaf AR, . Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women’s Health Initiative randomized controlled trial. JAMA. 2004 Apr 14;291(14):1701-12. doi: 10.1001/jama.291.14.1701. PMID: 15082697. Exclusion Code: X3.15082697
24 Ando H, Otoda T, Ookami H, . Dosing time-dependent effect of raloxifene on plasma plasminogen activator inhibitor-1 concentrations in post-menopausal women with osteoporosis. Clin Exp Pharmacol Physiol. 2013 Mar;40(3):227-32. doi: 10.1111/1440-1681.12055 [doi]. PMID: 23323567. Exclusion Code: X9.23323567
25 Ang CL, Singh G, Goh AS, . Densitometry trends in postmenopausal Asian women undergoing bisphosphonate treatment. Singapore Med J. 2011 Sep;52(9):677-80. PMID: 21947146. Exclusion Code: X9.21947146
26 Anpalahan M, Morrison SG, Gibson SJ. Hip fracture risk factors and the discriminability of hip fracture risk vary by age: a case-control study. Geriatr Gerontol Int. 2014 Apr;14(2):413-9. doi: 10.1111/ggi.12117 [doi]. PMID: 23879545. Exclusion Code:X14.23879545
27 Arabi A, Salamoun M, Ballout H, . Densitometer type and impact on risk assessment for osteoporosis. J Clin Densitom. 2005 Fall;8(3):261-6. PMID: 16055954. Exclusion Code: X7.16055954
28 Archer DF, Pinkerton JV, Utian WH, . Bazedoxifene, a selective estrogen receptor modulator: effects on the endometrium, ovaries, and breast from a randomized controlled trial in osteoporotic postmenopausal women. Menopause. 2009 Nov-Dec;16(6):1109-15. doi: 10.1097/gme.0b013e3181a818db [doi]. PMID: 19543129. Exclusion Code: X7.19543129
29 Asaoka D, Nagahara A, Hojo M, . Efficacy of alfacalcidol and alendronate on lumbar bone mineral density in osteoporotic patients using proton pump inhibitors. Biomedical Reports. 2016;5(2):165-70. Exclusion Code: X8.27446535
30 Aspenberg P, Genant HK, Johansson T, . Teriparatide for acceleration of fracture repair in humans: a prospective, randomized, double-blind study of 102 postmenopausal women with distal radial fractures. J Bone Miner Res. 2010 Feb;25(2):404-14. doi: 10.1359/jbmr.090731 [doi]. PMID: 19594305. Exclusion Code: X9.19594305
31 Aubry-Rozier B, Stoll D, Krieg MA, . What was your fracture risk evaluated by FRAX(R) the day before your osteoporotic fracture? Clin Rheumatol. 2013 Feb;32(2):219-23. doi: 10.1007/s10067-012-2106-1 [doi]. PMID: 23114631. Exclusion Code: X9.23114631
32 Austin M, Yang YC, Vittinghoff E, . Relations hip between bone mineral density changes with denosumab treatment and risk reduction for vertebral and nonvertebral fractures. J Bone Miner Res. 2012 Mar;27(3):687-93. doi: 10.1002/jbmr.1472 [doi]. PMID: 22095631. Exclusion Code: X9.22095631
33 Azagra R, Zwart M, Aguye A, . Fracture experience among participants from the FROCAT study: what thresholding is appropriate using the FRAX tool? Maturitas. 2016 Jan;83:65-71. doi: 10.1016/j.maturitas.2015.10.002. PMID: 26546077. Exclusion Code: X8.26546077
34 Bachmann G, Crosby U, Feldman RA, . Effects of bazedoxifene in nonflushing postmenopausal women: a randomized phase 2 trial. Menopause. 2011 May;18(5):508-14. doi: 10.1097/gme.0b013e3181fa358b [doi]. PMID: 21289525. Exclusion Code: X9.21289525
35 Badurski JE, Kanis JA, Johansson H, . The application of FRAX(R) to determine intervention thresholds in osteoporosis treatment in Poland. Pol Arch Med Wewn. 2011 May;121(5):148-55. PMID: 21610662. Exclusion Code: X9.21610662
36 Bai H, Jing D, Guo A, . Randomized controlled trial of zoledronic acid for treatment of osteoporosis in women. J Int Med Res. 2013 Jun;41(3):697-704. doi: 10.1177/0300060513480917. PMID: 23669294. Exclusion Code: X5.23669294
37 Bal UA, Atar İ, Öktem M, . The effect of raloxifene on left ventricular hypertrophy in postmenopausal women: A prospective, randomized, and controlled study. Anadolu Kardiyoloji Dergisi. 2015;15(6):480-4. Exclusion Code: X9.
38 Bala Y, Zebaze R, Ghasem-Zadeh A, . Cortical porosity identifies women with osteopenia at increased risk for forearm fractures. J Bone Miner Res. 2014 Jun;29(6):1356-62. doi: 10.1002/jbmr.2167 [doi]. PMID: 24519558. Exclusion Code: X7.24519558
39 Bandirali M, Di Leo G, Papini GD, . A new diagnostic score to detect osteoporosis in patients undergoing lumbar spine MRI. Eur Radiol. 2015 Oct;25(10):2951-9. doi: 10.1007/s00330-015-3699-y [doi]. PMID: 25899417. Exclusion Code: X7.25899417
40 Bandirali M, Poloni A, Sconfienza LM, . Short-termprecision assessment of trabecular bone score and bone mineral density using dual-energy X-ray absorptiometry with different scan modes: an in vivo study. Eur Radiol. 2015 Jul;25(7):2194-8. doi: 10.1007/s00330-015-3606-6 [doi]. PMID: 25663312. Exclusion Code: X7.25663312
41 Baniak N, Grzybowski S, Olszynski WP. Dual-energy x-ray absorptiometry scan autoanalysis vs manual analysis. J Clin Densitom. 2014 Jan-Mar;17(1):97-103. doi: 10.1016/j.jocd.2013.09.001. PMID: 24176429. Exclusion Code: X9.24176429
42 Barasch A, Cunha-Cruz J, Curro FA, . Risk factors for osteonecrosis of the jaws: A case-control study from the CONDOR dental PBRN. J Dent Res. 2011;90(4):439-44. Exclusion Code: X3.21317246
43 Baro F, Cano A, Sanchez Borrego R, . Frequency of FRAX risk factors in osteopenic postmenopausal women with and without history of fragility fracture. Menopause. 2012 Nov;19(11):1193-9. doi: 10.1097/gme.0b013e31825d65c5 [doi]. PMID: 22948137. Exclusion Code: X9.22948137
44 Barr RJ, Stewart A, Torgerson DJ, . Population screening for osteoporosis risk: a randomised control trial of medication use and fracture risk. Osteoporos Int. 2010 Apr;21(4):561-8. doi: 10.1007/s00198-009-1007-x [doi]. PMID: 19565176. Exclusion Code: X20.19565176
45 Barrera G, Bunout D, Gattas V, . A high body mass index protects against femoral neck osteoporosis in healthy elderly subjects. Nutrition. 2004 Sep;20(9):769-71. doi: 10.1016/j.nut.2004.05.014. PMID: 15325685. Exclusion Code: X7.15325685
46 Barrett-Connor E, Cox DA, Song J, . Raloxifene and risk for stroke based on the framingham stroke risk score. Am J Med. 2009 Aug;122(8):754-61. doi: 10.1016/j.amjmed.2009.01.033. PMID: 19540454. Exclusion Code: X4.19540454
47 Barrett-Connor E, Mosca L, Collins P, . Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med. 2006 Jul 13;355(2):125-37. doi: 10.1056/NEJMoa062462. PMID: 16837676. Exclusion Code: X3.16837676
48 Barrett-Connor E, Swern AS, Hustad CM, . Alendronate and atrial fibrillation: a meta-analysis of randomized placebo-controlled clinical trials. Osteoporos Int. 2012 Jan;23(1):233-45. doi: 10.1007/s00198-011-1546-9. PMID: 21369791. Exclusion Code: X6.21369791
49 Barrett-Connor E, Wehren LE, Siris ES, . Recency and duration of postmenopausal hormone therapy: effects on bone mineral density and fracture risk in the National Osteoporosis Risk Assessment (NORA) study. Menopause. 2003 Sep-Oct;10(5):412-9. doi: 10.1097/01.GME.0000086467.82759.DA [doi]. PMID: 14501602. Exclusion Code: X4.14501602
50 Bauer DC, Schwartz A, Palermo L, . Fracture prediction after discontinuation of 4 to 5 years of alendronate therapy: the FLEX study. JAMA Intern Med. 2014 Jul;174(7):1126-34. doi: 10.1001/jamainternmed.2014.1232. PMID: 24798675. Exclusion Code: X3.24798675
51 Baum T, Grande Garcia E, Burgkart R, . Osteoporosis imaging: effects of bone preservation on MDCT-based trabecular bone microstructure parameters and finite element models. BMC Med Imaging. 2015;15:22. doi: 10.1186/s12880-015-0066-z. PMID: 26113362. Exclusion Code: X3.26113362
52 Baum T, Muller D, Dobritz M, . BMD measurements of the spine derived from sagittal reformations of contrast-enhanced MDCT without dedicated software. Eur J Radiol. 2011 Nov;80(2):e140-5. doi: 10.1016/j.ejrad.2010.08.034. PMID: 20851544. Exclusion Code: X7.20851544
53 Baumgartner R, Heeren N, Quast D, . Is the cortical thickness index a valid parameter to assess bone mineral density in geriatric patients with hip fractures? Arch Orthop Trauma Surg. 2015 Jun;135(6):805-10. doi: 10.1007/s00402-015-2202-1 [doi]. PMID: 25801811. Exclusion Code: X3.25801811
54 Bazzocchi A, Ponti F, Diano D, . Trabecular bone score in healthy ageing. Br J Radiol. 2015 Aug;88(1052):20140865. doi: 10.1259/bjr.20140865 [doi]. PMID: 26148778. Exclusion Code: X9.26148778
55 Beck TJ, Fuerst T, Gaither KW, . The effects of bazedoxifene on bone structural strength evaluated by hip structure analysis. Bone. 2015 Aug;77:115-9. doi: 10.1016/j.bone.2015.04.027. PMID: 25917574. Exclusion Code: X9.25917574
56 Beck TJ, Lewiecki EM, Miller PD, . Effects of denosumab on the geometry of the proximal femur in postmenopausal women in comparison with alendronate. J Clin Densitom. 2008 Jul-Sep;11(3):351-9. doi: 10.1016/j.jocd.2008.04.001. PMID: 18495508. Exclusion Code: X9.18495508
57 Berry SD, Kiel DP, Donaldson MG, . Application of the National Osteoporosis Foundation Guidelines to postmenopausal women and men: the Framingham Osteoporosis Study. Osteoporos Int. 2010 Jan;21(1):53-60. doi: 10.1007/s00198-009-1127-3 [doi]. PMID: 19937426. Exclusion Code: X9.19937426
58 Bhandari M, Jin L, See K, . Does Teriparatide Improve Femoral Neck Fracture Healing: Results From A Randomized Placebo-controlled Trial. Clin Orthop Relat Res. 2016;474(5):1234-44. Exclusion Code: X3.26932738
59 Binkley N, Bolognese M, Sidorowicz-Bialynicka A, . A phase 3 trial of the efficacy and safety of oral recombinant calcitonin: the Oral Calcitonin in Postmenopausal Osteoporosis (ORACAL) trial. J Bone Miner Res. 2012 Aug;27(8):1821-9. doi: 10.1002/jbmr.1602 [doi]. PMID: 22437792. Exclusion Code: X7.22437792
60 Black DM, Bilezikian JP, Greenspan SL, . Improved adherence with PTH(1-84) in an extension trial for 24 months results in enhanced BMD gains in the treatment of postmenopausal women with osteoporosis. Osteoporos Int. 2013 Apr;24(4):1503-11. doi: 10.1007/s00198-012-2098-3 [doi]. PMID: 22930240. ExclusionCode: X8.22930240
61 Black DM, Cummings SR, Karpf DB, . Randomised trial of effect of alendronate on risk of fracture in women with existing vertebral fractures. Fracture Intervention Trial Research Group. Lancet. 1996 Dec 7;348(9041):1535-41. PMID: 8950879. Exclusion Code: X3.8950879
62 Black DM, Delmas PD, Eastell R, . Once-yearly zoledronic acid for treatment of postmen opausal osteoporosis. N Engl J Med. 2007 May 3;356(18):1809-22. doi: 10.1056/NEJMoa067312. PMID: 17476007. Exclusion Code: X3.17476007
63 Black DM, Kelly MP, Genant HK, . Bisphosphonates and fractures of the subtrochanteric or diaphyseal femur. N Engl J Med. 2010 May 13;362(19):1761-71. doi: 10.1056/NEJMoa1001086. PMID: 20335571. Exclusion Code: X3.20335571
64 Black DM, Reid IR, Cauley JA, . The effect of 6 versus 9 years of zoledronic acid treatment in osteoporosis: A randomized second extension to the HORIZON-pivotal fracture trial (PFT). In J Bone Miner Res Exclusion Code: X8.
65 Black DM, Steinbuch M, Palermo L, . An assessment tool for predicting fracture risk in postmenopausal women. Osteoporos Int. 2001;12(7):519-28. doi: 10.1007/s001980170072 [doi]. PMID: 11527048. Exclusion Code: X14.11527048
66 Blackburn TD, Howard DB, Leib ES. Utility of spine bone mineral density in fracture prediction within FRAX. J Clin Densitom. 2013 Jan-Mar;16(1):81-6. doi: 10.1016/j.jocd.2012.08.002. PMID: 23010380. Exclusion Code: X9.23010380
67 Blumsohn A, Marin F, Nickelsen T, . Early changes in biochemical markers of bone turnover and their relationship with bone mineral density changes after 24 months of treatment with teriparatide. Osteoporos Int. 2011 Jun;22(6):1935-46. doi: 10.1007/s00198-010-1379-y [doi]. PMID: 20938767. Exclusion Code: X8.20938767
68 Bodade PR, Mody RN. Panoramic radiography for screening postmenopausal osteoporosis in India: a pilot study. Oral Health Dent Manag. 2013 Jun;12(2):65-72. PMID: 23756421. Exclusion Code: X9.23756421
69 Boehm HF, Lutz J, Korner M, . Using Radon transform of standard radiographs of the hip to differentiate between post-menopausal women with and without fracture of the proximal femur. Osteoporos Int. 2009 Feb;20(2):323-33. doi: 10.1007/s00198-008-0663-6 [doi]. PMID: 18560746. Exclusion Code: X12.18560746
70 Boehm HF, Vogel T, Panteleon A, . Differentiation between post-menopausal women with and without hip fractures: enhanced evaluation of clinical DXA by topological analysis of the mineral distribution in the scan images. Osteoporos Int. 2007 Jun;18(6):779-87. doi: 10.1007/s00198-006-0302-z [doi]. PMID: 17235663. Exclusion Code: X12.17235663
71 Bonaccorsi G, Fila E, Cervellati C, . Assessment of Fracture Risk in A Population of Postmenopausal Italian Women: A Comparison of Two Different Tools. Calcif Tissue Int. 2015 Jul;97(1):50-7. doi: 10.1007/s00223-015-0009-2 [doi]. PMID: 25939647. Exclusion Code: X9.25939647
72 Bone HG, Bolognese MA, Yuen CK, . Effects of denosumab treatment and discontinuation on bone mineral density and bone turnover markers in postmenopausal women with low bone mass. J Clin Endocrinol Metab. 2011 Apr;96(4):972-80. doi: 10.1210/jc.2010-1502. PMID: 21289258. Exclusion Code: X4.21289258
73 Bone HG, Chapurlat R, Brandi ML, . The effect of three or six years of denosumab exposure in women with postmenopausal osteoporosis: results from the FREEDOM extension. J Clin Endocrinol Metab. 2013 Nov;98(11):4483-92. doi: 10.1210/jc.2013-1597. PMID: 23979955. Exclusion Code: X8.23979955
74 Bone HG, Dempster DW, Eisman JA, . Odanacatib for the treatment of postmenopausal osteoporosis: development history and design and participant characteristics of LOFT, the Long-Term Odanacatib Fracture Trial. In Osteoporosis international: a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA Exclusion Code: X7.
75 Bone HG, Greenspan SL, McKeever C, . Alendronate and estrogen effects in postmenopausal women with low bone mineral density. Alendronate/Estrogen Study Group. J Clin Endocrinol Metab. 2000 Feb;85(2):720-6. doi: 10.1210/jcem.85.2.6393. PMID: 10690882. Exclusion Code: X20.10690882
76 Bonnick SL, Beck TJ, Cosman F, . DXA-based hip structural analysis of once-weekly bisphosphonate-treated postmenopausal women with low bone mass. Osteoporos Int. 2009 Jun;20(6):911-21. doi: 10.1007/s00198-008-0762-4 [doi]. PMID: 18830555. Exclusion Code: X7.18830555
77 Bonnyman AM, Webber CE, Stratford PW, . Intrarater reliability of dual-energy X-ray absorptiometry-based measures of vertebral height in postmenopausal women. J Clin Densitom. 2012 Oct-Dec;15(4):405-12. doi: 10.1016/j.jocd.2012.03.005. PMID: 22578772. Exclusion Code: X9.22578772
78 Boonen S, Klemes AB, Zhou X, . Assessment of the relationship between age and the effect of risedronate treatment in women with postmenopausal osteoporosis: a pooled analysis of four studies. J Am Geriatr Soc. 2010 Apr;58(4):658-63. doi: 10.1111/j.1532-5415.2010.02763.x. PMID: 20345865. Exclusion Code: X3.20345865
79 Boonen S, Orwoll E, Magaziner J, . Once-yearly zoledronic acid in older men compared with women with recent hip fracture. J Am Geriatr Soc. 2011 Nov;59(11):2084-90. doi: 10.1111/j.1532-5415.2011.03666.x [doi]. PMID: 22091563. Exclusion Code: X4.22091563
80 Boonen S, Orwoll ES, Wenderoth D, . Once-weekly risedronate in men with osteoporosis: results of a 2-year, placebo-controlled, double-blind, multicenter study. J Bone Miner Res. 2009 Apr;24(4):719-25. doi: 10.1359/jbmr.081214. PMID: 19049326. Exclusion Code: X3.19049326
81 Borah B, Dufresne T, Nurre J, . Risedronate reduces intracortical porosity in women with osteoporosis. J Bone Miner Res. 2010 Jan;25(1):41-7. doi: 10.1359/jbmr.090711 [doi]. PMID: 19580469. Exclusion Code: X9.19580469
82 Borissova A M, Rashkov R, Boyanov M, . Femoral neck bone mineral density and 10-year absolute fracture risk in a national representative sample of Bulgarian women aged 50 years and older. Arch Osteoporos. 2011;6:189-95. doi: 10.1007/s11657-011-0064-x [doi]. Exclusion Code: X9.22886105
83 Boutroy S, Hans D, Sornay-Rendu E, . Trabecular bone score improves fracture risk prediction in non-osteoporotic women: the OFELY study. Osteoporos Int. 2013 Jan;24(1):77-85. doi: 10.1007/s00198-012-2188-2 [doi]. PMID: 23070481. Exclusion Code: X9.23070481
84 Bouxsein ML, Chen P, Glass EV, . Teriparatide and raloxifene reduce the risk of new adjacent vertebral fractures in postmenopausal women with osteoporosis. Results from two randomized controlled trials. J Bone Joint Surg Am. 2009 Jun;91(6):1329-38. doi: 10.2106/JBJS.H.01030. PMID: 19487509. Exclusion Code: X4.19487509
85 Boytsov N, Zhang X, Sugihara T, . Osteoporotic fractures and associated hospitalizations among patients treated with teriparatide compared to a matched cohort of patients not treated with teriparatide. Curr Med Res Opin. 2015;31(9):1665-75. doi: 10.1185/03007995.2015.1066765 [doi]. PMID: 26121328. Exclusion Code: X3.26121328
86 Brennan SL, Leslie WD, Lix LM, . FRAX provides robust fracture prediction regardless of socioeconomic status. Osteoporos Int. 2014 Jan;25(1):61-9. doi: 10.1007/s00198-013-2525-0 [doi]. PMID: 24190425. Exclusion Code: X8.24190425
87 Brewer L, Mellon L, Duggan J. Ability of fracture risk assessment tool and national osteoporosis guideline group guidance to stratify people appropriately before fracture. J Am Geriatr Soc. 2013 Sep;61(9):1633-4. doi: 10.1111/jgs.12435 [doi]. PMID: 24028368. Exclusion Code: X9.24028368
88 Bridges MJ, Ruddick S. Ability of FRAX/NOGG guidelines to identify patients sustaining low trauma fractures. Rheumatology (Oxford). 2010 Feb;49(2):391-2. doi: 10.1093/rheumatology/kep353.PMID: 19900999. Exclusion Code: X9.19900999
89 Bridges MJ, Ruddick SA. Do FRAX/NOGG guidelines predict fractures in post-menopausal women with Type 2 diabetes? Diabet Med. 2012 Apr;29(4):555-6. doi: 10.1111/j.1464-5491.2011.03470.x [doi]. PMID: 21978325. Exclusion Code: X9.21978325
90 Brown JP, Roux C, Torring O, . Discontinuation of denosumab and associated fracture incidence: analysis from the Fracture Reduction Evaluation of Denosumab in Osteoporosis Every 6 Months (FREEDOM) trial. J Bone Miner Res. 2013 Apr;28(4):746-52. doi: 10.1002/jbmr.1808 [doi]. PMID: 23109251. Exclusion Code: X9.23109251
91 Bruyere O, Fossi M, Zegels B, . Comparison of the proportion of patients potentially treated with an anti-osteoporotic drug using the current criteria of the Belgian national social security and the new suggested FRAX(registered trademark) criteria. Rheumatol Int. 2013;33(4):973-8. Exclusion Code: X9.22842952
92 Buckens CF, Dijkhuis G, de Keizer B, . Opportunistic screening for osteoporosis on routine computed tomography? An external validation study. Eur Radiol. 2015 Jul;25(7):2074-9. doi: 10.1007/s00330-014-3584-0 [doi]. PMID: 25591750. Exclusion Code: X7.25591750
93 Buist DS, LaCroix AZ, Manfredonia D, . Identifying postmenopausal women at high risk of fracture in populations: a comparison of three strategies. J Am Geriatr Soc. 2002 Jun;50(6):1031-8. PMID: 12110062. Exclusion Code: X9.12110062
94 Bumbasirevic M, Lesic A, Denic-Markovic L, . Prospective clinical study of once monthly ibandronate in the treatment of osteoporosis and prevention of fractures in postmenopausal women: ORPHEUM Study. Srp Arh Celok Lek. 2011;139(11-12):790-4. Exclusion Code: X5.22338477
95 Bunnell N. Osteoporosis. J Ky Med Assoc. 2005 Nov;103(11):567-8. PMID: 16302725. Exclusion Code: X2.16302725
96 Bunout D, Barrera G, de la Maza MP, . Height reduction, determined using knee height measurement as a risk factor or predictive sign for osteoporosis in elderly women. Nutrition. 2007 Nov-Dec;23(11-12):794-7. doi: 10.1016/j.nut.2007.08.012. PMID: 17936193. Exclusion Code: X7.17936193
97 Burger H, de Laet CE, Weel AE, . Added value of bone mineral density in hip fracture risk scores. Bone. 1999 Sep;25(3):369-74. PMID: 10495142. Exclusion Code: X14.10495142
98 Cadarette SM, Jaglal SB, Kreiger N, . Development and validation of the Osteoporosis Risk Assessment Instrument to facilitate selection of women for bone densitometry. CMAJ. 2000 May 2;162(9):1289-94. PMID: 10813010. Exclusion Code: X14.10813010
99 Cadarette SM, Jaglal SB, Murray TM. Validation of the simple calculated osteoporosis risk estimation (SCORE) for patient selection for bone densitometry. Osteoporos Int. 1999;10(1):85-90. doi: 10.1007/s001980050199. PMID: 10501785. Exclusion Code: X9.10501785
100 Cartsos VM, Zhu S, Zavras AI. Bisphosphonate use and the risk of adverse jaw outcomes: a medical claims study of 714,217 people. J Am Dent Assoc. 2008 Jan;139(1):23-30. PMID: 18167381. Exclusion Code: X20.18167381
101 Catalano A, Morabito N, Basile G, . Fracture risk assessmentin postmenopausal women referred to an italian center for osteoporosis: A single day experience in messina. Clinical Cases in Mineral and Bone Metabolism. 2013;10(3):191-4. Exclusion Code: X9.24554930
102 Cauley JA, LaCroix AZ, Robbins JA, . Baseline serumestradiol and fracture reduction during treatment with hormone therapy: the Women’s Health Initiative randomized trial. Osteoporos Int. 2010 Jan;21(1):167-77. doi: 10.1007/s00198-009-0953-7 [doi]. PMID: 19436934. Exclusion Code: X9.19436934
103 Chai J, Chau AC, Chu FC, . Diagnostic performance of mandibular bone density measurements in assessing osteoporotic status. Int J Oral Maxillofac Implants. 2014 May-Jun;29(3):667-74. PMID: 24818206. Exclusion Code: X7.24818206
104 Chailurkit LO, Jongjaroenprasert W, Rungbunnapun S, . Effect of alendronate on bone mineral density and bone turnover in Thai postmenopausal osteoporosis. J Bone Miner Metab. 2003;21(6):421-7. doi: 10.1007/s00774-003-0438-2. PMID: 14586800. Exclusion Code: X5.14586800
105 Chao AS, Chen FP, Lin YC. Application of the who fracture risk assessment tool to predict need for DXA scanning in postmenopausal women. In Osteoporos Int Exclusion Code: X9.
106 Chao AS, Chen FP, Lin YC, . Application of the World Health Organization Fracture Risk Assessment Toolto predict need for dual-energy X-ray absorptiometry scanning in postmenopausal women. Taiwan J Obstet Gynecol. 2015 Dec;54(6):722-5. doi: 10.1016/j.tjog.2015.10.005. PMID: 26700992. Exclusion Code: X9.26700992
107 Chao M, Hua Q, Yingfeng Z, . Study on the role of zoledronic acid in treatment of postmenopausal osteoporosis women. Pak J Med Sci. 2013 Nov;29(6):1381-4. PMID: 24550958. Exclusion Code: X5.24550958
108 Chapman I, Greville H, Ebeling PR, . Intravenous zoledronate improves bone density in adults with cystic fibrosis (CF). Clin Endocrinol (Oxf). 2009 Jun;70(6):838-46. doi: 10.1111/j.1365-2265.2008.03434.x. PMID: 18823395. Exclusion Code: X3.18823395
109 Chau D, Becker DL, Coombes ME, . Cost-effectiveness of denosumab in the treatment of postmenopausal osteoporosis in Canada. J Med Econ. 2012;15 Suppl 1:3-14. doi: 10.3111/13696998.2012.737393 [doi]. PMID: 23035625. Exclusion Code: X9.23035625
110 Chen CK, Chang HT, Chou HP, . Alendronate and risk of lower limb ischemic vascular events: a population-based cohort study. Osteoporos Int. 2014 Feb;25(2):673-80. doi: 10.1007/s00198-013-2478-3 [doi]. PMID: 23943167. Exclusion Code: X5.23943167
111 Chen F, Osterman AL, Mahony K. Smoking and bony union after ulna-shortening osteotomy. AmJ Orthop (Belle Mead NJ). 2001 Jun;30(6):486-9. PMID: 11411875. Exclusion Code: X9.11411875
112 Chen F, Wang Z, Bhattacharyya T. Absence of femoral cortical thickening in long-term bisphosphonate users: implications for atypical femur fractures. Bone. 2014 May;62:64-6. doi: 10.1016/j.bone.2014.01.011. PMID: 24468718. Exclusion Code: X9.24468718
113 Chen JS, Simpson JM, Blyth FM, . Managing osteoporosis with FRAX(R) in Australia: proposed new treatment thresholds from the 45&Up Study cohort. Bone. 2014 Dec;69:148-53. doi: 10.1016/j.bone.2014.09.015. PMID: 25263521. Exclusion Code: X9.25263521
114 Chen JS, Simpson JM, March LM, . Fracture risk assessment in frail older people using clinical risk factors. Age Ageing. 2008 Sep;37(5):536-41. doi: 10.1093/ageing/afn128. PMID: 18541611. Exclusion Code: X6.18541611
115 Chen P, Miller PD, Binkley NC, . Use of lowest single lumbar spine vertebra bone mineral density T-score and other T-score approaches for diagnosing osteoporosis and relationships with vertebral fracture status. J Clin Densitom. 2008 Oct-Dec;11(4):525-31. doi: 10.1016/j.jocd.2008.04.009. PMID: 18599331. Exclusion Code: X3.18599331
116 Chen SJ, Lin CS, Lin CL, . Osteoporosis Is Associated With High Risk for Coronary Heart Disease: A Population-Based Cohort Study. Medicine (Baltimore). 2015 Jul;94(27):e1146. doi: 10.1097/MD.0000000000001146. PMID: 26166125. Exclusion Code: X7.26166125
117 Chen Y, Harrold LR, Yood RA, . Identifying patients with osteoporosis or at risk for osteoporotic fractures. AmJ Manag Care. 2012 Feb;18(2):e61-7. PMID: 22435886. Exclusion Code: X14.22435886
118 Chen YC, Su FM, Cheng TT, . Is Long-Term Anti-Osteoporotic Treatment Associated with Greater Risk of Cancer in People with Severe Vertebral Fractures? A Hospital-Based Cohort Study. J Am Geriatr Soc. 2015 Nov;63(11):2418-9. doi: 10.1111/jgs.13798 [doi]. PMID: 26603069. Exclusion Code: X7.26603069
119 Chesnut CH 3rd, Skag A, Christiansen C, . Effects of oral ibandronate administered daily or intermittently on fracture risk in postmenopausal osteoporosis. J Bone Miner Res. 2004 Aug;19(8):1241-9. doi: 10.1359/jbmr.040325. PMID: 15231010. Exclusion Code: X3.15231010
120 Cheung E, Cheung CL, Kung AWC, . Possible FRAX-based intervention thresholds for a cohort of Chinese postmenopausal women. Osteoporos Int. 2014;25(3):1017-23. Exclusion Code: X7.24196720
121 Chin KY, Ima-Nirwana S, Isa Naina M, . Calcaneal quantitative ultrasound value for middle-aged and elderly Malaysian Chinese men and its association with age and body anthropometry. J Clin Densitom. 2012 Jan-Mar;15(1):86-91. doi: 10.1016/j.jocd.2011.09.004. PMID: 22169197. Exclusion Code: X9.22169197
122 Chiu WY, Chien JY, Yang WS, . The risk of osteonecrosis of the jaws in Taiwanese osteoporotic patients treated with oral alendronate or raloxifene. J Clin Endocrinol Metab. 2014 Aug;99(8):2729-35. doi: 10.1210/jc.2013-4119 [doi]. PMID: 24758181. Exclusion Code: X5.24758181
123 Choi D, Kim DY, Han CS, . Measurements of bone mineral density in the lumbar spine and proximal femur using lunar prodigy and the new pencil-beam dual-energy X-ray absorptiometry. Skeletal Radiol. 2010 Nov;39(11):1109-16. doi: 10.1007/s00256-009-0828-1 [doi]. PMID: 19924413. Exclusion Code: X9.19924413
124 Choi YJ, Yang SO, Shin CS, . The importance of morphometric radiographic vertebral assessment for the detection of patients who need pharmacological treatment of osteoporosis among postmenopausal diabetic Korean women. Osteoporos Int. 2012 Aug;23(8):2099-105. doi: 10.1007/s00198-011-1803-y [doi]. PMID: 21975560. Exclusion Code: X9.21975560
125 Chou SH, Vokes TJ, Ma SL, . Simplified criteria for selecting patients for vertebral fracture assessment. J Clin Densitom. 2014 Jul-Sep;17(3):386-91. doi: 10.1016/j.jocd.2013.11.003. PMID: 24582084. Exclusion Code: X14.24582084
126 Chow CC, Chan WB, Li JK, . Oral alendronate increases bone mineral density in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab. 2003 Feb;88(2):581-7. doi: 10.1210/jc.2002-020890. PMID: 12574184. Exclusion Code: X3.12574184
127 Christiansen C, Chesnut CH 3rd, Adachi JD, . Safety of bazedoxifene in a randomized, double-blind, placebo- and active-controlled Phase 3 study of postmenopausal women with osteoporosis. BMC Musculoskelet Disord. 2010;11:130. doi: 10.1186/1471-2474-11-130. PMID: 20569451. Exclusion Code: X3.20569451
128 Chung HY, Chin SO, Kang MI, . Efficacy of risedronate with cholecalciferol on 25-hydroxy vitamin D level and bone turnover in Korean patients with osteoporosis. Clin Endocrinol (Oxf). 2011 Jun;74(6):699-704. doi: 10.1111/j.1365-2265.2011.04041.x [doi]. PMID: 21521310. Exclusion Code: X8.21521310
129 Chung HY, Park HM. Effects of weekly risedronate with cholecalciferolon 25-hydroxyvitamin D level and bone mineral density in Korean patients with osteoporosis. In Osteoporos Int Exclusion Code: X8.
130 Chung YE, Lee SH, Lee SY, . Long-term treatment with raloxifene, but not bisphosphonates, reduces circulating sclerostin levels in postmenopausal women. Osteoporos Int. 2012 Apr;23(4):1235-43. doi: 10.1007/s00198-011-1675-1 [doi]. PMID: 21660558. Exclusion Code: X9.21660558
131 Clark E, Morrison L, Cuming M, . A screening programme for identification of vertebral fractures increases bisphosphonate prescribing and reduces fractures: Results of a large RCT. In J Bone Miner Res Exclusion Code: X18.
132 Clark EM, Gould V, Morrison L, . Randomized controlled trial of a primary care-based screening program to identify older women with prevalent osteoporotic vertebral fractures: Cohort for Skeletal Health in Bristol and Avon (COSHIBA). J Bone Miner Res. 2012 Mar;27(3):664-71. doi: 10.1002/jbmr.1478 [doi]. PMID: 22113935. Exclusion Code: X9.22113935
133 Clemmesen B, Ravn P, Zegels B, . A 2-year phase II study with 1-year of follow-up of risedronate (NE-58095) in postmenopausal osteoporosis. Osteoporos Int. 1997;7(5):488-95. PMID: 9425508. Exclusion Code: X3.9425508
134 Cohen S, Levy RM, Keller M, . Risedronate therapy prevents corticosteroid-induced bone loss: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, parallel-group study. Arthritis Rheum. 1999 Nov;42(11):2309-18. doi: 10.1002/1529-0131(199911)42:11<2309::aid-anr8>3.0.co;2-k. PMID: 10555025. Exclusion Code: X3.10555025
135 Cohen SB, Dore RK, Lane NE, . Denosumab treatment effects on structural damage, bone mineral density, and bone turnover in rheumatoid arthritis: a twelve-month, multicenter, randomized, double-blind, placebo-controlled, phase II clinical trial. Arthritis Rheum. 2008 May;58(5):1299-309. doi: 10.1002/art.23417 [doi]. PMID: 18438830. Exclusion Code: X3.18438830
136 Colon-Emeric C, Kuchibhatla M, Pieper C, . The contribution of hip fracture to risk of subsequent fractures: data from two longitudinal studies. Osteoporos Int. 2003 Nov;14(11):879-83. doi: 10.1007/s00198-003-1460-x [doi]. PMID: 14530910. Exclusion Code: X3.14530910
137 Colon-Emeric C, Nordsletten L, Olson S, . Association between timing of zoledronic acid infusion and hip fracture healing. Osteoporos Int. 2011 Aug;22(8):2329-36. doi: 10.1007/s00198-010-1473-1. PMID: 21153021. Exclusion Code: X3.21153021
138 Colon-Emeric CS, Pieper CF, Artz MB. Can historical and functional risk factors be used to predict fractures in community-dwelling older adults? development and validation of a clinical tool. Osteoporos Int. 2002 Dec;13(12):955-61. doi: 10.1007/s001980200133 [doi]. PMID: 12459938. Exclusion Code: X9.12459938
139 Compston J. Assessment of fracture risk key in osteoporosis. Practitioner. 2008 Dec;252(1713):15-6, 9. PMID: 19192698. Exclusion Code: X2.19192698
140 Cosman F, Cauley JA, Eastell R, . Reassessment of fracture risk in women after 3 years of treatment with zoledronic acid: when is it reasonable to discontinue treatment?. J Clin Endocrinol Metab. 2014 Dec;99(12):4546-54. doi: 10.1210/jc.2014-1971 [doi]. PMID: 25215556. Exclusion Code: X3.25215556
141 Cosman F, Crittenden DB, Adachi JD, . Romosozumab Treatment in Postmenopausal Women with Osteoporosis. N Engl J Med. 2016 Sep 18. doi: 10.1056/NEJMoa1607948. PMID: 27641143. Exclusion Code: X7.27641143
142 Cosman F, Gilchrist N, McClung M, . A phase 2 study of MK-5442, a calcium-sensing receptor antagonist, in postmenopausal women with osteoporosis after long-termuse of oral bisphosphonates. In Osteoporos Int Exclusion Code: X3.
143 Cosman F, Keaveny TM, Kopperdahl D, . Hip and spine strength effects of adding versus switching to teriparatide in postmenopausal women with osteoporosis treated with prior alendronate or raloxifene. J Bone Miner Res. 2013 Jun;28(6):1328-36. doi: 10.1002/jbmr.1853 [doi]. PMID: 23281041. Exclusion Code: X8.23281041
144 Cosman F, Lane NE, Bolognese MA, . Effect of transdermal teriparatide administration on bone mineral density in postmenopausal women. J Clin Endocrinol Metab. 2010 Jan;95(1):151-8. doi: 10.1210/jc.2009-0358. PMID: 19858319. Exclusion Code: X5.19858319
145 Cosman F, Nieves JW, Zion M, . Daily or Cyclical Teriparatide Treatment in Women With Osteoporosis on no Prior Therapy and Women on Alendronate. J Clin Endocrinol Metab. 2015 Jul;100(7):2769-76. doi: 10.1210/jc.2015-1715 [doi]. PMID: 25961136. Exclusion Code: X8.25961136
146 Couris CM, Chapurlat RD, Kanis JA, . FRAX(R) probabilities and risk of major osteoporotic fracture in France. Osteoporos Int. 2012 Sep;23(9):2321-7. doi: 10.1007/s00198-011-1883-8 [doi]. PMID: 22179418. Exclusion Code: X9.22179418
147 Crabtree NJ, Kroger H, Martin A, . Improving risk assessment: hip geometry, bone mineral distribution and bone strength in hip fracture cases and controls. The EPOS study. European Prospective Osteoporosis Study. Osteoporos Int. 2002 Jan;13(1):48-54. PMID: 11883408. Exclusion Code: X7.11883408
148 Crandall CJ, Hovey KM, Andrews CA, . Bone Mineral Density as a Predictor of Subsequent Wrist Fractures: Findings From the Women’s Health Initiative Study. J Clin Endocrinol Metab. 2015 Nov;100(11):4315-24. doi: 10.1210/jc.2015-2568 [doi]. PMID: 26367200. Exclusion Code: X9.26367200
149 Crandall CJ, Newberry SJ, Diamant A, . Comparative effectiveness of pharmacologic treatments to prevent fractures: an updated systematic review. Ann Intern Med. 2014 Nov 18;161(10):711-23. doi: 10.7326/M14-0317. PMID: 25199883. Exclusion Code: X19.25199883
150 Crans GG, Genant HK, Krege JH. Prognostic utility of a semiquantitative spinal deformity index. Bone. 2005 Aug;37(2):175-9. doi: 10.1016/j.bone.2005.04.003. PMID: 15922683. Exclusion Code: X3.15922683
151 Crawford BA, Kam C, Pavlovic J, . Zoledronic acid prevents bone loss after liver trans plantation: a randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2006 Feb 21;144(4):239-48. PMID: 16490909. Exclusion Code: X3.16490909
152 Croswell J. Screening for osteoporosis. Am Fam Physician. 2011 May 15;83(10):1201-2. PMID: 21568255. Exclusion Code: X2.21568255
153 Cummings SR. Prevention of hip fractures in older women: a population-based perspective. Osteoporos Int. 1998;8 Suppl 1:S8-12. PMID: 9682790. Exclusion Code: X8.9682790
154 Cummings SR, Cawthon PM, Ensrud KE, . BMD and risk of hip and nonvertebral fractures in older men: a prospective study and comparison with older women. J Bone Miner Res. 2006 Oct;21(10):1550-6. doi: 10.1359/jbmr.060708 [doi]. PMID: 16995809. Exclusion Code: X9.16995809
155 Cummings SR, Ensrud K, Delmas PD, . Lasofoxifene in postmenopausal women with osteoporosis. N Engl J Med. 2010 Feb 25;362(8):686-96. doi: 10.1056/NEJMoa0808692. PMID: 20181970. Exclusion Code: X7.20181970
156 Cummings SR, McClung M, Reginster JY, . Arzoxifene for prevention of fractures and invasive breast cancer in postmenopausal women. J Bone Miner Res. 2011 Feb;26(2):397-404. doi: 10.1002/jbmr.191 [doi]. PMID: 20658564. Exclusion Code: X7.20658564
157 Cummings SR, Nevitt MC, Browner WS, . Risk factors for hip fracture in white women. Study of Osteoporotic Fractures Research Group. N Engl J Med. 1995 Mar 23;332(12):767-73. doi: 10.1056/nejm199503233321202. PMID: 7862179. Exclusion Code: X9.7862179
158 Cummins NM, Poku EK, Towler MR, . clinical risk factors for osteoporosis in Ireland and the UK: a comparison of FRAX and QFractureScores. Calcif Tissue Int. 2011 Aug;89(2):172-7. doi: 10.1007/s00223-011-9504-2 [doi]. PMID: 21647704. Exclusion Code: X11.21647704
159 Curtis JR, McClure LA, Delzell E, . Population-based fracture risk assessment and osteoporosis treatment disparities by race and gender. J Gen Intern Med. 2009 Aug;24(8):956-62. doi: 10.1007/s11606-009-1031-8 [doi]. PMID: 19551449. Exclusion Code: X9.19551449
160 Czerwinski E, Kanis JA, Osieleniec J, . Evaluation of FRAX to characterise fracture risk in Poland. Osteoporos Int. 2011 Sep;22(9):2507-12. doi: 10.1007/s00198-010-1502-0 [doi]. PMID: 21127840. Exclusion Code: X9.21127840
161 D’Amelio P, Sassi F, Buondonno I, . Effect of intermittent PTH treatment on plasma glucose in osteoporosis: A randomized trial. In Bone Exclusion Code: X9.
162 Damiano J, Kolta S, Porcher R, . Diagnosis of vertebral fractures by vertebral fracture assessment. J Clin Densitom. 2006 Jan-Mar;9(1):66-71. doi: 10.1016/j.jocd.2005.11.002. PMID: 16731433. Exclusion Code: X11.16731433
163 Damilakis J, Vlasiadis K. Have panoramic indices the power to identify women with low BMD at the axial skeleton? Phys Med. 2011 Jan;27(1):39-43. doi: 10.1016/j.ejmp.2010.03.002. PMID: 20359922. Exclusion Code: X12.20359922
164 Dargent-Molina P, Douchin MN, Cormier C, . Use of clinical risk factors in elderly women with low bone mineral density to identify women at higher risk of hip fracture: The EPIDOS prospective study. Osteoporos Int. 2002 Jul;13(7):593-9. doi: 10.1007/s001980200078. PMID: 12111021. Exclusion Code: X14.12111021
165 Davis SR, Kirby C, Weekes A, . Simplifying screening for osteoporosis in Australian primary care: the Prospective Screening for Osteoporosis; Australian Primary Care Evaluation of Clinical Tests (PROSPECT) study. Menopause. 2011 Jan;18(1):53-9. doi: 10.1097/gme.0b013e3181e77468 [doi]. PMID: 20711081. Exclusion Code: X14.20711081
166 Dawson-Hughes B, Looker AC, Tosteson AN, . The potential impact of new National Osteoporosis Foundation guidance on treatment patterns. Osteoporos Int. 2010 Jan;21(1):41-52. doi: 10.1007/s00198-009-1034-7 [doi]. PMID: 19705046. Exclusion Code: X9.19705046
167 Dawson-Hughes B, Looker AC, Tosteson AN, . The potential impact of the National Osteoporosis Foundation guidance on treatment eligibility in the USA: an update in NHANES 2005-2008. Osteoporos Int. 2012 Mar;23(3):811-20. doi: 10.1007/s00198-011-1694-y [doi]. PMID: 21717247. Exclusion Code: X9.21717247
168 de Nijs RN, Jacobs JW, Lems WF, . Alendronate or alfacalcidol in glucocorticoid-induced osteoporosis. N Engl J Med. 2006 Aug 17;355(7):675-84. doi: 10.1056/NEJMoa053569. PMID: 16914703. Exclusion Code: X3.16914703
169 de Valk-de Roo GW, Stehouwer CD, Meijer P, . Both raloxifene and estrogen reduce major cardiovascular risk factors in healthy postmenopausal women: A 2-year, placebo-controlled study. Arterioscler Thromb Vasc Biol. 1999 Dec;19(12):2993-3000. PMID: 10591680. Exclusion Code: X9.10591680
170 de Villiers TJ. Individualized therapy for osteoporosis prevention and treatment in women under 60. Climacteric. 2009 Jun;12(3):210-2. doi: 10.1080/13697130902937644. PMID: 19437197. Exclusion Code: X2.19437197
171 de Villiers TJ, Chines AA, Palacios S, . Safety and tolerability of bazedoxifene in postmenopausal women with osteoporosis: results of a 5-year, randomized, placebo-controlled phase 3 trial. Osteoporos Int. 2011 Feb;22(2):567-76. doi: 10.1007/s00198-010-1302-6 [doi]. PMID: 20535606. Exclusion Code: X3.20535606
172 de Vries F, Souverein PC, Cooper C, . Use of beta-blockers and the risk of hip/femur fracture in the United Kingdom and The Netherlands. Calcif Tissue Int. 2007 Feb;80(2):69-75. doi: 10.1007/s00223-006-0213-1 [doi]. PMID: 17308987. Exclusion Code: X4.17308987
173 Del Rio LM, Winzenrieth R, Cormier C, . Is bone microarchitecture status of the lumbar spine assessed by TBS related to femoral neck fracture? A Spanish case-control study. Osteoporos Int. 2013 Mar;24(3):991-8. doi: 10.1007/s00198-012-2008-8 [doi]. PMID: 22581295. Exclusion Code: X11.22581295
174 Dencks S, Barkmann R, Padilla F, . Wavelet-based signal processing of in vitro ultrasonic measurements at the proximal femur. Ultrasound Med Biol. 2007 Jun;33(6):970-80. doi: 10.1016/j.ultrasmedbio.2006.12.002. PMID: 17445965. Exclusion Code: X3.17445965
175 Devlin H, Allen PD, Graham J, . Automated osteoporosis risk assessment by dentists: a new pathway to diagnosis. Bone. 2007 Apr;40(4):835-42. doi: 10.1016/j.bone.2006.10.024. PMID: 17188590. Exclusion Code: X12.17188590
176 Devlin H, Horner K. Mandibular radiomorphometric indices in the diagnosis of reduced skeletal bone mineral density. Osteoporos Int. 2002 May;13(5):373-8. doi: 10.1007/s001980200042 [doi]. PMID: 12086347. Exclusion Code: X12.12086347
177 Dexue L, Yueyue Z. Salmon calcitonin in the treatment of elderly women with type 2 diabetes complicated with osteoporosis. Pak J Pharm Sci. 2014 Nov;27(6 Suppl):2079-81. PMID: 25410076. Exclusion Code: X5.25410076
178 Dhainaut A, Hoff M, Syversen U, . Cortical hand bone porosity and its association with distal radius fracture in middle aged and elderly women. PLoS One. 2013;8(7):e68405. doi: 10.1371/journal.pone.0068405. PMID: 23844197. Exclusion Code: X11.23844197
179 Dhainaut A, Rohde G, Hoff M, . Phalangeal densitometry compared with dual energy X-ray absorptiometry for assessment of bone mineral density in elderly women. J Womens Health (Larchmt). 2011 Dec;20(12):1789-95. doi: 10.1089/jwh.2010.2682 [doi]. PMID: 21970521. Exclusion Code: X11.21970521
180 Dhainaut A, Rohde GE, Syversen U, . The ability of hand digital X-ray radiogrammetry to identify middle-aged and elderly women with reduced bone density, as assessed by femoral neck dual-energy X-ray absorptiometry. J Clin Densitom. 2010 Oct-Dec;13(4):418-25. doi: 10.1016/j.jocd.2010.07.005. PMID: 21029976. Exclusion Code: X11.21029976
181 Diab DL, Watts NB. Postmenopausal osteoporosis. Curr Opin Endocrinol Diabetes Obes. 2013 Dec;20(6):501-9. doi: 10.1097/01.med.0000436194.10599.94 [doi]. PMID: 24150190. Exclusion Code: X4.24150190
182 Dick IM, Devine A, Beilby J, . Effects of endogenous estrogen on renal calcium and phosphate handling in elderly women. Am J Physiol Endocrinol Metab. 2005 Feb;288(2):E430-5. doi: 10.1152/ajpendo.00140.2004. PMID: 15466921. Exclusion Code: X7.15466921
183 Diez-Perez A, Gonzalez-Macias J, Marin F, . Prediction of absolute risk of non-spinal fractures using clinical risk factors and heel quantitative ultrasound. Osteoporos Int. 2007 May;18(5):629-39. doi: 10.1007/s00198-006-0297-5 [doi]. PMID: 17235664. Exclusion Code: X14.17235664
184 Dincel VE, Sengelen M, Sepici V, . The association of proximal femur geometry with hip fracture risk. Clin Anat. 2008 Sep;21(6):575-80. doi: 10.1002/ca.20680 [doi]. PMID: 18661572. Exclusion Code: X7.18661572
185 Dobnig H, Stepan JJ, Burr DB, . Teriparatide reduces bone microdamage accumulation in postmenopausal women previously treated with alendronate. J Bone Miner Res. 2009 Dec;24(12):1998-2006. doi: 10.1359/jbmr.090527 [doi]. PMID: 19453263. Exclusion Code: X9.19453263
186 Dominguez JR, Kestenbaum B, Chonchol M, . Relationships between serum and urine phosphorus with all-cause and cardiovascular mortality: the Osteoporotic Fractures in Men (MrOS) Study. AmJ Kidney Dis.2013 Apr;61(4):555-63. doi: 10.1053/j.ajkd.2012.11.033. PMID: 23261120. Exclusion Code: X9.23261120
187 Domrongkitchaiporn S, Ongphiphadhanakul B, Stitchantrakul W, . Risk of calcium oxalate nephrolithiasis in postmenopausal women supplemented with calcium or combined calcium and estrogen. Maturitas. 2002 Feb 26;41(2):149-56. PMID: 11836046. Exclusion Code: X5.11836046
188 Donaldson MG, Palermo L, Ensrud KE, . Effect of alendronate for reducing fracture by FRAX score and femoral neck bone mineral density: the Fracture Intervention Trial. J Bone Miner Res. 2012 Aug;27(8):1804-10. doi: 10.1002/jbmr.1625 [doi]. PMID: 22492479. Exclusion Code: X3.22492479
189 Duckham RL, Frank AW, Johnston JD, . Monitoring time interval for Pqct-derived bone outcomes in postmenopausal women. Osteoporos Int. 2013 Jun;24(6):1917-22. doi: 10.1007/s00198-012-2242-0 [doi]. PMID: 23344257. Exclusion Code: X7.23344257
190 Durosier C, Hans D, Krieg MA, . Defining risk thresholds for a 10-year probability of hip fracture model that combines clinical risk factors and quantitative ultrasound: results using the EPISEM cohort. J Clin Densitom. 2008 Jul-Sep;11(3):397-403. doi: 10.1016/j.jocd.2008.03.002. PMID: 18456531. Exclusion Code: X9.18456531
191 Dursun N, Dursun E, Yalcin S. Comparison of alendronate, calcitonin and calcium treatments in postmenopausal osteoporosis. Int J Clin Pract. 2001 Oct;55(8):505-9. PMID: 11695068. Exclusion Code: X8.11695068
192 Eastell R, Boonen S, Cosman F, . Relationship between pretreatmentrate of bone loss and bone density response to once-yearly ZOL: HORIZON-PFT extension study. In J Bone Miner Res Exclusion Code: X8.
193 Eastell R, Christiansen C, Grauer A, . Effects of denosumab on bone turnover markers in postmenopausal osteoporosis. J Bone Miner Res. 2011 Mar;26(3):530-7. doi: 10.1002/jbmr.251 [doi]. PMID: 20839290. Exclusion Code: X9.20839290
194 Eastell R, Devogelaer JP, Peel NF, . Prevention of bone loss with risedronate in glucocorticoid-treated rheumatoid arthritis patients. Osteoporos Int. 2000;11(4):331-7. doi: 10.1007/s001980070122. PMID: 10928223. Exclusion Code: X3.10928223
195 Eastell R, Lang T, Boonen S, . Effect of once-yearly zoledronic acid on the spine and hip as measured by quantitative computed tomography: results of the HORIZON Pivotal Fracture Trial. Osteoporos Int. 2010 Jul;21(7):1277-85. doi: 10.1007/s00198-009-1077-9 [doi]. PMID: 19802508. Exclusion Code: X9.19802508
196 Edwards FD, Grover ML, Cook CB, . Use of FRAX as a determinant for risk-based osteoporosis screening may decrease unnecessary testing while improving the odds of identifying treatment candidates. Womens Health Issues. 2014 Nov-Dec;24(6):629-34. doi: 10.1016/j.whi.2014.06.006. PMID: 25128036. Exclusion Code: X9.25128036
197 Egorov V, Tatarinov A, Sarvazyan N, . Osteoporosis detection in postmenopausal women using axial transmission multi-frequency bone ultrasonometer: clinical findings. Ultrasonics. 2014 Jul;54(5):1170-7. doi: 10.1016/j.ultras.2013.08.017. PMID: 24070826. Exclusion Code: X7.24070826
198 Elffors L, Gullberg B, Allander E, . Methodology of MEDOS multicentre study of hip fracture incidence: validity and relevance considerations. Bone. 1993;14 Suppl 1:S45-19. PMID: 8110520. Exclusion Code: X7.8110520
199 El-Hajj Fuleihan G, Baddoura R, Awada H, . First update of the Lebanese guidelines for osteoporosis assessment and treatment. J Clin Densitom. 2008 Jul-Sep;11(3):383-96. doi: 10.1016/j.jocd.2008.02.006. PMID: 18448373. Exclusion Code: X2.18448373
200 Elvey MH, Pugh H, Schaller G, . Failure in the application of fragility fracture prevention guidelines. Ann R Coll Surg Engl. 2014 Jul;96(5):381-5. doi: 10.1308/003588414X13946184901164 [doi]. PMID: 24992424. Exclusion Code: X9.24992424
201 Engel P, Fabre A, Fournier A, . Risk of osteoporotic fractures after discontinuation of menopausal hormone therapy: results from the E3N cohort. AmJ Epidemiol. 2011 Jul 1;174(1):12-21. doi: 10.1093/aje/kwr044. PMID: 21555715. Exclusion Code: X3.21555715
202 Ensrud KE, Barrett-Connor EL, Schwartz A, . Randomized trial of effect of alendronate continuation versus discontinuation in women with low BMD: results from the Fracture Intervention Trial long-term extension. J Bone Miner Res. 2004 Aug;19(8):1259-69. doi: 10.1359/jbmr.040326. PMID: 15231012. Exclusion Code: X8.15231012
203 Ensrud KE, Stock JL, Barrett-Connor E, . Effects of raloxifene on fracture risk in postmenopausal women: the Raloxifene Use for the Heart Trial. J Bone Miner Res. 2008 Jan;23(1):112-20. doi: 10.1359/jbmr.070904. PMID: 17892376. Exclusion Code: X3.17892376
204 Ettinger B. Appropriate in tervention through fracture risk assessment. Manag Care. 2005 Aug;14(8 Suppl Osteoporosis):9-12; discussion 21-3. Exclusion Code: X2.
205 Ettinger B, Black DM, Dawson-Hughes B, . Updated fracture incidence rates for the US version of FRAX. Osteoporos Int. 2010 Jan;21(1):25-33. doi: 10.1007/s00198-009-1032-9 [doi]. PMID: 19705048. Exclusion Code: X9.19705048
206 Ettinger B, Hillier TA, Pressman A, . Simple computer model for calculating and reporting 5-year osteoporotic fracture risk in postmenopausal women. J Womens Health (Larchmt). 2005 Mar;14(2):159-71. doi: 10.1089/jwh.2005.14.159 [doi]. PMID: 15775734. Exclusion Code: X9.15775734
207 Ezoddini Ardakani F, Owlia MB, Hesami S, . Digital panoramic radiography as a useful tool for detection of bone loss: a comparative study. Acta Med Iran. 2013;51(2):94-100. PMID: 23585315. Exclusion Code: X15.23585315
208 Fahrleitner-Pammer A, Langdahl BL, Marin F, . Fracture rate and back pain during and after discontinuation of teriparatide: 36-month data from the European Forsteo Observational Study (EFOS). Osteoporos Int. 2011 Oct;22(10):2709-19. doi: 10.1007/s00198-010-1498-5 [doi]. PMID: 21113576. Exclusion Code: X8.21113576
209 Fahrleitner-Pammer A, Piswanger-Soelkner JC, Pieber TR, . Ibandronate prevents bone loss and reduces vertebral fracture risk in male cardiac transplant patients: a randomized double-blind, placebo-controlled trial. J Bone Miner Res. 2009 Jul;24(7):1335-44. doi: 10.1359/jbmr.090216. PMID: 19257824. Exclusion Code: X3.19257824
210 Faulkner KG, Orwoll E. Implications in the use of T-scores for the diagnosis of osteoporosis in men. J Clin Densitom. 2002 Spring;5(1):87-93. PMID: 11940733. Exclusion Code: X9.11940733
211 Fenton JJ, Robbins JA, Amarnath AL, . Osteoporosis Overtreatment in a Regional Health Care System. JAMA Intern Med. 2016 Mar;176(3):391-3. doi: 10.1001/jamainternmed.2015.6020. PMID: 26747062. Exclusion Code: X4.26747062
212 Ferrari S, Adachi JD, Lippuner K, . Further reductions in nonvertebral fracture rate with long-term denosumab treatment in the FREEDOM open-label extension and influence of hip bone mineral density after 3 years. Osteoporos Int. 2015;26(12):2763-71. Exclusion Code: X8.26068295
213 Fidler JL, Murthy NS, Khosla S, . Comprehensive Assessment of Osteoporosis and Bone Fragility with CT Colonography. Radiology. 2016 Jan;278(1):172-80. doi: 10.1148/radiol.2015141984 [doi]. PMID: 26200602. Exclusion Code: X9.26200602
214 Finkelstein JS, Wyland JJ, Lee H, . Effects of teriparatide, alendronate, or both in women with postmenopausal osteoporosis. J Clin Endocrinol Metab. 2010 Apr;95(4):1838-45. doi: 10.1210/jc.2009-1703. PMID: 20164296. Exclusion Code: X8.20164296
215 Fitzpatrick LA, Dabrowski CE, Cicconetti G, . The effects of ronacaleret, a calcium-sensing receptor antagonist, on bone mineral density and biochemical markers of bone turnover in postmenopausal women with low bone mineral density. J Clin Endocrinol Metab. 2011 Aug;96(8):2441-9. doi: 10.1210/jc.2010-2855. PMID: 21593114. Exclusion Code: X7.21593114
216 Forsblad-d’Elia H, Carlsten H. Hormone replacement therapy in postmenopausal women with rheumatoid arthritis stabilises bone mineral density by digital x-ray radiogrammetry in a randomised controlled trial. Ann Rheum Dis. 2011 Jun;70(6):1167-8. doi: 10.1136/ard.2010.137133. PMID: 21047910. Exclusion Code: X3.21047910
217 Fowler JR, Craig MR. Association of low-energy femoral shaft fractures and bisphosphonate use. Orthopedics. 2012 Jan;35(1):e38-40. doi: 10.3928/01477447-20111122-06 [doi]. PMID: 22229611. Exclusion Code: X4.22229611
218 Franek E, Wichrowska H, Gozdowski D, . WHO fracture risk calculator (FRAX) in the assessment of obese patients with osteoporosis. Endokrynol Pol. 2009 Mar-Apr;60(2):82-7. PMID: 19396750. Exclusion Code: X9.19396750
219 Fransiska Y, Tiksnadi B, Chaidir R, . The male osteoporosis risk estimation score and the osteoporosis self-assessment screening tool for Indonesian men. J Orthop Surg (Hong Kong). 2012 Aug;20(2):205-8. PMID: 22933680. Exclusion Code: X15.22933680
220 Frisoli A, Jr., Chaves PH, Pinheiro MM, . The effect of nandrolone decanoate on bone mineral density, muscle mass, and hemoglobin levels in elderly women with osteoporosis: a double-blind, randomized, placebo-controlled clinical trial. J Gerontol A Biol Sci Med Sci. 2005 May;60(5):648-53. PMID: 15972619. Exclusion Code: X7.15972619
221 Fujita T, Fukunaga M, Itabashi A, . Once-Weekly Injection of Low-Dose Teriparatide (28.2 mug) Reduced the Risk of Vertebral Fracture in Patients with Primary Osteoporosis. Calcif Tissue Int. 2014 Feb;94(2):170-5. doi: 10.1007/s00223-013-9777-8 [doi]. PMID: 23963633. Exclusion Code: X3.23963633
222 Fujiwara S, Masunari N, Suzuki G, Ross PD. Performance of Osteoporosis Risk Indices in a Japanese Population. Curr Ther Res Clin Exp. 2001;62:586-94. Exclusion Code: X9.
223 Fujiwara S, Hamaya E, Goto W, . Vertebral fracture status and the World Health Organization risk factors for predicting osteoporotic fracture risk in Japan. Bone. 2011 Sep;49(3):520-5. doi: 10.1016/j.bone.2011.05.021. PMID: 21652001. Exclusion Code: X3.21652001
224 Fujiwara S, Nakamura T, Orimo H, . Development and application of a Japanese model of the WHO fracture risk assessment tool (FRAX). Osteoporos Int. 2008 Apr;19(4):429-35. doi: 10.1007/s00198-007-0544-4 [doi]. PMID: 18292977. Exclusion Code: X9.18292977
225 Gaal J, Bender T, Varga J, . Overcoming resistance to bisphosphonates through the administration of alfacalcidol: results of a 1-year, open follow-up study. Rheumatol Int. 2009 Nov;30(1):25-31. doi: 10.1007/s00296-009-0892-9 [doi]. PMID: 19308412. Exclusion Code: X7.19308412
226 Gadam RK, Schlauch K, Izuora KE. Frax prediction without BMD for assessment of osteoporotic fracture risk. Endocr Pract. 2013 Sep-Oct;19(5):780-4. doi: 10.4158/EP12416.OR. PMID: 24121261. Exclusion Code: X9.24121261
227 Gaines JM, Marx KA, Narrett M, . Validation of the male osteoporosis knowledge quiz. AmJ Mens Health. 2011 Jan;5(1):78-83. doi: 10.1177/1557988310363816. PMID: 20413390. Exclusion Code: X9.20413390
228 Galesanu C, Lisnic N, Moisii L. Denosumab significantly increases BMD compared with alendronate in postmenopausal women. In Osteoporos Int Exclusion Code: X8.
229 Gallacher SJ, Dixon T. Impact of treatments for postmenopausal osteoporosis (bisphosphonates, parathyroid hormone, strontiumranelate, and denosumab) on bone quality: a systematic review. Calcif Tissue Int. 2010 Dec;87(6):469-84. doi: 10.1007/s00223-010-9420-x [doi]. PMID: 20872215. Exclusion Code: X9.20872215
230 Gallagher JC, Genant HK, Crans GG, . Teriparatide reduces the fracture risk associated with increasing number and severity of osteoporotic fractures. J Clin Endocrinol Metab. 2005 Mar;90(3):1583-7. doi: 10.1210/jc.2004-0826. PMID: 15613428. Exclusion Code: X3.15613428
231 Gates BJ, Sonnett TE, Duvall CA, . Review of osteoporosis pharmacotherapy for geriatric patients. Am J Geriatr Pharmacother. 2009 Dec;7(6):293-323. doi: 10.1016/j.amjopharm.2009.12.004. PMID: 20129253. Exclusion Code: X4.20129253
232 Gatti D, Viapiana O, Idolazzi L, . The waning of teriparatide effect on bone formation markers in postmenopausal osteoporosis is associated with increasing serumlevels of DKK1. J Clin Endocrinol Metab. 2011 May;96(5):1555-9. doi: 10.1210/jc.2010-2552. PMID: 21367927. Exclusion Code: X9.21367927
233 Geary S, Selvi F, Chuang SK, . Identifying dental panoramic radiograph features for the screening of low bone mass in postmenopausal women. Int J Oral Maxillofac Surg. 2015;44(3):395-9. Exclusion Code: X9.25480009
234 Gebauer M, Stark O, Vettorazzi E, . DXA and pQCT predict pertrochanteric and not femoral neck fracture load in a human side-impact fracture model. J Orthop Res. 2014 Jan;32(1):31-8. doi: 10.1002/jor.22478 [doi]. PMID: 24019186. Exclusion Code: X3.24019186
235 Gedmintas L, Solomon DH, Kim SC. Bisphosphonates and risk of subtrochanteric, femoral shaft, and atypical femur fracture: a systematic review and meta-analysis. J Bone Miner Res. 2013 Aug;28(8):1729-37. doi: 10.1002/jbmr.1893. PMID: 23408697. Exclusion Code: X3.23408697
236 Genant HK, Siris E, Crans GG, . Reduction in vertebral fracture risk in teriparatide-treated postmenopausal women as assessed by spinal deformity index. Bone. 2005 Aug;37(2):170-4. doi: 10.1016/j.bone.2005.04.023. PMID: 15961357. Exclusion Code: X9.15961357
237 Gerdhem P, Magnusson H, Karlsson MK, . Ultrasound of the phalanges is not related to a previous fracture. A comparison between ultrasound of the phalanges, calcaneus, and DXA of the spine and hip in 75-year-old women. J Clin Densitom. 2002 Summer;5(2):159-66. PMID: 12110759. Exclusion Code: X9.12110759
238 Ghirardi A, Di Bari M, Zambon A, . Effectiveness of oral bisphosphonates for primary prevention of osteoporotic fractures: Evidence from the AIFA-BEST observational study. Eur J Clin Pharmacol. 2014;70(9):1129-37. Exclusion Code: X4.24951915
239 Girman CJ, Chandler JM, Zimmerman SI, . Prediction of fracture in nursing home residents. J Am Geriatr Soc. 2002 Aug;50(8):1341-7. PMID: 12164989. Exclusion Code: X6.12164989
240 Gluck JS, Chhabra AB. Loss of alignment after closed reduction of distalradius fractures. J Hand Surg Am. 2013 Apr;38(4):782-3. doi: 10.1016/j.jhsa.2012.08.001. PMID: 23098633. Exclusion Code: X7.23098633
241 Gluer CC, Barkmann R. Quantitative ultrasound: use in the detection of fractures and in the assessment of bone composition. Curr Osteoporos Rep. 2003 Dec;1(3):98-104. PMID: 16036071. Exclusion Code: X2.16036071
242 Gnudi S, Sitta E, Pignotti E. Prediction of incident hip fracture by femoral neck bone mineral density and neck-shaft angle: a 5-year longitudinal study in post-menopausal females. Br J Radiol. 2012 Aug;85(1016):e467-73. doi: 10.1259/bjr/57130600. PMID: 22096224. Exclusion Code: X7.22096224
243 Goderie-Plomp HW, van der Klift M, de Ronde W, . Endogenous sex hormones, sex hormone-binding globulin, and the risk of incident vertebral fractures in elderly men and women: the Rotterdam Study. J Clin Endocrinol Metab. 2004 Jul;89(7):3261-9. doi: 10.1210/jc.2002-022041. PMID: 15240601. Exclusion Code: X7.15240601
244 Goh SK, Yang KY, Koh JS, . Subtrochanteric insufficiency fractures in patients on alendronate therapy: a caution. J Bone Joint Surg Br. 2007 Mar;89(3):349-53. doi: 10.1302/0301-620x.89b3.18146. PMID: 17356148. Exclusion Code: X4.17356148
245 Goldstein SR, Bhattoa HP, Neven P, . Gynecologic effects of arzoxifene in postmenopausal women with osteoporosis or low bone mass. Menopause. 2012 Jan;19(1):41-7. doi: 10.1097/gme.0b013e318223bbf4 [doi]. PMID: 21993078. Exclusion Code: X7.21993078
246 Goldstein SR, Neven P, Cummings S, . Postmenopausal Evaluation and Risk Reduction With Lasofoxifene (PEARL) trial: 5-year gynecological outcomes. Menopause. 2011 Jan;18(1):17-22. doi: 10.1097/gme.0b013e3181e84bb4 [doi]. PMID: 20689465. Exclusion Code: X7.20689465
247 Gomez-Vaquero C, Bianchi M, Santo P, . The activity of a Spanish bone densitometry unit revisited under the point of view of FRAX. Reumatol Clin. 2012 Jul-Aug;8(4):179-83. doi: 10.1016/j.reuma.2012.02.003. PMID: 22608955. Exclusion Code: X9.22608955
248 Gordon L, Pope TL, Monen S. Value of vertebral X-rays in osteoporosis. J S C Med Assoc. 2001 Mar;97(3):102-5. PMID: 11285880. Exclusion Code: X2.11285880
249 Gosens T, Speigner B, Minekus J. Fracture of the scapular body: functional outcome after conservative treatment. J Shoulder Elbow Surg. 2009 May-Jun;18(3):443-8. doi: 10.1016/j.jse.2009.01.030. PMID: 19393934. Exclusion Code: X11.19393934
250 Gourlay ML, Fine JP, Preisser JS, . Bone-density testing interval and transition to osteoporosis in older women. N Engl J Med. 2012 Jan 19;366(3):225-33. doi: 10.1056/NEJMoa1107142 [doi]. PMID: 22256806. Exclusion Code: X9.22256806
251 Gourlay ML, Overman RA, Fine JP, . Baseline age and time to major fracture in younger postmenopausal women. Menopause. 2015 Jun;22(6):589-97. doi: 10.1097/GME.0000000000000356 [doi]. PMID: 25349960. Exclusion Code: X9.25349960
252 Grady D, Ettinger B, Moscarelli E, . Safety and adverse effects associated with raloxifene: multiple outcomes of raloxifene evaluation. Obstet Gynecol. 2004 Oct;104(4):837-44. doi: 10.1097/01.AOG.0000137349.79204.b8. PMID: 15458908. Exclusion Code: X16.15458908
253 Grbic JT, Black DM, Lyles KW, . The incidence of osteonecrosis of the jaw in patients receiving 5 milligrams of zoledronic acid: data from the health outcomes and reduced incidence with zoledronic acid once yearly clinical trials program. J Am Dent Assoc. 2010 Nov;141(11):1365-70. PMID: 21037195. Exclusion Code: X8.21037195
254 Grbic JT, Landesberg R, Lin SQ, . Incidence of osteonecrosis of the jaw in women with postmenopausal osteoporosis in the health outcomes and reduced incidence with zoledronic acid once yearly pivotal fracture trial. J Am Dent Assoc. 2008 Jan;139(1):32-40. PMID: 18167382. Exclusion Code: X3.18167382
255 Green AD, Colon-Emeric CS, Bastian L, . Does this woman have osteoporosis? JAMA. 2004 Dec 15;292(23):2890-900. doi: 10.1001/jama.292.23.2890. PMID: 15598921. Exclusion Code: X2.15598921
256 Greenspan SL, Bhattacharya RK, Sereika SM, . Prevention of bone loss in survivors of breast cancer: A randomized, double-blind, placebo-controlled clinical trial. J Clin End ocrinol Metab. 2007 Jan;92(1):131-6. doi: 10.1210/jc.2006-1272. PMID: 17047022. Exclusion Code: X3.17047022
257 Greenspan SL, Perera S, Ferchak MA, . Efficacy and safety of single-dose zoledronic acid for osteoporosis in frail elderly women: a randomized clinical trial. JAMA Intern Med. 2015 Jun;175(6):913-21. doi: 10.1001/jamainternmed.2015.0747. PMID: 25867538. Exclusion Code: X3.25867538
258 Griffith JF, Yeung DK, Leung JC, . Prediction of bone loss in elderly female subjects by MR perfusion imaging and spectroscopy. Eur Radiol. 2011 Jun;21(6):1160-9. doi: 10.1007/s00330-010-2054-6 [doi]. PMID: 21225266. Exclusion Code: X7.21225266
259 Grotz W, Nagel C, Poeschel D, . Effect of ibandronate on bone loss and renal function after kidney transplantation. J Am Soc Nephrol. 2001 Jul;12(7):1530-7. PMID: 11423583. Exclusion Code: X3.11423583
260 Gruber M, Bauer JS, Dobritz M, . Bone mineral density measurements of the proximal femur from routine contrast-enhanced MDCT data sets correlate with dual-energy X-ray absorptiometry. Eur Radiol. 2013 Feb;23(2):505-12. doi: 10.1007/s00330-012-2629-5 [doi]. PMID: 22932742. Exclusion Code: X7.22932742
261 Guessous I, Cornuz J, Ruffieux C, . Osteoporotic fracture risk in elderly women: estimation with quantitative heel US and clinical risk factors. Radiology. 2008 Jul;248(1):179-84. doi: 10.1148/radiol.2481070986. PMID: 18483227. Exclusion Code: X14.18483227
262 Guggenbuhl P, Dufour R, Liu-Leage S, . Efficiency of bone density testing by dual-biphotonic X-rays absorptiometry for diagnosis of osteoporosis according to French guideline recommendations: the PRESAGE study. Joint Bone Spine. 2011 Oct;78(5):493-8. doi: 10.1016/j.jbspin.2010.12.009. PMID: 21367636. Exclusion Code: X8.21367636
263 Guglielmi G, Rossini M, Nicolosi MG, . Three-year prospective study on fracture risk in postmenopausal women by quantitative ultrasound at the phalanges. J Clin Densitom. 2013 Jul-Sep;16(3):341-6. doi: 10.1016/j.jocd.2012.07.006. PMID: 22901551. Exclusion Code: X13.22901551
264 Gulati D, Kumar S, Arora A, . Bone mineral density in young Indian adults with traumatic proximal femoral fractures. A case control study. Acta Orthop Belg. 2010 Jun;76(3):335-40. PMID: 20698454. Exclusion Code: X3.20698454
265 Hadziavdic A, Vajic N, Gavric N. COMPARISON OF T-SCORE VALUES OBTAINED BY ULTRASOUND OSTEODENSITOMETRY OF CALCANEUS AND BY DUAL-ENERGY X-RAY ABSORPTIOMETRY SCAN. Med Pregl. 2015 Sep-Oct;68(9-10):341-6. PMID: 26727832. Exclusion Code: X9.26727832
266 Hamdy RC, Kiebzak GM. Variance in 10-year fracture risk calculated with and without T-scores in select subgroups of normal and osteoporotic patients. J Clin Densitom. 2009 Apr-Jun;12(2):158-61. doi: 10.1016/j.jocd.2008.12.003. PMID: 19201635. Exclusion Code: X9.19201635
267 Hao Y, Hao G, Qiu S, . Effects of age and gender on the likelihood of hip fracture in the elderly population in Shanghai, China. Saudi Med J. 2009 Nov;30(11):1483-5. PMID: 19882067. Exclusion Code: X7.19882067
268 Harness NG, Funahashi T, Dell R, . Distalradius fracture risk reduction with a comprehensive osteoporosis management program. J Hand Surg Am. 2012 Aug;37(8):1543-9. doi: 10.1016/j.jhsa.2012.04.033. PMID: 22748352. Exclusion Code: X4.22748352
269 Harris ST, Watts NB, Genant HK, . Effects of risedronate treatment on vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: a randomized controlled trial. Vertebral Efficacy With Risedronate Therapy (VERT) Study Group. JAMA. 1999 Oct 13;282(14):1344-52. PMID: 10527181. Exclusion Code: X3.10527181
270 Harvey JA, Holm MK, Ranganath R, . The effects of bazedoxifene on mammographic breast density in postmenopausal women with osteoporosis. Menopause. 2009 Nov-Dec;16(6):1193-6. doi: 10.1097/gme.0b013e3181a7fb1e [doi]. PMID: 19503006. Exclusion Code: X9.19503006
271 Harvey NC, Kanis JA, Oden A, . Efficacy of weekly teriparatide does not vary by baseline fracture probability calculated using FRAX. Osteoporos Int. 2015 Sep;26(9):2347-53. doi: 10.1007/s00198-015-3129-7 [doi]. PMID: 26092062. Exclusion Code: X9.26092062
272 Harvey NC, McCloskey EV. Gaps and Solutions in Both Health: A Global Framework for Improvement. Nyon, Switzerland: Foundation IO; 2016. http://share.iofbonehealth.org/WOD/2016/thematic-report/WOD16-report-WEB-EN.pdf Exclusion Code: X2.
273 Hassani-Nejad A, Ahlqwist M, Hakeberg M, . Mandibular trabecular bone as fracture indicator in 80-year-old men and women. Eur J Oral Sci. 2013 Dec;121(6):525-31. doi: 10.1111/eos.12087 [doi]. PMID: 24102691. Exclusion Code: X12.24102691
274 Hasserius R, Karlsson MK, Nilsson BE, . Non-participants differ from participants as regards risk factors for vertebral deformities: a source of misinterpretation in the European Vertebral Osteoporosis Study. Acta Orthop Scand. 2002 Aug;73(4):451-4. doi: 10.1080/00016470216326 [doi]. PMID: 12358120. Exclusion Code: X4.12358120
275 Hassler N, Gamsjaeger S, Hofstetter B, . Effects of long-term alendronate treatment on postmenopausal osteoporosis bone material properties. In Osteoporosis international: a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA Exclusion Code: X9.
276 Hauk L. ACOG releases practice bulletin on osteoporosis. Am Fam Physician. 2013 Aug 15;88(4):269-75. PMID: 23944732. Exclusion Code: X2.23944732
277 Hawker G, Mendel A, Lam MA, . A clinical decision rule to enhance targeted bone mineral density testing in healthy mid-life women. Osteoporos Int. 2012 Jul;23(7):1931-8. doi: 10.1007/s00198-011-1862-0 [doi]. PMID: 22159633. Exclusion Code: X14.22159633
278 Heaney RP, Watson P. Variability in the measured response of bone to teriparatide. Osteoporos Int. 2011 Jun;22(6):1703-8. doi: 10.1007/s00198-010-1376-1 [doi]. PMID: 20827548. Exclusion Code: X4.20827548
279 Heckbert SR, Li G, Cummings SR, . Use of alendronate and risk of incident atrial fibrillation in women. Arch Intern Med. 2008 Apr 28;168(8):826-31. doi: 10.1001/archinte.168.8.826. PMID: 18443257. Exclusion Code: X3.18443257
280 Hedstrom L, Baigi A, Bergh H. The relation between bone mineral density in the heel and pixel intensity in the mandibular jaw bone among elderly women. Dentomaxillofac Radiol. 2010 Oct;39(7):409-13. doi: 10.1259/dmfr/50171873. PMID: 20841458. Exclusion Code: X8.20841458
281 Henriksen K, Byrjalsen I, Andersen JR, . A randomized, double-blind, multicenter, placebo-controlled study to evaluate the efficacy and safety of oral salmon calcitonin in the treatment of osteoporosis in postmenopausal women taking calcium and vitamin D. In Bone Exclusion Code: X7.
282 Henry MJ, Pasco JA, Sanders KM, . Application of epidemiology to change health policy: defining age-related thresholds of bone mineral density for primary prevention of fracture. J Clin Densitom. 2008 Oct-Dec;11(4):494-7. doi: 10.1016/j.jocd.2008.05.090. PMID: 18619881. Exclusion Code: X9.18619881
283 Henry MJ, Pasco JA, Seeman E, . Assessment of fracture risk: value of random population-based samples--the Geelong Osteoporosis Study. J Clin Densitom. 2001 Winter;4(4):283-9. PMID: 11748333. Exclusion Code: X9.11748333
284 Henry MJ, Pasco JA, Seeman E, . Fracture thresholds revisited. Geelong Osteoporosis Study. J Clin Epidemiol. 2002 Jul;55(7):642-6. PMID: 12160911. Exclusion Code: X11.12160911
285 Hey HW, Sng W J, Lim JL, . Interpretation of hip fracture patterns using areal bone mineral density in the proximal femur. Arch Orthop Trauma Surg. 2015 Dec;135(12):1647-53. doi: 10.1007/s00402-015-2326-3. PMID: 26391986. Exclusion Code: X3.26391986
286 Holloway KL, Kotowicz MA, Lane SE, . FRAX (Aus) and falls risk: Association in men and women. Bone. 2015;76((Holloway K.L., KHOLLO@BarwonHealth.org.au; Kotowicz M.A.; Lane S.E.; Brennan S.L.; Pasco J.A.) School of Medicine, Deakin University, Geelong, Australia):1-4. Exclusion Code: X8.
287 Hooper MJ, Ebeling PR, Roberts AP, . Risedronate prevents bone loss in early postmenopausal women: a prospective randomized, placebo-controlled trial. Climacteric. 2005 Sep;8(3):251-62. doi: 10.1080/13697130500118126. PMID: 16390757. Exclusion Code: X3.16390757
288 Horner K, Allen P, Graham J, . The relationship between the OSTEODENT index and hip fracture risk assessment using FRAX. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2010 Aug;110(2):243-9. doi: 10.1016/j.tripleo.2010.03.035. PMID: 20659701. Exclusion Code: X14.20659701
289 Horner K, Devlin H, Harvey L. Detecting patients with low skeletal bone mass. J Dent. 2002 May;30(4):171-5. PMID: 12450724. Exclusion Code: X12.12450724
290 Horner K, Karayianni K, Mitsea A, . The mandibular cortex on radiographs as a tool for osteoporosis risk assessment: the OSTEODENT Project. J Clin Densitom. 2007 Apr-Jun;10(2):138-46. doi: 10.1016/j.jocd.2007.02.004. PMID: 17449308. Exclusion Code: X12.17449308
291 Horwitz MJ, Augustine M, Khan L, . A comparison of parathyroid hormone-related protein (1-36) and parathyroid hormone (1-34) on markers of bone turnover and bone density in postmenopausal women: the PrOP study. J Bone Miner Res. 2013 Nov;28(11):2266-76. doi: 10.1002/jbmr.1978 [doi]. PMID: 23661240. Exclusion Code: X8.23661240
292 Hosking D, Chilvers CE, Christiansen C, . Prevention of bone loss with alendronate in postmenopausal women under 60 years of age. Early Postmenopausal Intervention Cohort Study Group. N Engl J Med. 1998 Feb 19;338(8):485-92. doi: 10.1056/nejm199802193380801. PMID: 9443925. Exclusion Code: X3.9443925
293 Hwang JS, Chin LS, Chen JF, . The effects of intravenous zoledronic acid in Chinese women with postmenopausal osteoporosis. J Bone Miner Metab. 2011 May;29(3):328-33. doi: 10.1007/s00774-010-0223-y. PMID: 20922438. Exclusion Code: X3.20922438
294 Hwang JS, Liou MJ, Ho C, . The effects of weekly alendronate therapy in Taiwanese males with osteoporosis. J Bone Miner Metab. 2010 May;28(3):328-33. doi: 10.1007/s00774-009-0136-9 [doi]. PMID: 20012918. Exclusion Code: X9.20012918
295 Iba K, Takada J, Sasaki K, . Course of NTX changes under continuous bisphosphonate treatment in cases of NTX over-reduction due to long-term treatment with bisphosphonates. J Orthop Sci. 2011 Jan;16(1):71-6. doi: 10.1007/s00776-010-0008-0 [doi]. PMID: 21290152. Exclusion Code: X4.21290152
296 Idolazzi L, Maugeri D, Monti S, . The Italian Observational Study on Severe Osteoporosis (ISSO): 24-month results on incidence of fractures and adherence to treatment. Clin Exp Rheumatol. 2016 Mar-Apr;34(2):247-53. PMID: 26940788. Exclusion Code: X4.26940788
297 Iida T, Chikamura C, Aoi S, . A study on the validity of quantitative ultrasonic measurement used the bone mineral density values on dual-energy X-ray absorptiometry in young and in middle-aged or older women. Radiological Physics and Technology. 2010;3(2):113-9. Exclusion Code: X9.20821084
298 Ikegami S, Kamimura M, Uchiyama S, . Unilateral vs bilateral hip bone mineral density measurement for the diagnosis of osteoporosis. J Clin Densitom. 2014 Jan-Mar;17(1):84-90. doi: 10.1016/j.jocd.2013.04.003. PMID: 23683727. Exclusion Code: X9.23683727
299 Ilter E, Karalok H, Tufekci EC, . Efficacy and acceptability of risedronate 5 mg daily compared with 35 mg once weekly for the treatment of postmenopausal osteoporosis. Climacteric. 2006 Apr;9(2):129-34. doi: 10.1080/13697130600652180. PMID: 16698659. Exclusion Code: X5.16698659
300 Isaacs JD, Shidiak L, Harris IA, . Femoral insufficiency fractures associated with prolonged bisphosphonate therapy. Clin Orthop Relat Res. 2010 Dec;468(12):3384-92. doi: 10.1007/s11999-010-1535-x [doi]. PMID: 20809164. Exclusion Code: X4.20809164
301 Ishii S, Greendale GA, Cauley JA, . Fracture risk assessment without race/ethnicity information. J Clin Endocrinol Metab.2012 Oct;97(10):3593-602. doi: 10.1210/jc.2012-1997. PMID: 22865903. Exclusion Code: X7.22865903
302 Itabashi A, Yoh K, Chines AA, . Effects of bazedoxifene on bone mineral density, bone turnover, and safety in postmenopausal Japanese women with osteoporosis. J Bone Miner Res. 2011 Mar;26(3):519-29. doi: 10.1002/jbmr.252 [doi]. PMID: 20839291. Exclusion Code: X7.20839291
303 Ito K, Leslie W D. Cost-effectiveness of fracture prevention in rural women with limited access to dual-energy X-ray absorptiometry. Osteoporos Int. 2015 Aug;26(8):2111-9. doi: 10.1007/s00198-015-3107-0 [doi]. PMID: 25807913. Exclusion Code: X9.25807913
304 Iwamoto J, Makita K, Sato Y, . Alendronate is more effective than elcatonin in improving pain and quality of life in postmenopausal women with osteoporosis. Osteoporos Int. 2011 Oct;22(10):2735-42. doi: 10.1007/s00198-010-1495-8 [doi]. PMID: 21104227. Exclusion Code: X8.21104227
305 Iwamoto J, Takeda T, Ichimura S, . Effects of 5-year treatment with elcatonin and alfacalcidolon lumbar bone mineral density and the incidence of vertebral fractures in postmenopausal women with osteoporosis: a retrospective study. J Orthop Sci. 2002;7(6):637-43. doi: 10.1007/s007760200114 [doi]. PMID: 12486466. Exclusion Code: X7.12486466
306 Jacobsen DE, Melis RJ, Verhaar HJ, . Raloxifene and tibolone in elderly women: a randomized, double-blind, double-dummy, placebo-controlled trial. J Am Med Dir Assoc. 2012 Feb;13(2):189 e1-7. doi: 10.1016/j.jamda.2011.05.005. PMID: 21741883. Exclusion Code: X3.21741883
307 Jagelaviciene E, Krasauskiene A, Zalinkevicius R, . The relationship between the calcaneal bone mineral density and the mental index in post-menopausal females. Dentomaxillofac Radiol. 2013;42(4):20120050. doi: 10.1259/dmfr.20120050. PMID: 23420860. Exclusion Code: X7.23420860
308 Jager PL, Slart RH, Webber CL, . Combined vertebral fracture assessment and bone mineral density measurement: a patient-friendly new tool with an important impact on the Canadian Risk Fracture Classification. Can Assoc Radiol J. 2010 Oct;61(4):194-200. doi: 10.1016/j.carj.2009.12.012. PMID: 20199851. Exclusion Code: X3.20199851
309 Jakob F, Oertel H, Langdahl B, . Effects of teriparatide in postmenopausal women with osteoporosis pre-treated with bisphosphonates: 36-month results from the European Forsteo Observational Study. Eur J Endocrinol. 2012 Jan;166(1):87-97. doi: 10.1530/EJE-11-0740. PMID: 22048967. Exclusion Code: X8.22048967
310 Jamal SA, Ljunggren O, Stehman-Breen C, . Effects of denosumab on fracture and bone mineral density by level of kidney function. J Bone Miner Res. 2011 Aug;26(8):1829-35. doi: 10.1002/jbmr.403 [doi]. PMID: 21491487. Exclusion Code: X3.21491487
311 Jiang E, Wang Z, Meng Q, . Study on bone density at various skeletal sites for the diagnosis of primary osteoporosis. Cell Biochem Biophys. 2012 Sep;64(1):1-3. doi: 10.1007/s12013-012-9361-2 [doi]. PMID: 22535203. Exclusion Code: X9.22535203
312 Jiang P, Missoum S, Chen Z. Fusion of clinical and stochastic finite element data for hip fracture risk prediction. J Biomech. 2015 Nov 26;48(15):4043-52. doi: 10.1016/j.jbiomech.2015.09.044. PMID: 26482733. Exclusion Code: X8.26482733
313 Jiang X, Good LE, Spinka R, . Osteoporosis screening in postmenopausal women aged 50-64 years: BMI alone compared with current screening tools. Maturitas. 2016 Jan;83:59-64. doi: 10.1016/j.maturitas.2015.09.009. PMID: 26471931. Exclusion Code: X9.26471931
314 Jiang X, Westermann LB, Galleo GV, . Age as a predictor of osteoporotic fracture compared with current risk-prediction models. Obstet Gynecol. 2013 Nov;122(5):1040-6. doi: 10.1097/AOG.0b013e3182a7e29b [doi]. PMID: 24104773. Exclusion Code: X11.24104773
315 Jobke B, Muche B, Burghardt AJ, . Teriparatide in bisphosphonate-resistant osteoporosis: microarchitectural changes and clinical results after 6 and 18 months. Calcif Tissue Int. 2011 Aug;89(2):130-9. doi: 10.1007/s00223-011-9500-6 [doi]. PMID: 21626160. Exclusion Code: X8.21626160
316 Johansson H, Kanis JA, McCloskey EV, . A FRAX(R) model for the assessment of fracture probability in Belgium. Osteoporos Int. 2011 Feb;22(2):453-61. doi: 10.1007/s00198-010-1218-1 [doi]. PMID: 20352409. Exclusion Code: X9.20352409
317 Johansson T. PTH 1-34 (teriparatide) may not improve healing in proximal humerus fractures. A randomized, controlled study of 40 patients. Acta Orthop. 2016 Feb;87(1):79-82. doi: 10.3109/17453674.2015.1073050 [doi]. PMID: 26179771. Exclusion Code: X9.26179771
318 Johnston CC, Jr., Bjarnason NH, Cohen FJ, . Long-term effects of raloxifene on bone mineral density, bone turnover, and serumlipid levels in early postmenopausal women: three-year data from 2 double-blind, randomized, placebo-controlled trials. Arch Intern Med. 2000 Dec 11-25;160(22):3444-50. PMID: 11112238. Exclusion Code: X4.11112238
319 Jonasson G, Alstad T, Vahedi F, . Trabecular pattern in the mandible as bone fracture predictor. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2009 Oct;108(4):e42-51. doi: 10.1016/j.tripleo.2009.05.018. PMID: 19778734. Exclusion Code: X9.19778734
320 Jonasson G, Billhult A. Mandibular bone structure, bone mineral density, and clinical variables as fracture predictors: a 15-year follow-up of female patients in a dental clinic. Oral Surg Oral Med Oral Pathol Oral Radiol. 2013 Sep;116(3):362-8. doi: 10.1016/j.oooo.2013.06.009. PMID: 23953422. Exclusion Code: X9.23953422
321 Jonasson G, Sundh V, Ahlqwist M, . A prospective study of mandibular trabecular bone to predict fracture incidence in women: a low-cost screening tool in the dental clinic. Bone. 2011 Oct;49(4):873-9. doi: 10.1016/j.bone.2011.06.036. PMID: 21777710. Exclusion Code: X9.21777710
322 Kamondetdecha R, Panyakhamlerd K, Chaikittisilpa S, . Value of Osteoporosis Self-assessment Tools for Asians (OSTA) with or without Brown’s clinical risk factors in detection of postmenopausal osteoporosis. Climacteric. 2013 Feb;16(1):127-32. doi: 10.3109/13697137.2012.678913 [doi]. PMID: 22741522. Exclusion Code: X5.22741522
323 Kang JH, Keller JJ, Lin HC. A population-based 2-year follow-up study on the relationship between bisphosphonates and the risk of stroke. Osteoporos Int. 2012 Oct;23(10):2551-7. doi: 10.1007/s00198-012-1894-0 [doi]. PMID: 22270858. Exclusion Code: X5.22270858
324 Kang JH, Keller JJ, Lin HC. Bisphosphonates reduced the risk of acute myocardial infarction: a 2-year follow-up study. Osteoporos Int. 2013 Jan;24(1):271-7. doi: 10.1007/s00198-012-2213-5 [doi]. PMID: 23152093. Exclusion Code: X5.23152093
325 Kanis JA, Brazier JE, Stevenson M, . Treatment of established osteoporosis: a systematic review and cost-utility analysis. Health Technol Assess. 2002;6(29):1-146. PMID: 12654239. Exclusion Code: X16.12654239
326 Kanis JA, Johansson H, Oden A, . The effects of a FRAX revision for the USA. Osteoporos Int. 2010 Jan;21(1):35-40. doi: 10.1007/s00198-009-1033-8 [doi]. PMID: 19705047. Exclusion Code: X9.19705047
327 Kanis JA, Johnell O, De Laet C, . International variations in hip fracture probabilities: implications for risk assessment. J Bone Miner Res. 2002 Jul;17(7):1237-44. doi: 10.1359/jbmr.2002.17.7.1237 [doi]. PMID: 12096837. Exclusion Code: X7.12096837
328 Kanis JA, Johnell O, Oden A, . Ten year probabilities of osteoporotic fractures according to BMD and diagnostic thresholds. Osteoporos Int. 2001 Dec;12(12):989-95. doi: 10.1007/s001980170006 [doi]. PMID: 11846333. Exclusion Code: X9.11846333
329 Kanis JA, Johnell O, Oden A, . Ten-year probabilities of clinical vertebral fractures according to phalangeal quantitative ultrasonography. Osteoporos Int. 2005 Sep;16(9):1065-70. doi: 10.1007/s00198-004-1805-0 [doi]. PMID: 15586268. Exclusion Code: X9.15586268
330 Kanis JA, McCloskey EV, Johansson H, . European guidance for the diagnosis and management of osteoporosis in postmenopausal women. Osteoporos Int. 2013 Jan;24(1):23-57. doi: 10.1007/s00198-012-2074-y [doi]. PMID: 23079689. Exclusion Code: X2.23079689
331 Kanis JA, Oden A, McCloskey EV, . A systematic review of hip fracture incidence and probability of fracture worldwide. Osteoporos Int. 2012 Sep;23(9):2239-56. doi: 10.1007/s00198-012-1964-3 [doi]. PMID: 22419370. Exclusion Code: X7.22419370
332 Karjalainen JP, Riekkinen O, Toyras J, . Multi-site bone ultrasound measurements in elderly women with and without previous hip fractures. Osteoporos Int. 2012 Apr;23(4):1287-95. doi: 10.1007/s00198-011-1682-2 [doi]. PMID: 21656263. Exclusion Code: X7.21656263
333 Karlamangla AS, Barrett-Connor E, Young J, . Hip fracture risk assessment using composite indices of femoral neck strength: the Rancho Bernardo study. Osteoporos Int. 2004 Jan;15(1):62-70. doi: 10.1007/s00198-003-1513-1 [doi]. PMID: 14605798. Exclusion Code: X9.14605798
334 Karras D, Stoykov I, Lems WF, . Effectiveness of teriparatide in postmenopausal women with osteoporosis and glucocorticoid use: 3-year results from the EFOS study. J Rheumatol. 2012 Mar;39(3):600-9. doi: 10.3899/jrheum.110947. PMID: 22247365. Exclusion Code: X4.22247365
335 Kaufman JM, Orwoll E, Goemaere S, . Teriparatide effects on vertebral fractures and bone mineral density in men with osteoporosis: treatment and discontinuation of therapy. Osteoporos Int. 2005 May;16(5):510-6. doi: 10.1007/s00198-004-1713-3. PMID: 15322742. Exclusion Code: X7.15322742
336 Kauppi M, Impivaara O, Maki J, . Quantitative ultrasound measurements and vitamin D status in the assessment of hip fracture risk in a nationally representative population sample. Osteoporos Int. 2013 Oct;24(10):2611-8. doi: 10.1007/s00198-013-2355-0 [doi]. PMID: 23595563. Exclusion Code: X14.23595563
337 Kavitha MS, Asano A, Taguchi A, . Diagnosis of osteoporosis from dental panoramic radiographs using the support vector machine method in a computer-aided system. BMC Med Imaging. 2012;12:1. doi: 10.1186/1471-2342-12-1. PMID: 22248480. Exclusion Code: X12.22248480
338 Kavitha MS, Samopa F, Asano A, . Computer-aided measurement of mandibular cortical width on dental panoramic radiographs for identifying osteoporosis. J Investig Clin Dent. 2012 Feb;3(1):36-44. doi: 10.1111/j.2041-1626.2011.00095.x [doi]. PMID: 22298519. Exclusion Code: X12.22298519
339 Kayalar G, Cevikol A, Yavuzer G, . The value of calcaneal bone mass measurement using a dual X-ray laser Calscan device in risk screening for osteoporosis. In Clinics (São Paulo, Brazil) Exclusion Code: X9.
340 Keaveny TM, McClung MR, Genant HK, . Femoral and vertebral strength improvements in postmenopausal women with osteoporosis treated with denosumab. J Bone Miner Res. 2014 Jan;29(1):158-65. doi: 10.1002/jbmr.2024 [doi]. PMID: 23794225. Exclusion Code: X9.23794225
341 Kendler D. Sustainability of anti-fracture efficacy and safety of denosumab in postmenopausal osteoporosis. Osteoporos Int. 2013;24(Suppl 4):S653-4. Exclusion Code: X8.
342 Kerkeni S, Kolta S, Fechtenbaum J, . Spinal deformity index (SDI) is a good predictor of incident vertebral fractures. Osteoporos Int. 2009 Sep;20(9):1547-52. doi: 10.1007/s00198-008-0832-7 [doi]. PMID: 19137350. Exclusion Code: X9.19137350
343 Kern LM, Powe NR, Levine MA, . Association between screening for osteoporosis and the incidence of hip fracture. Ann Intern Med. 2005 Feb 1;142(3):173-81. PMID: 15684205. Exclusion Code: X4.15684205
344 Kessel B, Nachtigall L, Plouffe L, . Effect of raloxifene on sexual function in postmenopausal women. Climacteric. 2003 Sep;6(3):248-56. PMID: 14567773. Exclusion Code: X9.14567773
345 Khan AA, Morrison A, Hanley DA, . Diagnosis and management of osteonecrosis of the jaw: a systematic review and international consensus. J Bone Miner Res. 2015 Jan;30(1):3-23. doi: 10.1002/jbmr.2405. PMID: 25414052. Exclusion Code: X3.25414052
346 Khan AA, Sandor GK, Dore E, . Bisphosphonate associated osteonecrosis of the jaw. J Rheumatol. 2009 Mar;36(3):478-90. doi: 10.3899/jrheum.080759. PMID: 19286860. Exclusion Code: X8.19286860
347 Kiebzak GM, Binkley N, Lewiecki EM, . Diagnostic agreement at the total hip using different DXA systems and the NHANES III database. J Clin Densitom. 2007 Apr-Jun;10(2):132-7. doi: 10.1016/j.jocd.2007.02.003. PMID: 17416539. Exclusion Code: X9.17416539
348 Kim JW, Koh JM, Park JH, . Validation of FRAX without BMD: an age-related analysis of the Fifth Korean National Health and Nutrition Examination Survey (KNHANES V-1, 2010). Bone. 2015 Jun;75:27-31. doi: 10.1016/j.bone.2015.02.013. PMID: 25697083. Exclusion Code: X9.25697083
349 Kim S, Won CW, Kim BS, . The association between the low muscle mass and osteoporosis in elderly Korean people. J Korean Med Sci. 2014 Jul;29(7):995-1000. doi: 10.3346/jkms.2014.29.7.995 [doi]. PMID: 25045234. Exclusion Code: X7.25045234
350 Kimber C, Grimmer-Somers K. A novel primary care clinical prediction rule for early detection of osteoporosis. Aust J Prim Health. 2011;17(2):175-80. doi: 10.1071/PY10045. PMID: 21645474. Exclusion Code: X3.21645474
351 Koh JM, Oh HJ, Park IH, . Efficacy and safety results froma six month double-blind study comparing 60mg Denosumab (DMAb) and placebo in Korean postmenopausal women with osteoporosis. J Bone Miner Res. 2013 Feb;28. PMID: WOS:000332035804003. Exclusion Code: X18.
352 Koyama H, Yoshihara H, Kotera M, . Th equantitative diagnostic capability of routine MR imaging and diffusion-weighted imaging in osteoporosis patients. Clin Imaging. 2013 Sep-Oct;37(5):925-9. doi: 10.1016/j.clinimag.2013.05.001. PMID: 23849102. Exclusion Code: X7.23849102
353 Kreidieh OI, El-Hajj Fuleihan G. Impact of changes in mortality on FRAX-derived fracture probabilities. Bone. 2014 May;62:43-50. doi: 10.1016/j.bone.2014.01.014. PMID: 24480305. Exclusion Code: X9.24480305
354 Kuet KP, Charles worth D, Peel NF. Vertebral fracture assessment scans enhance targeting of investigations and treatment within a fracture risk assessment pathway. Osteoporos Int. 2013 Mar;24(3):1007-14. doi: 10.1007/s00198-012-2255-8 [doi]. PMID: 23306821. Exclusion Code: X9.23306821
355 Kung AW, Pasion EG, Sofiyan M, . A comparison of teriparatide and calcitonin therapy in postmenopausal Asian women with osteoporosis: a 6-month study. Curr Med Res Opin. 2006 May;22(5):929-37. doi: 10.1185/030079906X104768 [doi]. PMID: 16709314. Exclusion Code: X5.16709314
356 Kung AW, Yeung SS, Chu LW. The efficacy and tolerability of alendronate in postmenopausal osteoporotic Chinese women: a randomized placebo-controlled study. Calcif Tissue Int. 2000 Oct;67(4):286-90. PMID: 11000341. Exclusion Code: X20.11000341
357 Kurland ES, Cosman F, McMahon DJ, . Parathyroid hormone as a therapy for idiopathic osteoporosis in men: effects on bone mineral density and bone markers. J Clin Endocrinol Metab. 2000 Sep;85(9):3069-76. doi: 10.1210/jcem.85.9.6818. PMID: 10999788. Exclusion Code: X3.10999788
358 Kuruvilla K, Kenny AM, Raisz LG, . Importance of bone mineral density measurements in evaluating fragility bone fracture risk in Asian Indian men. Osteoporos Int. 2011 Jan;22(1):217-21. doi: 10.1007/s00198-010-1237-y [doi]. PMID: 20445964. Exclusion Code: X9.20445964
359 Lacroix AZ, Buist DS, Brenneman SK, . Evaluation of three population-based strategies for fracture prevention: results of the osteoporosis population-based risk assessment (OPRA) trial. Med Care. 2005 Mar;43(3):293-302. PMID: 15725986. Exclusion Code: X8.15725986
360 LaFleur J, Nelson RE, Yao Y, . Validated risk rule using computerized data to identify males at high risk for fracture. Osteoporos Int. 2012 Mar;23(3):1017-27. doi: 10.1007/s00198-011-1646-6 [doi]. PMID: 21562876. Exclusion Code: X14.21562876
361 LaFleur J, Steenhoek CL, Horne J, . Comparing fracture absolute risk assessment (FARA) tools: an osteoporosis clinical informatics tool to improve identification and care of men at high risk of first fracture. Ann Pharmacother. 2015 May;49(5):506-14. doi: 10.1177/1060028015572819. PMID: 25712443. Exclusion Code: X9.25712443
362 Lalmohamed A, Welsing PM, Lems WF, . Calibration of FRAX (R) 3.1 to the Dutch population with data on the epidemiology of hip fractures. Osteoporos Int. 2012 Mar;23(3):861-9. doi: 10.1007/s00198-011-1852-2 [doi]. PMID: 22120910. Exclusion Code: X9.22120910
363 Landfeldt E, Lang A, Robbins S, . Gastrointestinal tolerability and patterns of switching in patients treated for primary osteoporosis: the Swedish Adherence Register Analysis (SARA). Calcif Tissue Int. 2011 Sep;89(3):234-45. doi: 10.1007/s00223-011-9511-3 [doi]. PMID: 21695544. Exclusion Code: X8.21695544
364 Langdahl BL, Teglbjaerg CS, Ho PR, . A 24-month study evaluating the efficacy and safety of denosumab for the treatment of men with low bone mineral density: results from the ADAMO trial. J Clin Endocrinol Metab. 2015 Apr;100(4):1335-42. doi: 10.1210/jc.2014-4079 [doi]. PMID: 25607608. Exclusion Code: X4.25607608
365 Langdahl BL, Teglbjærg CS, Ho PR, . A 24-month study evaluating the efficacy and safety of denosumab for the treatment of men with low bone mineral density: Results from the ADAMO trial. J Clin Endocrinol Metab. 2015;100(4):1335-42. Exclusion Code: X4.25607608
366 Lapi F, Cipriani F, Caputi AP, . Assessing the risk of osteonecrosis of the jaw due to bisphosphonate therapy in the secondary prevention of osteoporotic fractures. Osteoporos Int. 2013 Feb;24(2):697-705. doi: 10.1007/s00198-012-2013-y [doi]. PMID: 22618266. Exclusion Code: X3.22618266
367 Lasco A, Catalano A, Morabito N, . Adrenaleffects of teriparatide in the treatment of severe postmenopausal osteoporosis. Osteoporos Int. 2011 Jan;22(1):299-303. doi: 10.1007/s00198-010-1222-5 [doi]. PMID: 20309523. Exclusion Code: X20.20309523
368 Lee S, Yin RV, Hirpara H, . Increased risk for atypical fractures associated with bisphosphonate use. Fam Pract. 2015 Jun;32(3):276-81. doi: 10.1093/fampra/cmu088. PMID: 25846215. Exclusion Code: X4.25846215
369 Lee SH, Cho EH, Ahn SH, . Prediction of Future Osteoporotic Fracture Occurrence by Genetic Profiling: A 6-Year Follow-Up Observational Study. J Clin Endocrinol Metab. 2016 Mar;101(3):1215-24. doi: 10.1210/jc.2015-3972 [doi]. PMID: 26756118. Exclusion Code: X3.26756118
370 Leeangkoonsathian E, Boonyanuruk P, Pongchaiyakul C, . Validate of clinical risk index for osteoporosis in Thai women at Phramongkutklao Hospital. J Med Assoc Thai. 2012 Apr;95(4):487-92. PMID: 22612000. Exclusion Code: X5.22612000
371 Leib E, Winzenrieth R, Lamy O, . Comparing bone microarchitecture by trabecular bone score (TBS) in Caucasian American women with and without osteoporotic fractures. Calcif Tissue Int. 2014 Sep;95(3):201-8. doi: 10.1007/s00223-014-9882-3 [doi]. PMID: 24948332. Exclusion Code: X4.24948332
372 Lekamwasam S. Sri Lankan FRAX model and country-specific intervention thresholds. Arch Osteoporos. 2013;8:148. doi: 10.1007/s11657-013-0148-x [doi]. PMID: 23975235. Exclusion Code: X9.23975235
373 Lenart BA, Lorich DG, Lane JM. Atypical fractures of the femoral diaphysis in postmenopausal women taking alendronate. N Engl J Med. 2008 Mar 20;358(12):1304-6. doi: 10.1056/NEJMc0707493. PMID: 18354114. Exclusion Code: X8.18354114
374 Lerttrakul S, Soontrapa S. Modified OSTA index for referring women for DEXA measurement. J Med Assoc Thai. 2005 Oct;88 Suppl 5:S80-3. PMID: 16871660. Exclusion Code: X15.16871660
375 Leslie W, Majumdar S, Morin S, . Change in Bone Mineral Density is an Indicator of Treatment-Related Antifracture Effect in Routine Clinical Practice: A Registry-Based Cohort Study. Ann Intern Med. 2016;in press. Exclusion Code: X3.
376 Leslie WD, Berger C, Langsetmo L, . Construction and validation of a simplified fracture risk assessment tool for Canadian women and men: results from the CaMos and Manitoba cohorts. Osteoporos Int. 2011 Jun;22(6):1873-83. doi: 10.1007/s00198-010-1445-5 [doi]. PMID: 20967422. Exclusion Code: X9.20967422
377 Leslie WD, Lix LM. Effects of FRAX((R)) model calibration on intervention rates: a simulation study. J Clin Densitom. 2011 Jul-Sep;14(3):272-8. doi: 10.1016/j.jocd.2011.03.007. PMID: 21723769. Exclusion Code: X9.21723769
378 Leslie WD, Lix LM, Johansson H, . Does osteoporosis therapy invalidate FRAX for fracture prediction?. J Bone Miner Res. 2012 Jun;27(6):1243-51. doi: 10.1002/jbmr.1582 [doi]. PMID: 22392538. Exclusion Code: X9.22392538
379 Leslie WD, Lix LM, Langsetmo L, . Construction of a FRAX(R) model for the assessment of fracture probability in Canada and implications for treatment. Osteoporos Int. 2011 Mar;22(3):817-27. doi: 10.1007/s00198-010-1464-2 [doi]. PMID: 21161509. Exclusion Code: X9.21161509
380 Leslie WD, Lix LM, Wu X. Competing mortality and fracture risk assessment. Osteoporos Int. 2013 Feb;24(2):681-8. doi: 10.1007/s00198-012-2051-5 [doi]. PMID: 22736068. Exclusion Code: X9.22736068
381 Leslie WD, Majumdar SR, Lix LM, . High fracture probability with FRAX usually indicates densitometric osteoporosis: implications for clinical practice. Osteoporos Int. 2012 Jan;23(1):391-7. doi: 10.1007/s00198-011-1592-3 [doi]. PMID: 21365460. Exclusion Code: X7.21365460
382 Leslie WD, Metge C, Salamon EA, . Bone mineral density testing in healthy postmenopausal women. The role of clinical risk factor assessment in determining fracture risk. J Clin Densitom. 2002 Summer;5(2):117-30. PMID: 12110755. Exclusion Code: X9.12110755
383 Leslie WD, Morin S. Fracture burden in relation to low bone mineral density and FRAX((R)) probability. J Clin Densitom. 2011 Jul-Sep;14(3):279-85. doi: 10.1016/j.jocd.2011.04.010. PMID: 21723761. Exclusion Code: X9.21723761
384 Leslie WD, Siminoski K, Brown JP. Comparative effects of densitometric and absolute fracture risk classification systems on projected intervention rates in postmenopausal women. J Clin Densitom. 2007 Apr-Jun;10(2):124-31. doi: 10.1016/j.jocd.2007.01.003. PMID: 17485029. Exclusion Code: X9.17485029
385 Leslie WD, Tsang JF, Lix LM. Validation of ten-year fracture risk prediction: a clinical cohort study from the Manitoba Bone Density Program. Bone. 2008 Oct;43(4):667-71. doi: 10.1016/j.bone.2008.06.001. PMID: 18602504. Exclusion Code: X9.18602504
386 Leslie WD, Tsang JF, Lix LM. Simplified system for absolute fracture risk assessment: clinical validation in Canadian women. J Bone Miner Res. 2009 Feb;24(2):353-60. doi: 10.1359/jbmr.081012 [doi]. PMID: 19514851. Exclusion Code: X9.19514851
387 Levy BT, Hartz A, Woodworth G, . Interventions to improving osteoporosis screening: an Iowa Research Network (IRENE) study. In J Am Board Fam Med Exclusion Code: X7.
388 Li GW, Chang SX, Xu Z, . Prediction of hip osteoporotic fractures from composite indices of femoral neck strength. Skeletal Radiol. 2013 Feb;42(2):195-201. doi: 10.1007/s00256-012-1473-7 [doi]. PMID: 22714125. Exclusion Code: X7.22714125
389 Li W, Kornak J, Harris TB, . Bone fracture risk estimation based on image similarity. Bone. 2009 Sep;45(3):560-7. doi: 10.1016/j.bone.2009.04.250. PMID: 19414074. Exclusion Code: X7.19414074
390 Licks R, Licks V, Ourique F, . Development of a prediction tool for low bone mass based on clinical data and periapical radiography. Dentomaxillofac Radiol. 2010 May;39(4):224-30. doi: 10.1259/dmfr/23760876. PMID: 20395463. Exclusion Code: X14.20395463
391 Lillholm M, Ghosh A, Pettersen PC, . Vertebral fracture risk (VFR) score for fracture prediction in postmenopausal women. Osteoporos Int. 2011 Jul;22(7):2119-28. doi: 10.1007/s00198-010-1436-6 [doi]. PMID: 21069295. Exclusion Code: X12.21069295
392 Lin TC, Lee CH, Yang CY, . Incidence and risk of venous thromboembolism among Taiwan osteoporotic fracture population under osteoporosis pharmacological treatments. J Clin Endocrinol Metab. 2014 May;99(5):1599-607. doi: 10.1210/jc.2013-3114 [doi]. PMID: 24606074. Exclusion Code: X5.24606074
393 Lippuner K, Johansson H, Kanis JA, . Remaining lifetime and absolute 10-year probabilities of osteoporotic fracture in Swiss men and women. Osteoporos Int. 2009 Jul;20(7):1131-40. doi: 10.1007/s00198-008-0779-8 [doi]. PMID: 18974918. Exclusion Code: X11.18974918
394 Lippuner K, Roux C, Bone HG, . Denosumab treatment of postmenopausal women with osteoporosis for 7 years: Clinical fracture results from the first 4 years of the FREEDOM extension. Osteoporos Int. 2013;24(Suppl 1):S39-40. Exclusion Code: X8.
395 Liu JL, Zhu HM, Huang QR, . Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serumlipids in Chinese postmenopausal women with osteoporosis: a multi-center, randomized, placebo-controlled clinical trial. Chin Med J (Engl). 2004 Jul;117(7):1029-35. PMID: 15265377. Exclusion Code: X5.15265377
396 Liu JM, Ma LY, Bi YF, . A population-based study examining calcaneus quantitative ultrasound and its optimal cut-points to discriminate osteoporotic fractures among 9352 Chinese women and men. J Clin Endocrinol Metab. 2012 Mar;97(3):800-9. doi: 10.1210/jc.2011-1654. PMID: 22170722. Exclusion Code: X11.22170722
397 Lix LM, Quail J, Teare G, . Performance of comorbidity measures for predicting outcomes in population-based osteoporosis cohorts. Osteoporos Int. 2011 Oct;22(10):2633-43. doi: 10.1007/s00198-010-1516-7 [doi]. PMID: 21305268. Exclusion Code: X7.21305268
398 Ljunggren O, Barrett A, Stoykov I, . Effective osteoporosis treatment with teriparatide is associated with enhanced quality of life in postmenopausal women with osteoporosis: the European Forsteo Observational Study. BMC Musculoskelet Disord. 2013;14:251. doi: 10.1186/1471-2474-14-251. PMID: 23968239. Exclusion Code: X8.23968239
399 Lo JC, O’Ryan FS, Gordon NP, . Prevalence of osteonecrosis of the jaw in patients with oral bisphosphonate exposure. J Oral Maxillofac Surg. 2010 Feb;68(2):243-53. doi: 10.1016/j.joms.2009.03.050. PMID: 19772941. Exclusion Code: X3.19772941
400 Lobo DM, Tritto AC, da Silva LR, . Effects of long-term low-dosedietary creatine supplementation in older women. Exp Gerontol. 2015 Oct;70:97-104. doi: 10.1016/j.exger.2015.07.012. PMID: 26192975. Exclusion Code: X7.26192975
401 Looker AC, Dawson-Hughes B, Tosteson AN, . Hip fracture risk in older US adults by treatment eligibility status based on new National Osteoporosis Foundation guidance. Osteoporos Int. 2011 Feb;22(2):541-9. doi: 10.1007/s00198-010-1288-0 [doi]. PMID: 20480142. Exclusion Code: X9.20480142
402 Lu PY, Hsieh CF, Tsai YW, . Alendronate and raloxifene use related to cardiovascular diseases: differentiation by different dosing regimens of alendronate. Clin Ther. 2011 Sep;33(9):1173-9. doi: 10.1016/j.clinthera.2011.07.012. PMID: 21849210. Exclusion Code: X8.21849210
403 Lufkin EG, Whitaker MD, Nickelsen T, . Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial. J Bone Miner Res. 1998 Nov;13(11):1747-54. doi: 10.1359/jbmr.1998.13.11.1747. PMID: 9797484. Exclusion Code: X2.9797484
404 Lundin H, Saaf M, Strender LE, . One-leg standing time and hip-fracture prediction. Osteoporos Int. 2014 Apr;25(4):1305-11. doi: 10.1007/s00198-013-2593-1 [doi]. PMID: 24562837. Exclusion Code: X7.24562837
405 Lydick E, Cook K, Turpin J, . Development and validation of a simple questionnaire to facilitate identification of women likely to have low bone density. Am J Manag Care. 1998 Jan;4(1):37-48. PMID: 10179905. Exclusion Code: X9.10179905
406 Lyles KW, Colon-Emeric CS, Magaziner JS, . Zoledronic acid and clinical fractures and mortality after hip fracture. N Engl J Med. 2007 Nov 1;357(18):1799-809. doi: 10.1056/NEJMoa074941. PMID: 17878149. Exclusion Code: X3.17878149
407 Maatta M, Moilanen P, Timonen J, . Association between low-frequency ultrasound and hip fractures -- comparison with DXA-based BMD. BMC Musculoskelet Disord. 2014;15:208. doi: 10.1186/1471-2474-15-208. PMID: 24934318. Exclusion Code: X7.24934318
408 Mackey DC, Black DM, Bauer DC, . Effects of antiresorptive treatment on nonvertebral fracture outcomes. J Bone Miner Res. 2011 Oct;26(10):2411-8. doi: 10.1002/jbmr.446 [doi]. PMID: 21710615. Exclusion Code: X7.21710615
409 MacLean C, Newberry S, Maglione M, . Systematic review: comparative effectiveness of treatments to prevent fractures in men and women with low bone density or osteoporosis. Ann Intern Med. 2008 Feb 5;148(3):197-213. PMID: 18087050. Exclusion Code: X16.18087050
410 MacNeil JA, Adachi JD, Goltzman D, . Predicting fracture using 2D finite element modelling. Med Eng Phys. 2012 May;34(4):478-84. doi: 10.1016/j.medengphy.2011.08.008. PMID: 21959170. Exclusion Code: X7.21959170
411 Malluche HH, Davenport DL, Cantor T, . Bone mineral density and serum biochemical predictors of bone loss in patients with CKD on dialysis. Clin J Am Soc Nephrol. 2014 Jul;9(7):1254-62. doi: 10.2215/CJN.09470913. PMID: 24948144. Exclusion Code: X3.24948144
412 Marques A, Mota A, Canhao H, . A FRAX model for the estimation of osteoporotic fracture probability in Portugal. Acta Reumatol Port. 2013 Apr-Jun;38(2):104-12. PMID: 24141347. Exclusion Code: X9.24141347
413 Martino S, Cauley JA, Barrett-Connor E, . Continuing outcomes relevant to Evista: breast cancer incidence in postmenopausal osteoporotic women in a randomized trial of raloxifene. J Natl Cancer Inst. 2004 Dec 1;96(23):1751-61. doi: 10.1093/jnci/djh319. PMID: 15572757. Exclusion Code: X8.15572757
414 Mather J, MacDermid JC, Faber KJ, . Proximal humerus cortical bone thickness correlates with bone mineral density and can clinically rule out osteoporosis. J Shoulder Elbow Surg. 2013 Jun;22(6):732-8. doi: 10.1016/j.jse.2012.08.018. PMID: 23183030. Exclusion Code: X7.23183030
415 Maurer P, Sandulescu T, Kriwalsky MS, . Bisphosphonate-related osteonecrosis of the maxilla and sinusitis maxillaris. Int J Oral Maxillofac Surg. 2011 Mar;40(3):285-91. doi: 10.1016/j.ijom.2010.11.006. PMID: 21163624. Exclusion Code: X4.21163624
416 McAuliffe JA. Isolated diaphyseal fractures of the ulna. J Hand Surg Am. 2012 Jan;37(1):145-7. doi: 10.1016/j.jhsa.2011.05.005. PMID: 21658858. Exclusion Code: X2.21658858
417 McCloskey EV, Johansson H, Oden A, . Ten-year fracture probability identifies women who will benefit from clodronate therapy--additional results from a double-blind, placebo-controlled randomised study. Osteoporos Int. 2009 May;20(5):811-7. doi: 10.1007/s00198-008-0786-9 [doi]. PMID: 19002369. Exclusion Code: X7.19002369
418 McCloskey EV, Oden A, Harvey NC, . Adjusting fracture probability by trabecular bone score. Calcif Tissue Int. 2015 Jun;96(6):500-9. doi: 10.1007/s00223-015-9980-x [doi]. PMID: 25796374. Exclusion Code: X9.25796374
419 McClung MR, Grauer A, Boonen S, . Romosozumab in postmenopausal women with low bone mineral density. N Engl J Med. 2014 Jan 30;370(5):412-20. doi: 10.1056/NEJMoa1305224 [doi]. PMID: 24382002. Exclusion Code: X7.24382002
420 McClung MR, Lewiecki EM, Geller ML, . Effect of denosumab on bone mineral density and biochemical markers of bone turnover: 8-year results of a phase 2 clinical trial. Osteoporos Int. 2013 Jan;24(1):227-35. doi: 10.1007/s00198-012-2052-4 [doi]. PMID: 22776860. Exclusion Code: X8.22776860
421 McGowan B, Kanis JA, Johansson H, . Development and application of FRAX in the management of osteoporosis in Ireland. Arch Osteoporos. 2013;8:146. doi: 10.1007/s11657-013-0146-z [doi]. PMID: 23982943. Exclusion Code: X9.23982943
422 McGrother CW, Donaldson MM, Clayton D, . Evaluation of a hip fracture risk score for assessing elderly women: the Melton Osteoporotic Fracture (MOF) study. Osteoporos Int. 2002 Jan;13(1):89-96. doi: 10.1007/s198-002-8343-6 [doi]. PMID: 11883411. Exclusion Code: X14.11883411
423 Melton LJ 3rd, Atkinson EJ, Khosla S, . Evaluation of a prediction model for long-term fracture risk. J Bone Miner Res. 2005 Apr;20(4):551-6. doi: 10.1359/JBMR.041206 [doi]. PMID: 15765172. Exclusion Code: X20.15765172
424 Melton LJ 3rd, Atkinson EJ, O’Fallon WM, . Long-term fracture prediction by bone mineral assessed at different skeletal sites. J Bone Miner Res. 1993 Oct;8(10):1227-33. doi: 10.1002/jbmr.5650081010. PMID: 8256660. Exclusion Code: X9.8256660
425 Melton LJ 3rd, Beck TJ, Amin S, . Contributions of bone density and structure to fracture risk assessment in men and women. Osteoporos Int. 2005 May;16(5):460-7. doi: 10.1007/s00198-004-1820-1 [doi]. PMID: 15688123. Exclusion Code: X7.15688123
426 Melton LJ 3rd, Christen D, Riggs BL, . Assessing forearm fracture risk in postmenopausal women. Osteoporos Int. 2010 Jul;21(7):1161-9. doi: 10.1007/s00198-009-1047-2 [doi]. PMID: 19714390. Exclusion Code: X7.19714390
427 Melton LJ 3rd, Looker AC, Shepherd JA, . Osteoporosis assessment by whole body region vs. site-specific DXA. Osteoporos Int. 2005 Dec;16(12):1558-64. doi: 10.1007/s00198-005-1871-y [doi]. PMID: 15812599. Exclusion Code: X9.15812599
428 Meszaros S, Toth E, Ferencz V, . Calcaneous quantitative ultrasound measurements predicts vertebral fractures in idiopathic male osteoporosis. Joint Bone Spine. 2007 Jan;74(1):79-84. doi: 10.1016/j.jbspin.2006.04.008. PMID: 17197223. Exclusion Code: X11.17197223
429 Michaelsson K, Bergstrom R, Mallmin H, . Screening for osteopenia and osteoporosis: selection by body composition. Osteoporos Int. 1996;6(2):120-6. PMID: 8704349. Exclusion Code: X9.8704349
430 Michalska D, Stepan JJ, Basson BR, . The effect of raloxifene after discontinuation of long-term alendronate treatment of postmenopausal osteoporosis. J Clin Endocrinol Metab. 2006 Mar;91(3):870-7. doi: 10.1210/jc.2004-2212. PMID: 16352692. Exclusion Code: X8.16352692
431 Migliore A, Broccoli S, Massafra U, . Ranking antireabsorptive agents to prevent vertebral fractures in postmenopausal osteoporosis by mixed treatment comparison meta-analysis. Eur Rev Med Pharmacol Sci. 2013 Mar;17(5):658-67. PMID: 23543450. Exclusion Code: X8.23543450
432 Milgrom C, Finestone A, Novack V, . The effect of prophylactic treatment with risedronate on stress fracture incidence among infantry recruits. Bone. 2004 Aug;35(2):418-24. doi: 10.1016/j.bone.2004.04.016. PMID: 15268892. Exclusion Code: X3.15268892
433 Miller PD, Barlas S, Brenneman SK, . An approach to identifying osteopenic women at increased short-term risk of fracture. Arch Intern Med. 2004 May 24;164(10):1113-20. doi: 10.1001/archinte.164.10.1113. PMID: 15159269. Exclusion Code: X9.15159269
434 Miller PD, Bilezikian JP, Diaz-Curiel M, . Occurrence of hypercalciuria in patients with osteoporosis treated with teriparatide. J Clin Endocrinol Metab. 2007 Sep;92(9):3535-41. doi: 10.1210/jc.2006-2439. PMID: 17609307. Exclusion Code: X7.17609307
435 Miller PD, Bolognese MA, Lewiecki EM, . Effect of denosumab on bone density and turnover in postmenopausal women with low bone mass after long-term continued, discontinued, and restarting of therapy: a randomized blinded phase 2 clinical trial. Bone. 2008 Aug;43(2):222-9. doi: 10.1016/j.bone.2008.04.007. PMID: 18539106. Exclusion Code: X7.18539106
436 Miller PD, Hattersley G, Riis BJ, . Effect of abaloparatide vs placebo on new vertebral fractures in postmenopausal women with osteoporosis: a randomized clinical trial. JAMA. 2016 Aug 16;316(7):722-33. doi: 10.1001/jama.2016.11136. PMID: 27533157. Exclusion Code: X7.27533157
437 Miller PD, Recker RR, Harris S, . Long-term fracture rates seen with continued ibandronate treatment: Pooled analysis of DIVA and MOBILE long-term extension studies. Osteoporos Int. 2014;25(1):349-57. Exclusion Code: X4.24136103
438 Miller PD, Recker RR, Reginster JY, . Efficacy of monthly oralibandronate is sustained over 5 years: the MOBILE long-term extension study. Osteoporos Int. 2012 Jun;23(6):1747-56. doi: 10.1007/s00198-011-1773-0 [doi]. PMID: 21953471. Exclusion Code: X8.21953471
439 Miller PD, Siris ES, Barrett-Connor E, . Prediction of fracture risk in postmenopausal white women with peripheral bone densitometry: evidence from the National Osteoporosis Risk Assessment. J Bone Miner Res. 2002 Dec;17(12):2222-30. doi: 10.1359/jbmr.2002.17.12.2222 [doi]. PMID: 12469916. Exclusion Code: X20.12469916
440 Miller PD, Wagman RB, Peacock M, . Effect of denosumab on bone mineral density and biochemical markers of bone turnover: six-year results of a phase 2 clinical trial. J Clin Endocrinol Metab. 2011 Feb;96(2):394-402. doi: 10.1210/jc.2010-1805. PMID: 21159841. Exclusion Code: X8.21159841
441 Minematsu A, Hazaki K, Harano A, . A screening model for low bone mass in elderly Japanese men using quantitative ultrasound measurements: Fujiwara-Kyo Study. J Clin Densitom. 2012 Jul-Sep;15(3):343-50. doi: 10.1016/j.jocd.2012.02.001. PMID: 22677197. Exclusion Code: X13.22677197
442 Mirkin S, Komm BS, Pan K, . Effects of bazedoxifene/conjugated estrogens on endometrial safety and bone in postmenopausal women. Climacteric. 2013 Jun;16(3):338-46. doi: 10.3109/13697137.2012.717994 [doi]. PMID: 23038989. Exclusion Code: X3.23038989
443 Miyakoshi N, Aizawa T, Sasaki S, . Healing of bisphosphonate-associated atypical femoral fractures in patients with osteoporosis: a comparison between treatment with and without teriparatide. J Bone Miner Metab. 2015 Sep;33(5):553-9. doi: 10.1007/s00774-014-0617-3 [doi]. PMID: 25227287. Exclusion Code: X9.25227287
444 Miyauchi A, Matsumoto T, Sugimoto T, . Effects of teriparatide on bone mineral density and bone turnover markers in Japanese subjects with osteoporosis at high risk of fracture in a 24-month clinical study: 12-month, randomized, placebo-controlled, double-blind and 12-month open-label phases. Bone. 2010 Sep;47(3):493-502. doi: 10.1016/j.bone.2010.05.022. PMID: 20580870. Exclusion Code: X3.20580870
445 Mizunuma H, Taketani Y, Ohta H, . Dose effects of oral estradiol on bone mineral density in Japanese women with osteoporosis. Climacteric. 2010 Feb;13(1):72-83. 10.3109/13697130902926910 [doi]. PMID: 19591010. Exclusion Code: X9.19591010
446 Moayyeri A, Adams JE, Adler RA, . Quantitative ultrasound of the heel and fracture risk assessment: an updated meta-analysis. Osteoporos Int. 2012 Jan;23(1):143-53. doi: 10.1007/s00198-011-1817-5 [doi]. PMID: 22037972. Exclusion Code: X9.22037972
447 Moilanen P, Maatta M, Kilappa V, . Discrimination of fractures by low-frequency axial transmission ultrasound in postmenopausal females. Osteoporos Int. 2013 Feb;24(2):723-30. doi: 10.1007/s00198-012-2022-x [doi]. PMID: 22638711. Exclusion Code: X11.22638711
448 Moricke R, Rettig K, Bethke TD. Use of recombinant human parathyroid hormone(1-84) in patients with postmenopausal osteoporosis: a prospective, open-label, single-arm, multicentre, observational cohort study of the effects of treatment on quality of life and pain--the PROPOSE study. Clin Drug Investig. 2011;31(2):87-99. doi: 10.2165/11538880-000000000-00000. PMID: 21155613. Exclusion Code: X8.21155613
449 Mosca L, Grady D, Barrett-Connor E, . Effect of raloxifene on stroke and venous thromboembolism according to subgroups in postmenopausal women at increased risk of coronary heart disease. Stroke. 2009 Jan;40(1):147-55. doi: 10.1161/strokeaha.108.518621. PMID: 18948611. Exclusion Code: X3.18948611
450 Mrgan M, Mohammed A, Gram J. Combined vertebral assessment and bone densitometry increases the prevalence and severity of osteoporosis in patients referred to DXA scanning. J Clin Densitom. 2013 Oct-Dec;16(4):549-53. doi: 10.1016/j.jocd.2013.05.002. PMID: 23769657. Exclusion Code: X3.23769657
451 Mueller DK, Kuts cherenko A, Bartel H, . Phantom-less QCT BMD system as screening tool for osteoporosis without additional radiation. Eur J Radiol. 2011 Sep;79(3):375-81. doi: 10.1016/j.ejrad.2010.02.008. PMID: 20223609. Exclusion Code: X9.20223609
452 Muftic M, Selimovic EK, Miladinovic K. Osteoporosis--comparative study between quantitative ultrasound of calcaneus and DXA. Med Arch. 2013;67(4):289-91. Exclusion Code: X15.24520757
453 Murphy MG, Weiss S, McClung M, . Effect of alendronate and MK-677 (a growth hormone secretagogue), individually and in combination, on markers of bone turnover and bone mineral density in postmenopausal osteoporotic women. J Clin Endocrinol Metab. 2001 Mar;86(3):1116-25. doi: 10.1210/jcem.86.3.7294. PMID: 11238495. Exclusion Code: X20.11238495
454 Murray AW, McQuillan C, Kennon B, . Osteoporosis risk assessment and treatment intervention after hip or shoulder fracture. A comparison of two centres in the United Kingdom. Injury. 2005 Sep;36(9):1080-4. doi: 10.1016/j.injury.2005.03.012. PMID: 16051239. Exclusion Code: X3.16051239
455 Muschitz C, Dimai HP, Kocijan R, . The discriminatory capacity of BMD measurements by DXA and dual X-ray and laser (DXL) at the calcaneus including clinical risk factors for detecting patients with vertebral fractures. Osteoporos Int. 2013 Aug;24(8):2181-90. doi: 10.1007/s00198-013-2266-0 [doi]. PMID: 23344258. Exclusion Code: X11.23344258
456 Nakamura T, Matsumoto T, Sugimoto T, . Evaluation of efficacy and safety of denosumab in Japanese postmenopausal women with osteoporosis-phase II (dose response) study. In Osteoporos Int Exclusion Code: X2.
457 Nakamura T, Sugimoto T, Nakano T, . Randomized Teriparatide [human parathyroid hormone (PTH) 1-34] Once-Weekly Efficacy Research (TOWER) trial for examining the reduction in new vertebral fractures in subjects with primary osteoporosis and high fracture risk. J Clin Endocrinol Metab. 2012 Sep;97(9):3097-106. doi: 10.1210/jc.2011-3479. PMID: 22723322. Exclusion Code: X3.22723322
458 Nakamura T, Tsujimoto M, Hamaya E, . Consistency of fracture risk reduction in Japanese and Caucasian osteoporosis patients treated with teriparatide: a meta-analysis. J Bone Miner Metab. 2012 May;30(3):321-5. doi: 10.1007/s00774-011-0313-5 [doi]. PMID: 21938382. Exclusion Code: X3.21938382
459 Nakatoh S, Takemaru Y. Application of the fracture risk assessment tool (FRAX((R))) and determination of suitable cut-off values during primary screening in specific health check-ups in Japan. J Bone Miner Metab. 2013 Nov;31(6):674-80. doi: 10.1007/s00774-013-0457-6 [doi]. PMID: 23543192. Exclusion Code: X9.23543192
460 Nasser EJ, Iglesias ER, Ferreira JA, . Association of breast vascular calcifications with low bone mass in postmenopausal women. Climacteric. 2014 Aug;17(4):486-91. doi: 10.3109/13697137.2013.869672 [doi]. PMID: 24286614. Exclusion Code: X8.24286614
461 Nasser KM, Quinonez Obiols A, Silverman SL. Identifying individuals at risk for fracture in Guatemala. PLoS One. 2011;6(11):e28042. doi: 10.1371/journal.pone.0028042. PMID: 22140503. Exclusion Code: X15.22140503
462 Navarro Mdel C, Saavedra P, Gomez-de-Tejada MJ, . Discriminative ability of heel quantitative ultrasound in postmenopausal women with prevalent low-trauma fractures: application of optimal threshold cutoff values using CART models. J Clin Densitom. 2011 Oct-Dec;14(4):492-8. doi: 10.1016/j.jocd.2011.06.008. PMID: 22051094. Exclusion Code: X3.22051094
463 Navarro Mdel C, Saavedra P, Gomez-de-Tejada MJ, . Discriminative ability of heel quantitative ultrasound in postmenopausal women with prevalent vertebral fractures: application of optimal threshold cutoff values using classification and regression tree models. Calcif Tissue Int. 2012 Aug;91(2):114-20. doi: 10.1007/s00223-012-9616-3 [doi]. PMID: 22752617. Exclusion Code: X3.22752617
464 Nayak S, Edwards DL, Saleh AA, . Performance of risk assessment instruments for predicting osteoporotic fracture risk: a systematic review. Osteoporos Int. 2014 Jan;25(1):23-49. doi: 10.1007/s00198-013-2504-5. PMID: 24105431. Exclusion Code: X17.24105431
465 Nayak S, Roberts MS, Greenspan SL. Cost-effectiveness of different screening strategies for osteoporosis in postmenopausal women. Ann Intern Med. 2011 Dec 6;155(11):751-61. doi: 10.7326/0003-4819-155-11-201112060-00007. PMID: 22147714. Exclusion Code: X9.22147714
466 Naylor KE, Clowes JA, Finigan J, . The effect of cessation of raloxifene treatment on bone turnover in postmenopausal women. Bone. 2010 Mar;46(3):592-7. doi: 10.1016/j.bone.2009.10.043. PMID: 19897063. Exclusion Code: X3.19897063
467 Naylor KL, Leslie WD, Hodsman AB, . FRAX predicts fracture risk in kidney transplantrecipients. Transplantation. 2014 May 15;97(9):940-5. doi: 10.1097/01.TP.0000438200.84154.1a [doi]. PMID: 24503761. Exclusion Code: X8.24503761
468 Neer RM, Arnaud CD, Zanchetta JR, . Effect of parathyroid hormone (1-34) on fractures and bone mineral density in postmenopausal women with osteoporosis. N Engl J Med. 2001 May 10;344(19):1434-41. doi: 10.1056/nejm200105103441904. PMID: 11346808. Exclusion Code: X3.11346808
469 Nevitt MC, Chen P, Dore RK, . Reduced risk of back pain following teriparatide treatment: a meta-analysis. Osteoporos Int. 2006 Feb;17(2):273-80. doi: 10.1007/s00198-005-2013-2 [doi]. PMID: 16142502. Exclusion Code: X9.16142502
470 Nguyen ND, Frost SA, Center JR, . Development of a nomogram for individualizing hip fracture risk in men and women. Osteoporos Int. 2007 Aug;18(8):1109-17. doi: 10.1007/s00198-007-0362-8 [doi]. PMID: 17370100. Exclusion Code: X14.17370100
471 Nguyen ND, Frost SA, Center JR, . Development of prognostic nomograms for individualizing 5-year and 10-year fracture risks. Osteoporos Int. 2008 Oct;19(10):1431-44. doi: 10.1007/s00198-008-0588-0. PMID: 18324342. Exclusion Code: X14.18324342
472 Nguyen ND, Pongchaiyakul C, Center JR, . Abdominal fat and hip fracture risk in the elderly: the Dubbo Osteoporosis Epidemiology Study. BMC Musculoskelet Disord. 2005;6:11. doi: 10.1186/1471-2474-6-11. PMID: 15727686. Exclusion Code: X7.15727686
473 Nguyen TV, Center JR, Eisman JA. Femoral neck bone loss predicts fracture risk independent of baseline BMD. J Bone Miner Res. 2005 Jul;20(7):1195-201. doi: 10.1359/JBMR.050215 [doi]. PMID: 15940372. Exclusion Code: X9.15940372
474 Nishiyama KK, Macdonald HM, Hanley DA, . Women with previous fragility fractures can be classified based on bone microarchitecture and finite element analysis measured with HR-pQCT. Osteoporos Int. 2013 May;24(5):1733-40. doi: 10.1007/s00198-012-2160-1 [doi]. PMID: 23179565. Exclusion Code: X3.23179565
475 Noale M, Maggi S, Gonnelli S, . Quantitative ultrasound criteria for risk stratification in clinical practice: a comparative assessment. Ultrasound Med Biol. 2012 Jul;38(7):1138-44. doi: 10.1016/j.ultrasmedbio.2012.02.022. PMID: 22542263. Exclusion Code: X7.22542263
476 Odvina CV, Zerwekh JE, Rao DS, . Severely suppressed bone turnover: a potential complication of alendronate therapy. J Clin Endocrinol Metab. 2005 Mar;90(3):1294-301. doi: 10.1210/jc.2004-0952. PMID: 15598694. Exclusion Code: X8.15598694
477 Office of Drug Safety. ODS Postmarketing Safety Review. Rockville, MD: U.S. Food and Drug Administration; 2004. www.fda.gov/ohrms/dockets/ac/05/briefing/2005-4095B2_03_04-FDA-TAB3.pdf. Accessed on September 13 2016. Exclusion Code: X3.
478 Okabe S, Morimoto Y, Ansai T, . Assessment of the relationship between the mandibular cortex on panoramic radiographs and the risk of bone fracture and vascular disease in 80-year-olds. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2008 Sep;106(3):433-42. doi: 10.1016/j.tripleo.2007.09.013. PMID: 18299222. Exclusion Code: X9.18299222
479 Ollivier M, Le Corroller T, Blanc G, . Radiographic bone texture analysis is correlated with 3D microarchitecture in the femoral head, and improves the estimation of the femoral neck fracture risk when combined with bone mineral density. Eur J Radiol. 2013 Sep;82(9):1494-8. doi: 10.1016/j.ejrad.2013.04.042. PMID: 23756323. Exclusion Code: X11.23756323
480 Olszynski WP, Adachi JD, Hanley DA, . Comparison of Speed of Sound Measures Assessed by Multisite Quantitative Ultrasound to Bone Mineral Density Measures Assessed by Dual-Energy X-Ray Absorptiometry in a Large Canadian Cohort: the Canadian Multicentre Osteoporosis Study (CaMos). J Clin Densitom. 2016 Apr-Jun;19(2):234-41. doi: 10.1016/j.jocd.2015.04.004. PMID: 26050876. Exclusion Code: X9.26050876
481 Orwoll ES, Binkley NC, Lewiecki EM, . Efficacy and safety of monthly ibandronate in men with low bone density. Bone. 2010 Apr;46(4):970-6. doi: 10.1016/j.bone.2009.12.034. PMID: 20060082. Exclusion Code: X3.20060082
482 Oswald AJ, Berg J, Milne G, . Teriparatide treatment of severe osteoporosis reduces the risk of vertebral fractures compared with standard care in routine clinical practice. Calcif Tissue Int. 2014 Feb;94(2):176-82. doi: 10.1007/s00223-013-9788-5 [doi]. PMID: 24026567. Exclusion Code: X8.24026567
483 Oyen J, Gjesdal CG, Brudvik C, . Low-energy distal radius fractures in middle-aged and elderly men and womenthe burden of osteoporosis and fracture risk: A study of 1794 consecutive patients. Osteoporos Int. 2010 Jul;21(7):1257-67. doi: 10.1007/s00198-009-1068-x [doi]. PMID: 19813045. Exclusion Code: X9.19813045
484 Palacios S, de Villiers TJ, Nardone Fde C, . Assessment of the safety of long-term bazedoxifene treatment on the reproductive tract in postmenopausal women with osteoporosis: results of a 7-year, randomized, placebo-controlled, phase 3 study. Maturitas. 2013 Sep;76(1):81-7. doi: 10.1016/j.maturitas.2013.06.008. PMID: 23871271. Exclusion Code: X7.23871271
485 Palacios S, Farias ML, Luebbert H, . Raloxifene is not associated with biologically relevant changes in hot flushes in postmenopausal women for whom therapy is appropriate. Am J Obstet Gynecol. 2004 Jul;191(1):121-31. doi: 10.1016/j.ajog.2003.10.701. PMID: 15295352. Exclusion Code: X3.15295352
486 Palacios S, Rizzoli R, Zapalowski C, . Denosumab reduced osteoporotic fractures in postmenopausal women with osteoporosis with prior fracture: Results from freedom. Osteoporos Int. 2013;24(Suppl 1):S299-300. Exclusion Code: X8.
487 Palacios S, Silverman SL, de Villiers TJ, . A 7-year randomized, placebo-controlled trial as sessing the long-term efficacy and safety of bazedoxifene in postmenopausal women with osteoporosis: effects on bone density and fracture. Menopause. 2015 Aug;22(8):806-13. doi: 10.1097/GME.0000000000000419 [doi]. PMID: 25668306. Exclusion Code: X9.25668306
488 Palomba S, Manguso F, Orio F, Jr., . Effectiveness of risedronate in osteoporotic postmenopausal women with inflammatory bowel disease: a prospective, parallel, open-label, two-year extension study. Menopause. 2008 Jul-Aug;15(4 Pt 1):730-6. doi: 10.1097/gme.0b013e318159f190. PMID: 18698280. Exclusion Code: X3.18698280
489 Palomba S, Orio F, Jr., Colao A, . Effect of estrogen replacement plus low-dose alendronate treatment on bone density in surgically postmenopausal women with osteoporosis. J Clin Endocrinol Metab. 2002 Apr;87(4):1502-8. doi: 10.1210/jcem.87.4.8323. PMID: 11932272. Exclusion Code: X8.11932272
490 Palomba S, Orio F, Jr., Manguso F, . Efficacy of risedronate administration in osteoporotic postmenopausal women affected by inflammatory bowel disease. Osteoporos Int. 2005 Sep;16(9):1141-9. doi: 10.1007/s00198-005-1927-z. PMID: 15928801. Exclusion Code: X3.15928801
491 Panico A, Lupoli GA, Marciello F, . Teriparatide vs. alendronate as a treatment for osteoporosis: changes in biochemical markers of bone turnover, BMD and quality of life. Med Sci Monit. 2011 Aug;17(8):CR442-8. PMID: 21804463. Exclusion Code: X8.21804463
492 Papaioannou A, Kennedy CC, Freitag A, . Alendronateonce weekly for the prevention and treatment of bone loss in Canadian adult cystic fibrosis patients (CFOS trial). Chest. 2008 Oct;134(4):794-800. doi: 10.1378/chest.08-0608. PMID: 18641106. Exclusion Code: X3.18641106
493 Papapoulos S, Chapurlat R, Libanati C, . Five years of denosumab exposure in women with postmenopausal osteoporosis: results from the first two years of the FREEDOM extension. J Bone Miner Res. 2012 Mar;27(3):694-701. doi: 10.1002/jbmr.1479 [doi]. PMID: 22113951. Exclusion Code: X8.22113951
494 Papapoulos S, Lippuner K, Roux C, . The effect of 8 or 5 years of denosumab treatment in postmenopausal women with osteoporosis: results from the FREEDOM Extension study. In Osteoporos Int Exclusion Code: X8.
495 Papapoulos S, McClung MR, Franchimont N, . Denosumab (DMab) treatment for 6 years maintains low fracture incidence in women (greater-than or equal to) 75 years with postmen opausal osteoporosis (PMO). Osteoporos Int. 2013;24(Suppl):S45-6. Exclusion Code: X8.
496 Papapoulos S, Roux C, Bone HG, . Denosumab treatment in postmenopausal women with osteoporosis for up to 9 years: Results through year 6 of the freedom extension. In Osteoporos Int Exclusion Code: X8.
497 Parker S, Ciaccio M, Cook E, . Validation of a modified FRAX(R) tool for improving outpatient efficiency--part of the “Catch Before a Fall” initiative. Arch Osteoporos. 2015;10:230. doi: 10.1007/s11657-015-0230-7 [doi]. PMID: 26272713. Exclusion Code: X3.26272713
498 Patel DV, Bolland M, Nisa Z, . Incidence of ocular side effects with intravenous zoledronate: secondary analysis of a randomized controlled trial. Osteoporos Int. 2014;26(2):499-503. Exclusion Code: X4.25187119
499 Pazianas M, Blumentals WA, Miller PD. Lack of association between oral bisphosphonates and osteonecrosis using jaw surgery as a surrogate marker. Osteoporos Int. 2008 Jun;19(6):773-9. doi: 10.1007/s00198-007-0547-1. PMID: 17999023. Exclusion Code: X20.17999023
500 Pazianas M, Miller P, Blumentals WA, . A review of the literature on osteonecrosis of the jaw in patients with osteoporosis treated with oral bisphosphonates: prevalence, risk factors, and clinical characteristics. Clin Ther. 2007 Aug;29(8):1548-58. doi: 10.1016/j.clinthera.2007.08.008. PMID: 17919538. Exclusion Code: X4.17919538
501 Pedrazzoni M, Girasole G, Giusti A, . Assessment of the 10-year risk of fracture in Italian postmenopausal women using FRAX(R): a north Italian multicenter study. J Endocrinol Invest. 2011 Dec;34(11):e386-91. PMID: 21750394. Exclusion Code: X8.21750394
502 Penning-van Beest FJ, Erkens JA, Olson M, . Loss of treatment benefit due to low compliance with bisphosphonate therapy. Osteoporos Int. 2008 Apr;19(4):511-7. doi: 10.1007/s00198-007-0466-1 [doi]. PMID: 17874028. Exclusion Code: X8.17874028
503 Pfister AK, Welch CA, Emmett MK, . An approach to identify rural women aged 60 to 64 for osteoporosis treatment. South Med J. 2012 Jan;105(1):11-7. doi: 10.1097/SMJ.0b013e3182e1b57. PMID: 22189661. Exclusion Code: X9.22189661
504 Phillips MB. Risedronate-induced Hepatitis. Am J Med. 2007 Mar;120(3):e1-2. doi: 10.1016/j.amjmed.2006.04.032. PMID: 17349419. Exclusion Code: X2.17349419
505 Pickhardt PJ, Bodeen G, Brett A, . Comparison of femoral neck BMD evaluation obtained using Lunar DXA and QCT with asynchronous calibration from CT colonography. J Clin Densitom. 2015 Jan-Mar;18(1):5-12. doi: 10.1016/j.jocd.2014.03.002. PMID: 24880495. Exclusion Code: X9.24880495
506 Pickhardt PJ, Lee LJ, del Rio AM, . Simultaneous screening for osteoporosis at CT colonography: bone mineral density assessment using MDCT attenuation techniques compared with the DXA reference standard. J Bone Miner Res. 2011 Sep;26(9):2194-203. doi: 10.1002/jbmr.428 [doi]. PMID: 21590738. Exclusion Code: X7.21590738
507 Pickhardt PJ, Pooler BD, Lauder T, . Opportunistic screening for osteoporosis using abdominal computed tomography scans obtained for other indications. Ann Intern Med. 2013 Apr 16;158(8):588-95. doi: 10.7326/0003-4819-158-8-201304160-00003. PMID: 23588747. Exclusion Code: X9.23588747
508 Pinheiro MM, Reis Neto ET, Machado FS, . Development and validation of a tool for identifying women with low bone mineral density and low-impact fractures: the Sao Paulo Osteoporosis Risk Index (SAPORI). Osteoporos Int. 2012 Apr;23(4):1371-9. doi: 10.1007/s00198-011-1722-y [doi]. PMID: 21769663. Exclusion Code: X15.21769663
509 Pinkerton JV, Archer DF, Utian WH, . Bazedoxifene effects on the reproductive tract in postmenopausal women at risk for osteoporosis. Menopause. 2009 Nov-Dec;16(6):1102-8. doi: 10.1097/gme.0b013e3181a816be [doi]. PMID: 19546825. Exclusion Code: X7.19546825
510 Pinkerton JV, Pickar JH, Ryan KA, . Conjugated estrogens and bazedoxifene in minority populations: Pooled analysis of four phase 3 trials. In Menopause (New York, N.Y.) Exclusion Code: X4.
511 Pisani P, Conversano F, Muratore M, . A novel ultrasound parameter to assess skeletal fragility and fracture risk from an echographic scan of lumbar spine. In Osteoporos Int Exclusion Code: X12.
512 Piscitelli P, Chitano G, Johannson H, . Updated fracture incidence rates for the Italian version of FRAX(R). Osteoporos Int. 2013 Mar;24(3):859-66. doi: 10.1007/s00198-012-2021-y [doi]. PMID: 22638710. Exclusion Code: X8.22638710
513 Pluijm SM, Koes B, de Laet C, . A simple risk score for the assessment of absolute fracture risk in general practice based on two longitudinal studies. J Bone Miner Res. 2009 May;24(5):768-74. doi: 10.1359/jbmr.081244 [doi]. PMID: 19113932. Exclusion Code: X14.19113932
514 Pluskiewicz W, Drozdzowska B, Adamczyk P. Ten-year fracture risk in the assessment of osteoporosis management efficacy in postmenopausal women: a pilot study. Climacteric. 2013 Feb;16(1):117-26. doi: 10.3109/13697137.2011.646345 [doi]. PMID: 22335356. Exclusion Code: X9.22335356
515 Pongchaiyakul C, Leerapun T, Wongsiri S, . Value and validation of RCOST and TOPF clinical practice guideline for osteoporosis treatment. J Med Assoc Thai. 2012 Dec;95(12):1528-35. PMID: 23390783. Exclusion Code: X9.23390783
516 Pouilles JM, Tremollieres F, Roux C, . Effects of cyclical etidronate therapy on bone loss in early postmenopausal women who are not undergoing hormonal replacement therapy. Osteoporos Int. 1997;7(3):213-8. PMID: 9205633. Exclusion Code: X3.9205633
517 Pugely AJ, Martin CT, Gao Y, . A risk calculator for short-termmorbidity and mortality after hip fracture surgery. J Orthop Trauma. 2014 Feb;28(2):63-9. doi: 10.1097/BOT.0b013e3182a22744 [doi]. PMID: 23872716. Exclusion Code: X3.23872716
518 Rabiei M, Masooleh IS, Leyli EK, . Salivary calcium concentration as a screening tool for postmenopausal osteoporosis. Int J Rheum Dis. 2013 Apr;16(2):198-202. doi: 10.1111/1756-185X.12003 [doi]. PMID: 23773645. Exclusion Code: X8.23773645
519 Rabier B, Heraud A, Grand-Lenoir C, . A multicentre, retrospective case-control study assessing the role of trabecular bone score (TBS) in menopausal Caucasian women with low areal bone mineral density (BMDa): Analysing the odds of vertebral fracture. Bone. 2010 Jan;46(1):176-81. doi: 10.1016/j.bone.2009.06.032. PMID: 19747992. Exclusion Code: X4.19747992
520 Rajatanavin R, Chailurkit L, Saetung S, . The efficacy of calcium supplementation alone in elderly Thai women over a 2-year period: a randomized controlled trial. Osteoporos Int. 2013 Nov;24(11):2871-7. doi: 10.1007/s00198-013-2387-5 [doi]. PMID: 23681085. Exclusion Code: X3.23681085
521 Recker R, Stakkestad JA, Chesnut CH 3rd, . Insufficiently dosed intravenous ibandronate injections are associated with suboptimal antifracture efficacy in postmenopausal osteoporosis. Bone. 2004 May;34(5):890-9. doi: 10.1016/j.bone.2004.01.008. PMID: 15121021. Exclusion Code: X3.15121021
522 Reginster JY, Felsenberg D, Pavo I, . Effect of raloxifene combined with monofluorophosphate as compared with monofluorophosphate alone in postmenopausal women with low bone mass: a randomized, controlled trial. Osteoporos Int. 2003 Sep;14(9):741-9. doi: 10.1007/s00198-003-1432-1. PMID: 12827224. Exclusion Code: X8.12827224
523 Rehman DE, Qureshi S, Abdul Haq A. Early detection of osteoporosis from incisure depth of human mandible in an orthopantomogram. J Pak Med Assoc. 2014 Jul;64(7):766-9. PMID: 25255583. Exclusion Code: X8.25255583
524 Reid DM, Hughes RA, Laan RF, . Efficacy and safety of daily risedronate in the treatment of corticosteroid-induced osteoporosis in men and women: a randomized trial. European Corticosteroid-Induced Osteoporosis Treatment Study. J Bone Miner Res. 2000 Jun;15(6):1006-13. doi: 10.1359/jbmr.2000.15.6.1006. PMID: 10841169. Exclusion Code: X3.10841169
525 Reid IR, Eastell R, Fogelman I, . A comparison of the effects of raloxifene and conjugated equine estrogen on bone and lipids in healthy postmenopausal women. Arch Intern Med. 2004 Apr 26;164(8):871-9. doi: 10.1001/archinte.164.8.871. PMID: 15111373. Exclusion Code: X3.15111373
526 Rendl S, Lapa C, Blumel C, . Decision making for osteoporotic treatment using FRAX or DVO risk algorithms in a clinical setting. J Musculoskelet Neuronal Interact. 2013 Sep;13(3):339-45. PMID: 23989255. Exclusion Code: X9.23989255
527 Rhee CW, Lee J, Oh S, . Use of bisphosphonate and risk of atrial fibrillation in older women with osteoporosis. Osteoporos Int. 2012 Jan;23(1):247-54. doi: 10.1007/s00198-011-1608-z [doi]. PMID: 21431993. Exclusion Code: X20.21431993
528 Rianon NJ, Lang TF, Siggeirsdottir K, . Fracture risk assessment in older adults using a combination of selected quantitative computed tomography bone measures: a subanalysis of the Age, Gene/Environment Susceptibility-Reykjavik Study. J Clin Densitom. 2014 Jan-Mar;17(1):25-31. doi: 10.1016/j.jocd.2013.03.005. PMID: 23562129. Exclusion Code: X8.23562129
529 Rikkonen T, Sirola J, Salovaara K, . Muscle strength and body composition are clinical indicators of osteoporosis. Calcif Tissue Int. 2012 Aug;91(2):131-8. doi: 10.1007/s00223-012-9618-1 [doi]. PMID: 22733383. Exclusion Code: X9.22733383
530 Ringe JD, Dorst A, Faber H, . Alendronate treatment of established primary osteoporosis in men: 3-year results of a prospective, comparative, two-arm study. Rheumatol Int. 2004 Mar;24(2):110-3. doi: 10.1007/s00296-003-0388-y. PMID: 13680141. Exclusion Code: X3.13680141
531 Ringe JD, Dorst A, Farahmand P. Efficacy of strontiumranelate on bone mineral density in men with osteoporosis. Arzneimittelforschung. 2010;60(5):267-72. PMID: 20533764. Exclusion Code: X7.20533764
532 Ringe JD, Farahmand P, Schacht E, . Superiority of a combined treatment of Alendronate and Alfacalcidol compared to the combination of Alendronate and plain vitamin D or Alfacalcidol alone in established postmenopausal or male osteoporosis (AAC-Trial). Rheumatol Int. 2007 Mar;27(5):425-34. doi: 10.1007/s00296-006-0288-z. PMID: 17216477. Exclusion Code: X8.17216477
533 Ripamonti C, Lisi L, Avella M. Femoral neck shaft angle width is associated with hip-fracture risk in males but not independently of femoral neck bone density. Br J Radiol. 2014 May;87(1037):20130358. doi: 10.1259/bjr.20130358 [doi]. PMID: 24678889. Exclusion Code: X9.24678889
534 Robbins J, Aragaki AK, Kooperberg C, . Factors associated with 5-year risk of hip fracture in postmenopausal women. JAMA. 2007 Nov 28;298(20):2389-98. doi: 10.1001/jama.298.20.2389. PMID: 18042916. Exclusion Code: X3.18042916
535 Robbins JA, Aragaki A, Crandall CJ, . Women’s Health Initiative clinical trials: interaction of calcium and vitamin D with hormone therapy. Menopause. 2014 Feb;21(2):116-23. doi: 10.1097/GME.0b013e3182963901 [doi]. PMID: 23799356. Exclusion Code: X3.23799356
536 Roberts BJ, Thrall E, Muller JA, . Comparison of hip fracture risk prediction by femoral aBMD to experimentally measured factor of risk. Bone. 2010 Mar;46(3):742-6. doi: 10.1016/j.bone.2009.10.020. PMID: 19854307. Exclusion Code: X8.19854307
537 Rossini M, Gatti D, Girardello S, . Effects of two intermittent alendronate regimens in the prevention or treatment of postmenopausal osteoporosis. Bone. 2000 Jul;27(1):119-22. PMID: 10865218. Exclusion Code: X3.10865218
538 Rostislav N, Nahum R, David N, . Canal-to-Diaphysis Ratio as an Osteoporosis-Related Risk Factor for Hip Fractures. Orthopedics. 2015 Jun;38(6):e457-61. doi: 10.3928/01477447-20150603-51 [doi]. PMID: 26091216. Exclusion Code: X9.26091216
539 Roux C, Briot K, Horlait S, . Assessment of non-vertebral fracture risk in postmenopausal women. Ann Rheum Dis. 2007 Jul;66(7):931-5. doi: 10.1136/ard.2006.064071. PMID: 17314119. Exclusion Code: X3.17314119
540 Roux S, Cabana F, Carrier N, . The World Health Organization Fracture Risk Assessment Tool (FRAX) underestimates incident and recurrent fractures in consecutive patients with fragility fractures. J Clin Endocrinol Metab. 2014 Jul;99(7):2400-8. doi: 10.1210/jc.2013-4507 [doi]. PMID: 24780062. Exclusion Code: X3.24780062
541 Rozental TD, Deschamps LN, Taylor A, . Premenopausal women with a distal radial fracture have deteriorated trabecular bone density and morphology compared with controls without a fracture. J Bone Joint Surg Am. 2013 Apr 3;95(7):633-42. doi: 10.2106/JBJS.L.00588. PMID: 23553299. Exclusion Code: X9.23553299
542 Rubin KH, Abrahamsen B, Hermann AP, . Fracture risk assessed by Fracture Risk Assessment Tool (FRAX) compared with fracture risk derived from population fracture rates. Scand J Public Health. 2011 May;39(3):312-8. doi: 10.1177/1403494811402412. PMID: 21429990. Exclusion Code: X8.21429990
543 Rubin KH, Friis-Holmberg T, Hermann AP, . Risk assessment tools to identify women with increased risk of osteoporotic fracture: complexity or simplicity? A systematic review. J Bone Miner Res. 2013 Aug;28(8):1701-17. doi: 10.1002/jbmr.1956. PMID: 23592255. Exclusion Code: X17.23592255
544 Rubin MR, Lee KH, McMahon DJ, . Raloxifene lowers serumcalciumand markers of bone turnover in postmenopausal women with primary hyperparathyroidism. J Clin Endocrinol Metab. 2003 Mar;88(3):1174-8. doi: 10.1210/jc.2002-020667. PMID: 12629102. Exclusion Code: X3.12629102
545 Rud B, Hilden J, Hyldstrup L, . Performance of the Osteoporosis Self-Assessment Tool in ruling out low bone mineral density in postmenopausal women: a systematic review. Osteoporos Int. 2007 Sep;18(9):1177-87. doi: 10.1007/s00198-006-0319-3 [doi]. PMID: 17361324. Exclusion Code: X9.17361324
546 Rud B, Hilden J, Hyldstrup L, . The Osteoporosis Self-Assessment Tool versus alternative tests for selecting postmenopausal women for bone mineral density assessment: a comparative systematic review of accuracy. Osteoporos Int. 2009 Apr;20(4):599-607. doi: 10.1007/s00198-008-0713-0 [doi]. PMID: 18716823. Exclusion Code: X17.18716823
547 Saag KG, Emkey R, Schnitzer TJ, . Alendronate for the prevention and treatment of glucocorticoid-induced osteoporosis. Glucocorticoid-Induced Osteoporosis Intervention Study Group. N Engl J Med. 1998 Jul 30;339(5):292-9. doi: 10.1056/nejm199807303390502. PMID: 9682041. Exclusion Code: X3.9682041
548 Saarelainen J, Hassi S, Honkanen R, . Bone loss and wrist fractures after withdrawal of hormone therapy: The 15-year follow-up of the OSTPRE cohort. Maturitas. 2016 Mar;85:49-55. doi: 10.1016/j.maturitas.2015.12.011. PMID: 26857879. Exclusion Code: X4.26857879
549 Salaffi F, Silveri F, Stancati A, . Development and validation of the osteoporosis prescreening risk assessment (OPERA) tool to facilitate identification of women likely to have low bone density. Clin Rheumatol. 2005 Jun;24(3):203-11. doi: 10.1007/s10067-004-1014-4. PMID: 15549501. Exclusion Code: X14.15549501
550 Sambrook PN, Rodriguez JP, Wasnich RD, . Alendronate in the prevention of osteoporosis: 7-year follow-up. Osteoporos Int. 2004 Jun;15(6):483-8. doi: 10.1007/s00198-003-1571-4. PMID: 15205720. Exclusion Code: X7.15205720
551 Samels on EJ, Miller PD, Christiansen C, . RANKL inhibition with denosumab does not influence 3-year progression of aortic calcification or incidence of adverse cardiovascular events in postmenopausal women with osteoporosis and high cardiovascular risk. J Bone Miner Res. 2014;29(2):450-7. Exclusion Code: X20.23873632
552 Sanad Z, Ellakwa H, Desouky B. Comparison of alendronate and raloxifene in postmenopausal women with osteoporosis. Climacteric. 2011 Jun;14(3):369-77. doi: 10.3109/13697137.2010.537408 [doi]. PMID: 21254911. Exclusion Code: X8.21254911
553 Sanfelix-Genoves J, Peiro S, Sanfelix-Gimeno G, . Development and validation of a population-based prediction scale for osteoporotic fracture in the region of Valencia, Spain: the ESOSVAL-R study. BMC Public Health. 2010;10:153. doi: 10.1186/1471-2458-10-153. PMID: 20334639. Exclusion Code: X2.20334639
554 Sato Y, Iwamoto J, Kanoko T, . Alendronate and vitamin D2 for prevention of hip fracture in Parkinson’s disease: a randomized controlled trial. Mov Disord. 2006 Jul;21(7):924-9. doi: 10.1002/mds.20825. PMID: 16538619. Exclusion Code: X10.16538619
555 Schnatz PF, Marakovits KA, Dubois M, . Osteoporosis screening and treatment guidelines: are they being followed? Menopause. 2011 Oct;18(10):1072-8. doi: 10.1097/gme.0b013e318215101a [doi]. PMID: 21753740. Exclusion Code: X9.21753740
556 Schneider DL, Worley K, Beard MK, . The primary care osteoporosis risk of fracture screening (POROS) study: design and baseline characteristics. Contemp Clin Trials. 2010 Jul;31(4):336-44. doi: 10.1016/j.cct.2010.03.012. PMID: 20382273. Exclusion Code: X2.20382273
557 Schousboe JT, Rosen HR, Vokes TJ, . Prediction models of prevalent radiographic vertebral fractures among older women. J Clin Densitom. 2014 Jul-Sep;17(3):378-85. doi: 10.1016/j.jocd.2013.09.021. PMID: 24582085. Exclusion Code: X14.24582085
558 Schousboe JT, Rosen HR, Vokes TJ, . Prediction models of prevalent radiographic vertebral fractures among older men. J Clin Densitom. 2014 Oct-Dec;17(4):449-57. doi: 10.1016/j.jocd.2013.09.020. PMID: 24289883. Exclusion Code: X14.24289883
559 Schuit SC, van der Klift M, Weel AE, . Fracture incidence and association with bone mineral density in elderly men and women: the Rotterdam Study. Bone. 2004 Jan;34(1):195-202. PMID: 14751578. Exclusion Code: X9.14751578
560 Schuler B, Fritscher KD, Kuhn V, . Assessment of the individual fracture risk of the proximal femur by using statistical appearance models. Med Phys. 2010 Jun;37(6):2560-71. PMID: 20632568. Exclusion Code: X3.20632568
561 Sedrine WB, Chevallier T, Zegels B, . Development and assessment of the Osteoporosis Index of Risk (OSIRIS) to facilitate selection of women for bone densitometry. Gynecol Endocrinol. 2002 Jun;16(3):245-50. doi: 10.1080/gye.16.3.245.250. PMID: 12192897. Exclusion Code: X14.12192897
562 Sen SS, Rives VP, Messina OD, . A risk assessment tool (OsteoRisk) for identifying Latin American women with osteoporosis. J Gen Intern Med. 2005 Mar;20(3):245-50. doi: 10.1111/j.1525-1497.2005.40900.x. PMID: 15836528. Exclusion Code: X15.15836528
563 Seok H, Kim KJ, Kim KM, . High prevalence of spine-femur bone mineral density discordance and comparison of vertebral fracture risk assessment using femoral neck and lumbar spine bone density in Korean patients. J Bone Miner Metab. 2014 Jul;32(4):405-10. doi: 10.1007/s00774-013-0512-3 [doi]. PMID: 24122250. Exclusion Code: X9.24122250
564 Sestak I. Changes in bone mineral density at 3 years in postmenopausal women receiving anastrozole and risedronate in the IBIS-II bone substudy: an international, double-blind, randomised, placebo-controlled trial. The Lancet. Oncology. 2014;15(13):1460-8. Exclusion Code: X3.25456365
565 Shahla A. Validity of bone mineral density and WHO fracture risk assessment thresholds in hip fractures. Arch Iran Med. 2011 Sep;14(5):352-4. PMID: 21888461. Exclusion Code: X9.21888461
566 Shan LP, Bee OF, Suniza SS, . Developing a Malaysian Osteoporosis Screening Tool (MOST) for early osteoporosis detection in Malaysian women. Sex Reprod Healthc. 2011 Apr;2(2):77-82. doi: 10.1016/j.srhc.2010.11.004. PMID: 21439525. Exclusion Code: X15.21439525
567 Sharma A, Einstein AJ, Vallakati A, . Risk of atrial fibrillation with use of oral and intravenous bisphosphonates. Am J Cardiol. 2014 Jun 1;113(11):1815-21. doi: 10.1016/j.amjcard.2014.03.008. PMID: 24837258. Exclusion Code: X3.24837258
568 Sheehy O, Kindundu C, Barbeau M, . Adherence to weekly oral bisphosphonate therapy: cost of wasted drugs and fractures. Osteoporos Int. 2009 Sep;20(9):1583-94. doi: 10.1007/s00198-008-0829-2 [doi]. PMID: 19153677. Exclusion Code: X8.19153677
569 Shepstone L, Fordham R, Lenaghan E, . A pragmatic randomised controlled trial of the effectiveness and cost-effectiveness of screening older women for the prevention of fractures: rationale, design and methods for the SCOOP study. Osteoporos Int. 2012 Oct;23(10):2507-15. doi: 10.1007/s00198-011-1876-7 [doi]. PMID: 22314936. Exclusion Code: X2.22314936
570 Shepstone L, Lenaghan E, Clarke S, . A randomized controlled trial of screening in the community to reduce fractures in older women in the UK (the scoop study). In Osteoporos Int Exclusion Code: X16.
571 Shkolnikova J, Flynn J, Choong P. Burden of bisphosphonate-associated femoral fractures. ANZ J Surg. 2013 Mar;83(3):175-81. doi: 10.1111/ans.12018 [doi]. PMID: 23216704. Exclusion Code: X4.23216704
572 Short CE, Shaw SG, Fisher MJ, . Comparison of peripheral forearm DXA and clinical risk factor screening using FRAX(R) to assess the risk of HIV-associated low bone mass: a cross-sectional study. Arch Osteoporos. 2014;9(1):181. doi: 10.1007/s11657-014-0181-4 [doi]. PMID: 24847675. Exclusion Code: X3.24847675
573 Shribman S, Torsney KM, Noyce AJ, . A service development study of the assessment and management of fracture risk in Parkinson’s disease. J Neurol. 2014 Jun;261(6):1153-9. doi: 10.1007/s00415-014-7333-8 [doi]. PMID: 24718980. Exclusion Code: X3.24718980
574 Sievanen H, Weynand LS, Wacker WK, . A novel DXA-based hip failure index captures hip fragility independent of BMD. J Clin Densitom. 2008 Jul-Sep;11(3):367-72. doi: 10.1016/j.jocd.2008.02.005. PMID: 18456529. Exclusion Code: X12.18456529
575 Silverman S, Miller P, Sebba A, . The Direct Assessment of Nonvertebral Fractures in Community Experience (DANCE) study: 2-year nonvertebral fragility fracture results. Osteoporos Int. 2013 Aug;24(8):2309-17. doi: 10.1007/s00198-013-2284-y [doi]. PMID: 23404615. Exclusion Code: X3.23404615
576 Silverman SL, Chines AA, Kendler DL, . Sustained efficacy and safety of bazedoxifene in preventing fractures in postmenopausal women with osteoporosis: results of a 5-year, randomized, placebo-controlled study. Osteoporos Int. 2012 Jan;23(1):351-63. doi: 10.1007/s00198-011-1691-1 [doi]. PMID: 21779819. Exclusion Code: X7.21779819
577 Silverman SL, Christiansen C, Genant HK, . Efficacy of bazedoxifene in reducing new vertebral fracture risk in postmenopausal women with osteoporosis: results from a 3-year, randomized, placebo-, and active-controlled clinical trial. J Bone Miner Res. 2008 Dec;23(12):1923-34. doi: 10.1359/jbmr.080710. PMID: 18665787. Exclusion Code: X3.18665787
578 Silverman SL, Siris E, Kendler DL, . Persistence at 12 months with denosumab in postmenopausal women with osteoporosis: interim results from a prospective observational study. Osteoporos Int. 2015 Jan;26(1):361-72. doi: 10.1007/s00198-014-2871-6 [doi]. PMID: 25236877. Exclusion Code: X8.25236877
579 Siris ES, Genant HK, Laster AJ, . Enhanced prediction of fracture risk combining vertebral fracture status and BMD. Osteoporos Int. 2007 Jun;18(6):761-70. doi: 10.1007/s00198-006-0306-8 [doi]. PMID: 17245546. Exclusion Code: X9.17245546
580 Siris ES, Harris ST, Eastell R, . Skeletal effects of raloxifene after 8 years: results from the continuing outcomes relevant to Evista (CORE) study. J Bone Miner Res. 2005 Sep;20(9):1514-24. doi: 10.1359/jbmr.050509. PMID: 16059623. Exclusion Code: X3.16059623
581 Skowronska-Jozwiak E, Wojcicka A, Lorenc RS, . Comparison of selected methods for fracture risk assessment in postmenopausal women: analysis of the Lodz population in the EPOLOS study. Pol Arch Med Wewn. 2010 May;120(5):197-202. PMID: 20502405. Exclusion Code: X9.20502405
582 Smith MR, Eastham J, Gleason DM, . Randomized controlled trial of zoledronic acid to prevent bone loss in men receiving androgen deprivation therapy for nonmetastatic prostate cancer. J Urol. 2003 Jun;169(6):2008-12. doi: 10.1097/01.ju.0000063820.94994.95. PMID: 12771706. Exclusion Code: X3.12771706
583 Smith MR, Fallon MA, Lee H, . Raloxifene to prevent gonadotropin-releasing hormone agonist-induced bone loss in men with prostate cancer: a randomized controlled trial. J Clin Endocrinol Metab. 2004 Aug;89(8):3841-6. doi: 10.1210/jc.2003-032058. PMID: 15292315. Exclusion Code: X3.15292315
584 Sobel EM, Ettinger B, Lo JC, . Application of new method for evaluating performance of fracture risk tool. Am J Manag Care. 2012 Oct;18(10):e398. PMID: 23145848. Exclusion Code: X8.23145848
585 Soontrapa S, Chaikitpinyo S. Using quantitative ultrasound and OSTA index to increase the efficacy and decrease the cost for diagnosis of osteoporosis. J Med Assoc Thai. 2009 Sep;92 Supp 15:S49-53. PMID: 19894331. Exclusion Code: X15.19894331
586 Sornay-Rendu E, Duboeuf F, Boutroy S, . How to predict fragility fracture beyond 10 years? The OFELY study. J Clin Endocrinol Metab. 2014 Dec;99(12):4690-7. doi: 10.1210/jc.2014-2601 [doi]. PMID: 25250635. Exclusion Code: X9.25250635
587 Springe B, Slaidina A, Soboleva U, . Bone mineral density and mandibular residual ridge resorption. Int J Prosthodont. 2014 May-Jun;27(3):270-6. PMID: 24905270. Exclusion Code: X3.24905270
588 Stepan JJ, Burr DB, Li J, . Histomorphometric changes by teriparatide in alendronate-pretreated women with osteoporosis. Osteoporos Int. 2010 Dec;21(12):2027-36. doi: 10.1007/s00198-009-1168-7 [doi]. PMID: 20135094. Exclusion Code: X9.20135094
589 Steurer J, Haller C, Hauselmann H, . Clinical value of prognostic instruments to identify patients with an increased risk for osteoporotic fractures: systematic review. PLoS One. 2011;6(5):e19994. doi: 10.1371/journal.pone.0019994. PMID: 21625596. Exclusion Code: X17.21625596
590 Stevenson M, Jones ML, De Nigris E, . A systematic review and economic evaluation of alendronate, etidronate, risedronate, raloxifene and teriparatide for the prevention and treatment of postmenopausal osteoporosis. Health Technol Assess. 2005 Jun;9(22):1-160. PMID: 15929857. Exclusion Code: X3.15929857
591 Stuart AL, Williams LJ, Brennan SL, . Poor agreement between self-reported diagnosis and bone mineral density results in the identification of osteoporosis. J Clin Densitom. 2015 Jan-Mar;18(1):13-6. doi: 10.1016/j.jocd.2014.04.123. PMID: 24912958. Exclusion Code: X8.24912958
592 Su FM, Chen YC, Cheng TT, . Is raloxifene associated with lower risk of mortality in postmenopausal women with vertebral fractures after vertebroplasty?: a hospital-based analysis. BMC Musculoskelet Disord. 2015;16:209. doi: 10.1186/s12891-015-0670-7. PMID: 26286481. Exclusion Code: X3.26286481
593 Su FM, Liu DH, Chen JF, . Development and Validation of an Osteoporosis Self-Assessment Tool for Taiwan (OSTAi) Postmenopausal Women-A Sub-Study of the Taiwan OsteoPorosis Survey (TOPS). PLoS One. 2015;10(6):e0130716. doi: 10.1371/journal.pone.0130716. PMID: 26086766. Exclusion Code: X9.26086766
594 Sugimoto T, Matsumoto T, Hosoi T, . Three-year denosumab treatment in postmenopausal Japanese women and men with osteoporosis: results from a 1-year open-label extension of the Denosumab Fracture Intervention Randomized Placebo Controlled Trial (DIRECT). Osteoporos Int. 2015 Feb;26(2):765-74. doi: 10.1007/s00198-014-2964-2 [doi]. PMID: 25403903. Exclusion Code: X3.25403903
595 Sugimoto T, Matsumoto T, Hosoi T, . Three-year denosumab treatment in postmenopausal Japanese women and men with osteoporosis: results from a 1-year open-label extension of the Denosumab Fracture Intervention Randomized Placebo Controlled Trial (DIRECT). In Osteoporosis international: a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA Exclusion Code: X8.
596 Sumino H, Ichikawa S, Kasama S, . Effects of raloxifene on the renin-angiotensin-aldosterone system and blood pressure in hypertensive and normotensive osteoporotic postmenopausal women. Geriatr Gerontol Int. 2010 Jan;10(1):70-7. doi: 10.1111/j.1447-0594.2009.00562.x. PMID: 20102385. Exclusion Code: X9.20102385
597 Summers RM, Baecher N, Yao J, . Feasibility of simultaneous computed tomographic colonography and fully automated bone mineral densitometry in a single examination. In J Comput Assist Tomogr Exclusion Code: X9.
598 Sun LM, Lin MC, Muo CH, . Calcitonin nasalspray and increased cancer risk: a population-based nested case-control study. J Clin Endocrinol Metab. 2014 Nov;99(11):4259-64. doi: 10.1210/jc.2014-2239 [doi]. PMID: 25144633. Exclusion Code: X7.25144633
599 Sunder R, Tyler K. Basal skull fracture and the halo sign. CMAJ. 2013 Mar 19;185(5):416. doi: 10.1503/cmaj.120055. PMID: 22891200. Exclusion Code: X9.22891200
600 Svejme O, Ahlborg HG, Nilsson JA, . Low BMD is an independent predictor of fracture and early menopause of mortality in post-menopausal women--a 34-year prospective study. Maturitas. 2013 Apr;74(4):341-5. doi: 10.1016/j.maturitas.2013.01.002. PMID: 23374709. Exclusion Code: X4.23374709
601 Swaminathan K, Flynn R, Garton M, . Search for secondary osteoporosis: are Z scores useful predictors? Postgrad Med J. 2009 Jan;85(999):38-9. doi: 10.1136/pgmj.2007.065748. PMID: 19240287. Exclusion Code: X3.19240287
602 Takaishi Y, Arita S, Honda M, . Assessment of alveolar bone mineral density as a predictor of lumbar fracture probability. Adv Ther. 2013 May;30(5):487-502. doi: 10.1007/s12325-013-0028-1 [doi]. PMID: 23674163. Exclusion Code: X12.23674163
603 Takeuchi Y, Kuroda T, Sugimoto T, . Renal Phosphate Reabsorption is Correlated with the Increase in Lumbar Bone Mineral Density in Patients Receiving Once-Weekly Teriparatide. In Calcif Tissue Int Exclusion Code: X9.
604 Tamone C, Fonte G, Panico A, . Impact of a phone follow-up program on persistence with teriparatide or PTH(1-84) treatment. Calcif Tissue Int. 2012 Apr;90(4):272-8. doi: 10.1007/s00223-012-9574-9 [doi]. PMID: 22322409. Exclusion Code: X9.22322409
605 Tanaka S, Kuroda T, Sugimoto T, . Changes in bone mineral density, bone turnover markers, and vertebral fracture risk reduction with once weekly teriparatide. Curr Med Res Opin. 2014 May;30(5):931-6. doi: 10.1185/03007995.2013.879440 [doi]. PMID: 24392946. Exclusion Code: X3.24392946
606 Tanprasertkul C, Wattanaruangkowit P, Panyakhamlerd K. The combination of body mass index and age as a new index for identifying osteoporosis in Thai postmenopausal women. J Med Assoc Thai. 2010 Dec;93 Suppl 7:S76-82. PMID: 21294400. Exclusion Code: X15.21294400
607 Tay WL, Chui CK, Ong SH, . Osteoporosis screening using areal bone mineral density estimation from diagnostic CT images. Acad Radiol. 2012 Oct;19(10):1273-82. doi: 10.1016/j.acra.2012.05.017. PMID: 22958722. Exclusion Code: X7.22958722
608 Taylor BC, Schreiner PJ, Stone KL, . Long-termprediction of incident hip fracture risk in elderly white women: study of osteoporotic fractures. J Am Geriatr Soc. 2004 Sep;52(9):1479-86. doi: 10.1111/j.1532-5415.2004.52410.x. PMID: 15341549. Exclusion Code: X9.15341549
609 Teede HJ, Renouf DA, Jayasuriya IA, . STOP fracture study: southern health osteoporotic fracture screening project. Intern Med J. 2012 May;42(5):e74-9. doi: 10.1111/j.1445-5994.2010.02258.x. PMID: 20492007. Exclusion Code: X9.20492007
610 Tell GS, Fried LP, Hermanson B, . Recruitment of adults 65 years and older as participants in the Cardiovascular Health Study. Ann Epidemiol. 1993 Jul;3(4):358-66. PMID: 8275211. Exclusion Code: X4.8275211
611 Thevenot J, Hirvasniemi J, Pulkkinen P, . Assessment of risk of femoral neck fracture with radiographic texture parameters: a retrospective study. Radiology. 2014 Jul;272(1):184-91. doi: 10.1148/radiol.14131390 [doi]. PMID: 24620912. Exclusion Code: X8.24620912
612 Thomson AB, Marshall JK, Hunt RH, . 14 day endoscopy study comparing risedronate and alendronate in postmenopausal women stratified by Helicobacter pyloristatus. J Rheumatol. 2002 Sep;29(9):1965-74. PMID: 12233894. Exclusion Code: X3.12233894
613 Toulis KA, Anastasilakis AD. Increased risk of serious infections in women with osteopenia or osteoporosis treated with denosumab. Osteoporos Int. 2010 Nov;21(11):1963-4. doi: 10.1007/s00198-009-1145-1. PMID: 20012939. Exclusion Code: X3.20012939
614 Touvier J, Winzenrieth R, Johansson H, . Fracture discrimination by combined bone mineral density (BMD) and microarchitectural texture analysis. Calcif Tissue Int. 2015 Apr;96(4):274-83. doi: 10.1007/s00223-015-9952-1 [doi]. PMID: 25586017. Exclusion Code: X11.25586017
615 Tremollieres F, Cochet T, Cohade C, . Fracture risk in early postmenopausal women assessed using FRAX. Joint Bone Spine. 2010 Jul;77(4):345-8. doi: 10.1016/j.jbspin.2010.04.012. PMID: 20605507. Exclusion Code: X7.20605507
616 Trimpou P, Bosaeus I, Bengtsson BA, . High correlation between quantitative ultrasound and DXA during 7 years of follow-up. Eur J Radiol. 2010 Feb;73(2):360-4. doi: 10.1016/j.ejrad.2008.11.024. PMID: 19135327. Exclusion Code: X3.19135327
617 Tsai JN, Uihlein AV, Lee H, . Teriparatide and denosumab, alone or combined, in women with postmenopausal osteoporosis: the DATA study randomised trial. Lancet. 2013 Jul 6;382(9886):50-6. doi: 10.1016/S0140-6736(13)60856-9. PMID: 23683600. Exclusion Code: X8.23683600
618 Tsang JF, Leslie WD. Exclusion of focal vertebral artifacts from spine bone densitometry and fracture prediction: a comparison of expert physicians, three computer algorithms, and the minimum vertebra. J Bone Miner Res. 2007 Jun;22(6):789-98. doi: 10.1359/jbmr.070319 [doi]. PMID: 17371161. Exclusion Code: X9.17371161
619 Tsang SW, Kung AW, Kanis JA, . Ten-year fracture probability in Hong Kong Southern Chinese according to age and BMD femoral neck T-scores. Osteoporos Int. 2009 Nov;20(11):1939-45. doi: 10.1007/s00198-009-0906-1 [doi]. PMID: 19326036. Exclusion Code: X7.19326036
620 Tseng WJ, Hung LW, Shieh JS, . Hip fracture risk assessment: artificial neural network outperforms conditional logistic regression in an age- and sex-matched case control study. BMC Musculoskelet Disord. 2013;14:207. doi: 10.1186/1471-2474-14-207. PMID: 23855555. Exclusion Code: X8.23855555
621 Tsujimoto M, Chen P, Miyauchi A, . PINP as an aid for monitoring patients treated with teriparatide. Bone. 2011 Apr 1;48(4):798-803. doi: 10.1016/j.bone.2010.12.006. PMID: 21168536. Exclusion Code: X9.21168536
622 Tufts G. The treatment of osteopenia in Asian women: a new approach. J Am Acad Nurse Pract. 2011 Aug;23(8):434-42. doi: 10.1111/j.1745-7599.2011.00629.x [doi]. PMID: 21790837. Exclusion Code: X9.21790837
623 Ungar WJ, Josse R, Lee S, . The Canadian SCORE questionnaire: optimizing the use of technology for low bone density assessment. Simple Calculated Osteoporosis Risk Estimate. J Clin Densitom. 2000 Fall;3(3):269-80. PMID: 11090234. Exclusion Code: X9.11090234
624 Urushihara H, Kikuchi N, Yamada M, . Raloxifene and stroke risks in Japanese postmenopausal women with osteoporosis on postmarketing surveillance. Menopause. 2009 Sep-Oct;16(5):971-7. doi: 10.1097/gme.0b013e3181a15622 [doi]. PMID: 19357545. Exclusion Code: X4.19357545
625 Uusi-Rasi K, Kannus P, Cheng S, . Effect of alendronate and exercise on bone and physical performance of postmenopausal women: a randomized controlled trial. Bone. 2003 Jul;33(1):132-43. PMID: 12919708. Exclusion Code: X9.12919708
626 Valerio CS, Trindade AM, Mazzieiro ET, . Use of digital panoramic radiography as an auxiliary means of low bone mineral density detection in post-menopausal women. Dentomaxillofac Radiol. 2013;42(10):20120059. doi: 10.1259/dmfr.20120059. PMID: 24005062. Exclusion Code: X9.24005062
627 Vallipakorn SA, Vallipakorn O, Sophonsritsuk A, . The Optimal Cut-Points for Weight and Non-Weight Quantitative Ultrasound of the Calcaneus to Screen Osteoporosis in Postmenopausal Women. J Med Assoc Thai. 2016 Mar;99(3):249-56. PMID: 27276734. Exclusion Code: X15.27276734
628 van Staa T, Abenhaim L, Cooper C. Upper gastrointestinal adverse events and cyclical etidronate. Am J Med. 1997 Dec;103(6):462-7. PMID: 9428828. Exclusion Code: X20.9428828
629 van Staa TP, Geusens P, Kanis JA, . A simple clinical score for estimating the long-term risk of fracture in post-men opausal women. QJM. 2006 Oct;99(10):673-82. doi: 10.1093/qjmed/hcl094. PMID: 16998210. Exclusion Code: X9.16998210
630 Vestergaard P. Acute myocardial infarction and atherosclerosis of the coronary arteries in patients treated with drugs against osteoporosis: calcium in the vessels and not the bones? Calcif Tissue Int. 2012 Jan;90(1):22-9. doi: 10.1007/s00223-011-9549-2 [doi]. PMID: 22120197. Exclusion Code: X20.22120197
631 Vestergaard P, Jorgensen NR, Mosekilde L, . Effects of parathyroid hormone alone or in combination with antiresorptive therapy on bone mineral density and fracture risk--a meta-analysis. Osteoporos Int. 2007 Jan;18(1):45-57. doi: 10.1007/s00198-006-0204-0. PMID: 16951908. Exclusion Code: X8.16951908
632 Vestergaard P, Schwartz F, Rejnmark L, . Risk of femoral shaft and subtrochanteric fractures among users of bisphosphonates and raloxifene. Osteoporos Int. 2011 Mar;22(3):993-1001. doi: 10.1007/s00198-010-1512-y [doi]. PMID: 21165600. Exclusion Code: X20.21165600
633 Vestergaard P, Schwartz K, Pinholt EM, . Gastric and esophagus events before and during treatment of osteoporosis. Calcif Tissue Int. 2010 Feb;86(2):110-5. doi: 10.1007/s00223-009-9323-x [doi]. PMID: 19957165. Exclusion Code: X20.19957165
634 Vestergaard P, Schwartz K, Pinholt EM, . Stroke in relation to use of raloxifene and other drugs against osteoporosis. Osteoporos Int. 2011 Apr;22(4):1037-45. doi: 10.1007/s00198-010-1276-4 [doi]. PMID: 20449570. Exclusion Code: X20.20449570
635 Vestergaard P, Schwartz K, Rejnmark L, . Oral bisphosphonate use increases the risk for inflammatory jaw disease: a cohort study. J Oral Maxillofac Surg. 2012 Apr;70(4):821-9. doi: 10.1016/j.joms.2011.02.093. PMID: 21764202. Exclusion Code: X20.21764202
636 Voelker R. Osteoporosis screening may be needed less often than previously believed. JAMA. 2012 Feb 15;307(7):654. doi: 10.1001/jama.2012.129. PMID: 22337665. Exclusion Code: X2.22337665
637 Von Muhlen D, Visby Lunde A, Barrett-Connor E, . Evaluation of the simple calculated osteoporosis risk estimation (SCORE) in older Caucasian women: the Rancho Bernardo study. Osteoporos Int. 1999;10(1):79-84. doi: 10.1007/s001980050198. PMID: 10501784. Exclusion Code: X9.10501784
638 Vujasinovic-Stupar N, Milic N, Petrovic-Rackov L, . Efficacy and safety of once monthly ibandronate treatment in patients with reduced bone mineral densityESTHER study. Srp Arh Celok Lek. 2010;138(1-2):56-61. Exclusion Code: X5.20422911
639 Walker MD, Cusano NE, Sliney J, Jr., . Combination therapy with risedronate and teriparatide in male osteoporosis. Endocrine. 2013 Aug;44(1):237-46. doi: 10.1007/s12020-012-9819-4 [doi]. PMID: 23099796. Exclusion Code: X8.23099796
640 Wang X, Sanyal A, Cawthon PM, . Prediction of new clinical vertebral fractures in elderly men using finite element analysis of CT scans. J Bone Miner Res. 2012 Apr;27(4):808-16. doi: 10.1002/jbmr.1539 [doi]. PMID: 22190331. Exclusion Code: X7.22190331
641 Wang YJ, Zhan JK, Huang W, . Effects of low-dose testosterone undecanoate treatment on bone mineral density and bone turnover markers in elderly male osteoporosis with low serumtestosterone. In Int J Endocrinol Exclusion Code: X7.
642 Watts NB, Brown JP, Cline G. Risedronate on 2 consecutive days a month reduced vertebral fracture risk at 1year compared with historical placebo. J Clin Densitom. 2010 Jan-Mar;13(1):56-62. doi: 10.1016/j.jocd.2009.09.005. PMID: 19942469. Exclusion Code: X4.19942469
643 Watts NB, Geusens P, Barton IP, . Relationship between changes in BMD and nonvertebral fracture incidence associated with risedronate: reduction in risk of nonvertebral fracture is not related to change in BMD. J Bone Miner Res. 2005 Dec;20(12):2097-104. doi: 10.1359/JBMR.050814 [doi]. PMID: 16294263. Exclusion Code: X9.16294263
644 Wei GS, Jackson JL. Postmenopausal bone density referral decision rules: correlation with clinical fractures. Mil Med. 2004 Dec;169(12):1000-4. PMID: 15646195. Exclusion Code: X11.15646195
645 Weidauer L, Binkley T, Beare T, . Do Sex Differences Exist in Rates of Falls and Fractures in Hutterite, Rural, and Nonrural Populations, Aged 20 to 66 Years? Clin Orthop Relat Res. 2015 Aug;473(8):2514-20. doi: 10.1007/s11999-015-4248-3 [doi]. PMID: 25762018. Exclusion Code: X7.25762018
646 Weinstein L, Ullery B. Identification of at-risk women for osteoporosis screening. Am J Obstet Gynecol. 2000 Sep;183(3):547-9. doi: 10.1067/mob.2000.106594. PMID: 10992172. Exclusion Code: X9.10992172
647 Wells G, Cranney A, Peterson J, . Risedronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008(1):Cd004523. doi: 10.1002/14651858.CD004523.pub3. PMID: 18254053. Exclusion Code: X7.18254053
648 Wells GA, Cranney A, Peterson J, . Alendronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008(1):Cd001155. doi: 10.1002/14651858.CD001155.pub2. PMID: 18253985. Exclusion Code: X3.18253985
649 Wells GA, Cranney A, Peterson J, . Etidronate for the primary and secondary prevention of osteoporotic fractures in postmenopausal women. Cochrane Database Syst Rev. 2008(1):Cd003376. doi: 10.1002/14651858.CD003376.pub3. PMID: 18254018. Exclusion Code: X3.18254018
650 Wihlborg A, Englund M, Akesson K, . Fracture predictive ability of physical performance tests and history of falls in elderly women: a 10-year prospective study. Osteoporos Int. 2015 Aug;26(8):2101-9. doi: 10.1007/s00198-015-3106-1 [doi]. PMID: 25832178. Exclusion Code: X7.25832178
651 Wilczek ML, Kalvesten J, Algulin J, . Digital X-ray radiogrammetry of hand or wrist radiographs can predict hip fracture risk--a study in 5,420 women and 2,837 men. Eur Radiol. 2013 May;23(5):1383-91. doi: 10.1007/s00330-012-2706-9 [doi]. PMID: 23229168. Exclusion Code: X12.23229168
652 Winzenrieth R, Dufour R, Pothuaud L, . A retrospective case-control study assessing the role of trabecular bone score in postmenopausal Caucasian women with osteopenia: analyzing the odds of vertebral fracture. Calcif Tissue Int. 2010 Feb;86(2):104-9. doi: 10.1007/s00223-009-9322-y [doi]. PMID: 19998029. Exclusion Code: X11.19998029
653 Wong AK, Beattie KA, Min KK, . A Trimodality Comparison of Volumetric Bone Imaging Technologies. Part III: SD, SEE, LSC Association With Fragility Fractures. J Clin Densitom. 2015 Jul-Sep;18(3):408-18. doi: 10.1016/j.jocd.2014.07.003. PMID: 25129407. Exclusion Code: X7.25129407
654 Woo C, Gao G, Wade S, . Gastrointestinal side effects in postmenopausal women using osteoporosis therapy: 1-year findings in the POSSIBLE US study. Curr Med Res Opin. 2010 Apr;26(4):1003-9. doi: 10.1185/03007991003633603 [doi]. PMID: 20201623. Exclusion Code: X4.20201623
655 Wood WA, Muss H. Quantitation of individual risk for osteoporotic fracture. Oncology (Williston Park). 2010 Jul;24(8):753-5. PMID: 20718256. Exclusion Code: X8.20718256
656 Wyshak G. Percent body fat, fractures and risk of osteoporosis in women. J Nutr Health Aging. 2010 Jun;14(6):428-32. PMID: 20617283. Exclusion Code: X8.20617283
657 Xu L, Tsai KS, Kim GS, . Efficacy and safety of bazedoxifene in postmenopausal Asian women. Osteoporos Int. 2011 Feb;22(2):559-65. doi: 10.1007/s00198-010-1259-5 [doi]. PMID: 20535607. Exclusion Code: X5.20535607
658 Yaffe K, Krueger K, Cummings SR, . Effect of raloxifene on prevention of dementia and cognitive impairment in older women: the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. Am J Psychiatry. 2005 Apr;162(4):683-90. doi: 10.1176/appi.ajp.162.4.683. PMID: 15800139. Exclusion Code: X9.15800139
659 Yamamoto T, Taketsuna M, Guo X, . The safety and effectiveness profile of daily teriparatide in a prospective observational study in Japanese patients with osteoporosis at high risk for fracture: interim report. J Bone Miner Metab. 2014;32(6):699-708. Exclusion Code: X3.24368586
660 Yamamoto T, Tsujimoto M, Sowa H. Safety of daily teriparatide treatment: A post hoc analysis of a Phase III study to investigate the possible association of teriparatide treatment with calcium homeostasis in patients with serum procollagen type I N-terminal propeptide elevation. In Clin Interv Aging Exclusion Code: X9.
661 Yang Y, Luo X, Xie X, . Influences of teriparatide administration on marrow fat content in postmenopausal osteopenic women using MR spectroscopy. Climacteric. 2016;19(3):285-91. Exclusion Code: X5.26744910
662 Yarnall AJ, Duncan GW, Khoo TK, . Falling short: underestimation of fracture risk in atypical parkinsonian syndromes. Parkinsonism Relat Disord. 2012 Jun;18(5):692-3. doi: 10.1016/j.parkreldis.2012.01.004. PMID: 22265139. Exclusion Code: X3.22265139
663 Yazdani S, Iranpour Asli A, Salemi A, . Determination of clinical decision rule for estimation of bone mineral density in women. Med Princ Pract. 2011;20(5):416-21. doi: 10.1159/000327661. PMID: 21757929. Exclusion Code: X4.21757929
664 Yu R, Leung J, Woo J. Sarcopenia combined with FRAX probabilities improves fracture risk prediction in older Chinese men. J Am Med Dir Assoc. 2014 Dec;15(12):918-23. doi: 10.1016/j.jamda.2014.07.011. PMID: 25262197. Exclusion Code: X3.25262197
665 Yun H, Delzell E, Ensrud KE, . Predicting hip and major osteoporotic fractures using administrative data. Arch Intern Med. 2010 Nov 22;170(21):1940-2. doi: 10.1001/archinternmed.2010.410. PMID: 21098356. Exclusion Code: X2.21098356
666 Zanchetta JR, Farias J, Bogado CE, . A clinicaltrial on the efficacy and safety of two teriparatide formulations. In Osteoporos Int Exclusion Code: X8.
667 Zegels B, Eastell R, Russell RG, . Effect of high doses of oral risedronate (20 mg/day) on serumparathyroid hormone levels and urinary collagen cross-link excretion in postmenopausal women with spinal osteoporosis. Bone. 2001 Jan;28(1):108-12. PMID: 11165950. Exclusion Code: X3.11165950
668 Zein CO, Jorgensen RA, Clarke B, . Alendronate improves bone mineral density in primary biliary cirrhosis: a randomized placebo-controlled trial. Hepatology. 2005 Oct;42(4):762-71. doi: 10.1002/hep.20866. PMID: 16175618. Exclusion Code: X3.16175618
669 Zerbini CAF, Szejnfeld VL, Abergaria BH, . Incidence of hip fracture in Brazil and the development of a FRAX model. Archives of Osteoporosis. 2015;10(1). Exclusion Code: X5.25910867
670 Zhang L, Lv H, Zheng H, . Correlation between Parameters of Calcaneal Quantitative Ultrasound and Hip Structural Analysis in Osteoporotic Fracture Patients. PLoS One. 2015;10(12):e0145879. doi: 10.1371/journal.pone.0145879. PMID: 26710123. Exclusion Code: X3.26710123
671 Zhang ZL, Liao EY, Xia WB, . Alendronate sodium/vitamin D3 combination tablet versus calcitriol for osteoporosis in Chinese postmenopausal women: a 6-month, randomized, open-label, active-comparator-controlled study with a 6-month extension. In Osteoporosis international: a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA Exclusion Code: X8.
672 Zheng S, Wu Y, Zhang Z, . Effects of raloxifene hydrochloride on bone mineral density, bone metabolism and serumlipids in postmenopausal women: a randomized clinical trial in Beijing. Chin Med J (Engl). 2003 Aug;116(8):1127-33. PMID: 12935394. Exclusion Code: X5.12935394
673 Zhu K, Devine A, Lewis JR, . “Timed up and go” test and bone mineral density measurement for fracture prediction. Arch Intern Med. 2011 Oct 10;171(18):1655-61. doi: 10.1001/archinternmed.2011.434. PMID: 21987195. Exclusion Code: X8.21987195
674 Ziemlewicz TJ, Binkley N, Pickhardt PJ. Opportunistic Osteoporosis Screening: Addition of Quantitative CT Bone Mineral Density Evaluation to CT Colonography. J Am Coll Radiol. 2015 Oct;12(10):1036-41. doi: 10.1016/j.jacr.2015.04.018. PMID: 26435117. Exclusion Code: X7.26435117