# Appendix B Inclusion and Exclusion Criteria

Screening For Osteoporosis: Inclusion And Exclusion Criteria

Include or Exclude Question | Exclusion Code | Reason for Exclusion | Inclusion Criteria | Exclusion Criteria
1. Was the article published in English? | X1 | Not published in English | Study must be published in English | Study not published in English
2. Does the title/abstract represent original research? | X2 | Not original research | Published or unpublished original research | Nonsystematic review article, letter, or editorial; articles in which results are reported elsewhere; articles with no original data
3. KQs 1–3: Does the study report on general primary care men and women age ≥40 years without history of low trauma fractures; or endocrine disorders likely to be related to metabolic bone disease, such as premature ovarian failure, hypogonadism, untreated hyperthyroidism, hyperparathyroidism, adrenal insufficiency or Cushingʼs syndrome; or chronic use of glucocorticoids medications (>5 mg/d oral prednisone (or equivalent) for 3 months or longer)? KQs 4, 5: Does the review report on adults age 240 years with increased fracture risk? | X3 | Wrong population | KQs 1–3: General primary care men and women age ≥40 years without history of low trauma fractures; or endocrine disorders likely to be related to metabolic bone disease, such as premature ovarian failure, hypogonadism, untreated hyperthyroidism, hyperparathyroidism, adrenal insufficiency or Cushingʼs syndrome; or chronic use of glucocorticoids medications (>5 mg/d oral prednisone (or equivalent) for 3 months or longer) KQs 4, 5: Majority are adults with increased fracture risk | KQs 1–5:; - Majority of study population has underlying medical condition likely to be related to metabolic bone disease or is already receiving treatment for osteoporosis or has experienced a low-trauma facture; - Nonhuman populations; - Majority of study population comprises adults younger than age 40 years; KQs 4, 5: Majority are adults with no increased fracture risk
4. Does the study use of a study design of interest? | X4 | Wrong study design | KQs 1–3:; - Randomized, controlled trials; - Controlled clinical trials; - Systematic reviews of trials; KQs 2, 3: Observational studies other than case series and case reports KQ 4: Systematic reviews and randomized controlled trials, controlled trials published since any recent, relevant review KQ 5: Systematic reviews and randomized controlled trials, controlled trials, and observational studies published since any recent, relevant review | KQ 1: Nonrandomized, controlled trials; noncontrolled clinical trials, or nonsystematic reviews of trials KQs 2, 3: Case series, case reports KQs 4, 5: Nonsystematic reviews, case series, case reports KQ 4: Case control studies^a^
5. Does the study include countries with a human development index (HDI) similar to the United States? | X5 | Wrong geographical setting | KQs 1, 4, 5: U.S. adult population or comparable populations (i.e., those categorized as “Very High” on the Human Development Index, as defined by the United Nations Development Programme)^b^ KQs 2, 3: Include all geographic settings | KQs 1, 4 5: Settings not comparable or applicable to U.S. adult population KQs 2, 3: Include all geographic settings at this time
6. Is the study conducted in a clinical setting of interest? | X6 | Wrong clinical setting | KQ 1: Primary care or primary care–like settings KQs 2–5: Primary care or primary care–like settings, specialists | KQ 1: Inpatient, medical specialty (e.g., endocrinology), or nursing home settings KQs 2–5: Inpatient or nursing home settings
7. Does the study include an intervention of interest? | X7 | Wrong or no intervention | KQs 1–3: Externally validated and publicly available risk assessment instruments for low bone mass, osteoporosis, or fracture risk (interventions available in the United States) Risk assessment tools are any paper-based or electronic approach/instrument that compiles/consolidates various demographic or clinical characteristics of an individual and compares an individualʼs characteristics against a threshold or guideline to make a subsequent decision for testing or treatment. Examples include age, body weight criterion, Brownʼs clinical risk assessment, “clinical guidelines,” “case identification algorithm,” Elderly Falls Screening Test, Fracture absolute risk assessment, Garvan Fracture Risk Calculator, Male Osteoporosis Risk Estimation Score (MORES), NOF guidelines, Nomograms, Osteoporosis Self-Assessment Tool; Osteoporosis Self assessment Tool for Asians (OSTA); modified OSTA, ORAI, OSIRIS, QFracture algorithm, Simple Calculated Osteoporosis Risk Estimate (SCORE)^a^ Eligible bone measurement testing includes DXA (central or peripherally measured) and quantitative ultrasound, also include dental bone tests and trabecular bone score^a^ | KQs 1–3:; - Not externally validated or publicly available risk assessment or bone measurement testing specifically for osteoporosis or fracture risk^a^; - Test not widely for routine clinical use in the United States; KQs 2, 3: Non-FDA approved tests for screening; biomarkers of bone metabolism, quantitative CT, MRI, hip structural analysis, structural engineering models, finite element analysis
7. Does the study include an intervention of interest? (continued) | | | KQs 4, 5: Pharmacotherapy for the treatment or prevention of osteoporosis (including b isphosphonates, estrogen agonists/antagonists, hormone therapy, parathyroid hormone, and RANK Ligand Inhibitors) -Note: Bazedoxifine alone is not FDA approved, calcitonin is no longer used as first-line therapy^a^ | KQs 4, 5: Interventions other than those described in the inclusion criteria
8. Does the study include a comparator of interest? | X8 | Wrong or no comparator | KQ 1 (control interventions): No screening group KQs 2, 3 (control interventions): Other risk assessment/testing approach, threshold, or interval; DXA screening at hip or lumbar spine reporting T-scores based on NHANES III US White Female reference ranges^a^ KQ 4 (control interventions): Placebo KQ 5 (control interventions): Pacebo or no treatment | KQ 1 (control interventions): Lack of a no screening group (active comparator) KQ 2 (control interventions): Not an active comparator; no comparator, DXA screening at peripheral sites, other non-central DXA imaging tests (e.g., quantitative ultrasound), T-scores based on non-NHANES or local reference ranges^a^ KQ 3: None KQs 4, 5 (control interventions): Active comparator
9. Does the study include an outcome of interest? | X9 | Wrong or no outcome | All KQs: Fractures, fracture-related morbidity, fracture-related mortality, or all-cause mortality. Fractures include “major osteoporotic fractures, ” which include fractures of the hip, wrist (including distal radius), humerus, and spine/vertebral (clinically presenting). Morphometric spine/ vertebral fractures will also be included but recorded separately if possible^a^ KQ 2:; - Screening test characteristics (e.g., Youdenʼs index, sensitivity, specificity, area under the receiver operating characteristic curve or AUC, positive predictive value, negative predictive value, diagnostic odds ratio, likelihood ratio)^a^ and reliability (test-retest measures such as Kappa)^a^ of risk assessment (for fractures)^a^, bone mass measurement (for fractures or identification of osteoporosis)^a^, or both (for fractures)^a^; - Fracture risk prediction characteristics (overall model performance [Brier score, R-squared] extended measures of discrimination [concordance statistic c, discrimination slope], calibration [calibration-in-the-large, calibration slope, “goodness-of-fit” test or Hosmer-Lemeshow test], reclassfication [reclassification table, reclassification calibration, net reclassification improvement, integrated discrimination improvement]), and clinical usefulness (net benefit, decision curve analysis)^a^; - Risk assessment instruments for identifying osteoporosis: AUC for ROC curves for identifying BMD ≤-2.5 | Exclude if: KQ 1 and KQ 4:; - Nonvalidated fractures (i.e., self-reported)^a^, fracture-related morbidity, or fracture-related mortality; - Bone measurement testing (T-scores, z-scores); KQ 2: Outcomes other than screening test or risk prediction characteristics^a^ ● KQs 3, 5: No health outcomes excluded for harms^a^
9. Does the study include an outcome of interest? (continued) | | | KQ 3: Harms (e.g., unnecessary radiation, labeling, anxiety, false-positive results) KQ 5: Harms (e.g., cardiovascular events, hot flashes, esophageal cancer, gastrointestinal events, osteonecrosis of the jaw, atypical fractures of the femur, rashes)

a Italicized text represents additional clarification to operationalize inclusion and exclusion criteria.

b Very high human development index countries include Norway, Australia, Switzerland, Denmark, Netherlands, Germany, Ireland, United States, Canada, New Zealand, Singapore, Hong Kong, China (SAR), Liechtenstein, Sweden, United Kingdom, Iceland, Korea (Republic of), Israel, Luxembourg, Japan, Belgium, France, Austria, Finland, Slovenia, Spain, Italy, Czech Republic, Greece, Estonia, Brunei Darussalam, Cyprus, Qatar, Andorra, Slovakia, Poland, Lithuania, Malta, Saudi Arabia, Argentina, United Arab Emirates, Chile, Portugal, Hungary, Bahrain, Latvia, Croatia, Kuwait, Montenegro (http://hdr.undp.org/en/content/table-1-human-development-index-and-its-components).